# Appendix A Detailed Methods

## Appendix A1 Search Strategies

Database: Database: Ovid MEDLINE^®^

Search Strategy:

------------------------------------------------------------

1. exp Breast Neoplasms/pc [Prevention & Control]
2. exp aromatase inhibitors/ad, ae, tu, to
3. 1 and 2
4. exp breast neoplasms/
5. Chemoprevention/
6. 4 and 5
7. 2 and 6
8. ((prevent* or chemoprev* or prophyla* or risk*) adj10 ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*) adj7 (exemestane or Aromasin or anastrozole or Arimidex or letrozole or Femara or (aromatas* adj3 (block* or interfer* or inhibit* or antagoni*))))).mp.
9. (chemoprev* adj7 ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*))).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms]
10. (risk* adj5 (reduc* or lower* or adjust* or assess* or compar* or alter* or chang* or calculat*) adj7 ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*))).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms]
11. 9 or 10
12. 2 and 11
13. 3 or 7 or 8
14. 3 or 7 or 8 or 12
15. limit 14 to english language
16. limit 14 to abstracts
17. 15 or 16

Database: Database: Ovid MEDLINE^®^ without Revisions

Search Strategy:

------------------------------------------------------------

1. exp Breast Neoplasms/pc [Prevention & Control]
2. exp Tamoxifen/ad, ae, tu, to
3. 1 and 2
4. exp breast neoplasms/
5. Chemoprevention/
6. 4 and 5
7. 2 and 6
8. ((prevent* or chemoprev* or prophyla*) adj10 ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*) adj7 (tamoxif* or raloxif* or serm* or (selectiv* adj3 estrogen* adj3 receptor* adj3 modulat*)))).mp.
9. (chemoprev* adj7 ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*))).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms]
10. (risk* adj5 (reduc* or lower* or adjust* or assess* or compar* or alter* or chang* or calculat*) adj7 ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*))).mp.
11. 9 or 10
12. 2 and 4 and 11
13. 3 or 7 or 8 or 12
14. limit 13 to humans
15. limit 14 to english language
16. limit 14 to abstracts
17. 15 or 16

Database: EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

------------------------------------------------------------

1. ((prevent* or chemoprev* or prophyla*) adj10 ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*) adj7 (exemestane or Aromasin or anastrozole or Arimidex or letrozole or Femara or (aromatas* adj3 (block* or interfer* or inhibit* or antagoni*))))).mp.
2. ((prevent* or chemoprev* or prophyla*) adj10 ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*) adj7 (tamoxif* or raloxif* or serm* or (selectiv* adj3 estrogen* adj3 receptor* adj3 modulat*)))).mp.
3. limit 2 to yr="2013 -Current"
4. ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*) adj10 ((drug* or pharmac* or prescri* or dose* or dosag*) adj7 (risk* adj5 (reduc* or lower* or adjust* or assess* or compar* or alter* or chang* or calculat*)))).mp. [mp=title, abstract, full text, keywords, caption text]
5. ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*) adj10 chemoprev*).mp. [mp=title, abstract, full text, keywords, caption text]
6. 1 or 3 or 4 or 5
7. 1 or 3 or 4 or 5

Database: Cochrane Central Register of Controlled Trials

Search Strategy:

------------------------------------------------------------

1. ((prevent* or chemoprev* or prophyla*) adj10 ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*) adj7 (exemestane or Aromasin or anastrozole or Arimidex or letrozole or Femara or (aromatas* adj3 (block* or interfer* or inhibit* or antagoni*))))).mp.
2. ((prevent* or chemoprev* or prophyla*) adj10 ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*) adj7 (tamoxif* or raloxif* or serm* or (selectiv* adj3 estrogen* adj3 receptor* adj3 modulat*)))).mp.
3. limit 2 to yr="2013 -Current"
4. ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*) adj10 ((drug* or pharmac* or prescri* or dose* or dosag*) adj7 (risk* adj5 (reduc* or lower* or adjust* or assess* or compar* or alter* or chang* or calculat*)))).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5. ((breast* or mammar*) adj5 (cancer* or neoplas* or tumor* or tumour* or carcino* or adenocarcin* or malig*) adj10 chemoprev*).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
6. 1 or 3 or 4 or 5

Database: Elsevier Embase®

Search Strategy:

------------------------------------------------------------

((((‘tamoxifen’/exp OR ‘tamoxifen’/exp OR tamoxifen OR ‘raloxifene’/exp OR ‘raloxifene’/exp OR raloxifene) AND ‘breast cancer’/exp AND ‘risk reduction’/exp OR ‘breast cancer’/exp) AND ‘chemoprophylaxis’/exp AND [embase]/lim NOT [medline]/lim OR ‘aromatase inhibitor’/exp OR ‘aromatase inhibitor’ OR ‘aminoglutethimide’/exp OR ‘aminoglutethimide’/exp OR aminoglutethimide OR ‘testolactone’/exp OR ‘testolactone’/exp OR testolactone OR ‘anastrozole’/exp OR ‘anastrozole’/exp OR anastrozole OR ‘letrozole’/exp OR ‘letrozole’/exp OR letrozole OR ‘exemestane’/exp OR ‘exemestane’/exp OR exemestane OR ‘vorozole’/exp OR ‘vorozole’/exp OR vorozole OR ‘formestane’/exp OR ‘formestane’/exp OR formestane OR ‘fadrozole’/exp OR ‘fadrozole’/exp OR fadrozole) AND ‘breast cancer’/exp AND ‘risk reduction’/exp OR ‘breast cancer’/exp) AND ‘chemoprophylaxis’/exp AND [embase]/lim NOT [medline]/lim AND [english]/lim AND [humans]/lim

## Appendix A2 Inclusion and Exclusion Criteria

| Included | Excluded
Populations | Women without preexisting breast cancer, including women who are known carriers of BRCA genetic mutations and women with previous nonmalignant breast biopsies (e.g., atypical hyperplasia) | Women with preexisting breast cancer (invasive or ductal carcinoma in situ); men; populations dissimilar to those in the U.S.
Interventions | KQ 1: Risk assessment; KQs 2–4: Tamoxifen, raloxifene, and aromatase inhibitors | KQ 1: Risk assessment done by a specialist or not able to be completed in primary care setting; KQs 2–4: Medications not used or available in the U.S.; other medications not listed as included
Comparisons | KQ 1: Risk assessment methods vs. usual care or an alternative risk assessment method; KQs 2–4: Medication vs. placebo; tamoxifen vs. raloxifene, tamoxifen vs. aromatase inhibitors, and raloxifene vs. aromatase inhibitors | Comparisons with other types of medications
Outcomes | KQ 1: Measures of risk assessment test performance (sensitivity, specificity; positive and negative likelihood ratio; c-statistic); KQs 2, 4: Invasive and noninvasive breast cancer incidence; breast cancer and all-cause mortality; other beneficial outcomes (e.g., reduced fractures caused by certain medications); KQs 3, 4: Adverse effects (including but not limited to: thromboembolic events, cardiovascular events, metabolic disorders, musculoskeletal symptoms, mental health, genitourinary outcomes, adverse breast outcomes, other malignancies, ophthalmologic disorders, gastrointestinal/hepatobiliary disorders, other adverse events affecting quality of life) | Other outcomes
Setting | Primary care settings; settings comparable to U.S. practice | Practice settings dissimilar to those in the U.S.
Study Design | KQ 1: Discriminatory accuracy studies; KQs 1a, 1b, 2–4: Randomized, controlled trials; observational studies, with or without comparison groups, except for efficacy (KQ 2) | Other study designs
Study Quality | Good- and fair-quality studies for meta-analyses | Poor-quality studies

Abbreviations: BRCA=breast cancer susceptibility gene; KQ=key questions; U.S.=United States.

## Appendix A3 Literature Flow Diagram

* Other sources include reference lists of relevant articles, studies, and systematic reviews, suggestions from reviewers, etc. and Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews

^†^ See Appendix A4 for the list of excluded studies and Appendix A2 for the list of exclusion criteria.

^‡^ Studies that provided data and contributed to the body of evidence were considered ‘included.’

^ǁ^ Studies may have been used to answer more than one question.

^¶^ This includes 46 studies in 82 publications.

^§^ This includes 1 new publication of long-term results for the International Breast Cancer Intervention Study (IBIS-I), which was included in the prior report and 3 new trials (2 of aromatase inhibitors and 1 of low dose tamoxifen).

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows that 1786 abstracts of potentially relevant articles were identified through MEDLINE, Cochrane databases (including the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews), EMBASE and other sources (reference lists of relevant articles, studies, and systematic reviews, suggestions from reviewers, etc.). Of these 1269 citations were excluded for not being relevant to the key questions, and 50 papers were pulled for relevance to the contextual questions. The remaining 467 articles were retrieved and reviewed at the full-text level. Of these 454 were excluded for the following reasons: background information only (68), used for contextual questions only (14), population not applicable (34), intervention not applicable (38), wrong outcomes (74), companion paper, data not used (15), non-systematic or outdated review (78), wrong study design for key question (9), wrong publication type (122), or non-English language paper (2). An additional 101 full-text articles from the prior report were reviewed for inclusion in this report. Of these 32 were excluded for the following reasons: background information only (2), used for contextual questions only (6), intervention not appropriate (3), wrong outcomes (13), companion paper, data not used (7), or non-systematic review (1). After exclusion of these studies, 46 studies in 82 publications were included that provide evidence for the key questions, as follows: 6 new studies and 19 studies from the prior report for Key Question 1, 4 new trials in 7 publications and 7 trials in 33 publications from the prior report for Key Question 2, 5 new trials in 8 publications and 18 studies in 46 publications from the prior report for Key Question 3, and 2 new trials in 2 publications and 7 trials in 10 publications from the prior report for Key Question 4.

1 Nelson HD, Smith ME, Griffin JC, Fu R. Use of medications to reduce risk for primary breast cancer: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013;158(8):604–614.23588749

## Appendix A4 List of Excluded Studies

Exclusions From Key Questions Code: 2: background information only; 3: contextual information only; 4: ineligible population; 5: ineligible intervention; 6: ineligible outcome; 7; ineligible publication type; 9: ineligible study design; 10: non-English paper; 11: nonsystematic review or companion paper not used for evidence.

### Excluded From Prior Report

1 Archer DF, Pinkerton JV, Utian WH, . Bazedoxifene, a selective estrogen receptor modulator: effects on the endometrium, ovaries, and breast from a randomized controlled trial in osteoporotic postmenopausal women. Menopause. 2009;16(6):1109–115. doi: 10.1097/gme.0b013e3181a818db PMID: 19543129 Exclusion: 519543129
2 Armstrong K, Quistberg DA, Micco E, . Prescription of tamoxifen for breast cancer prevention by primary care physicians. Arch. Intern. Med. 2006 Nov 13;166(20):2260–5. doi: 10.1001/archinte.166.20.2260. PMID: 17101945. Exclusion: 317101945
3 Bastian LA, Lipkus IM, Kuchibhatla MN, . Women’s interest in chemoprevention for breast cancer. Arch. Intern. Med. 2001 Jul 9;161(13):1639–44. PMID: 11434796. Exclusion: 611434796
4 Bober SL, Hoke LA, Duda RB, . Decision-making about tamoxifen in women at high risk for breast cancer: Clinical and psychological factors. J. Clin. Oncol. 2004;22(24):4951–7. doi: 10.1200/JCO.2004.05.192. PMID: 15598980. Exclusion: 315598980
5 Boyd NF, Guo H, Martin LJ, . Mammographic density and the risk and detection of breast cancer. N. Engl. J. Med. 2007 Jan 18;356(3):227–36. doi: 10.1056/NEJMoa062790. PMID: 17229950. Exclusion: 617229950
6 Coopey SB, Mazzola E, Buckley JM, . The role of chemoprevention in modifying the risk of breast cancer in women with atypical breast lesions. Breast Cancer Res. Treat. 2012 Dec;136(3):627–33. doi: 10.1007/s10549-012-2318-8. PMID: 23117858. Exclusion: 223117858
7 Cramer JA, Roy A, Burrell A, . Medication compliance and persistence: terminology and definitions. Value Health. 2008 Jan–Feb;11(1):44–7. doi: 10.1111/j.1524-4733.2007.00213.x. PMID: 18237359. Exclusion: 618237359
8 Cummings SR, Ettinger B, Delmas PD, . The effects of tibolone in older postmenopausal women. N. Engl. J. Med. 2008;359(7):697–708. doi: 10.1056/NEJMoa0800743. PMID: 18703472. Exclusion: 518703472
9 Day R. Quality of life and tamoxifen in a breast cancer prevention trial: a summary of findings from the NSABP P-1 study. National Surgical Adjuvant Breast and Bowel Project. Ann. N. Y. Acad. Sci. 2001 Dec;949:143–50. PMID: 11795346. Exclusion: 1111795346
10 Day R, Ganz PA, Costantino JP, . Health-related quality of life and tamoxifen in breast cancer prevention: a report from the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J. Clin. Oncol. 1999 Sep;17(9):2659–69. PMID: 10561339. Exclusion: 1110561339
11 Ensrud K, Riccardo Genazzani A, Geiger MJ, . Effect of Raloxifene on cardiovascular adverse events in postmenopausal women with osteoporosis. Am. J. Cardiol. 2006;97(4):520–7. PMID: 16461049. Exclusion: 1116461049
12 Fagerlin A, Dillard AJ, Smith DM, . Women’s interest in taking tamoxifen and raloxifene for breast cancer prevention: response to a tailored decision aid. Breast Cancer Res. Treat. 2011 Jun;127(3):681–8. doi: 10.1007/s10549-011-1450-1. PMID: 21442198. Exclusion: 621442198
13 Fagerlin A, Zikmund-Fisher BJ, Nair V, . Women’s decisions regarding tamoxifen for breast cancer prevention: responses to a tailored decision aid. Breast Cancer Res. Treat. 2010 Feb;119(3):613–20. doi: 10.1007/s10549-009-0618-4. PMID: 19908143. Exclusion: 319908143
14 Freedman M, San Martin J, O’Gorman J, . Digitized mammography: a clinical trial of postmenopausal women randomly assigned to receive raloxifene, estrogen, or placebo. J. Natl. Cancer Inst. 2001 Jan 3;93(1):51–6. PMID: 11136842. Exclusion: 611136842
15 Gail MH, Costantino JP, Pee D, . Projecting individualized absolute invasive breast cancer risk in African American women. J. Natl. Cancer Inst. 2007;99(23):1782–92. doi: 10.1093/jnci/djm223 PMID: 18042936. Exclusion: 518042936
16 Goldstein SR, Johnson S, Watts NB, . Incidence of urinary incontinence in postmenopausal women treated with raloxifene or estrogen. Menopause. 2005 Mar;12(2):160–4. PMID: 15772563. Exclusion: 1115772563
17 Iqbal J, Ginsburg OM, Wijeratne TD, . Endometrial cancer and venous thromboembolism in women under age 50 who take tamoxifen for prevention of breast cancer: a systematic review. Cancer Treat. Rev. 2012 Jun;38(4):318–28. doi: 10.1016/j.ctrv.2011.06.009. PMID: 21775065. Exclusion: 721775065
18 Kaplan CP, Kim SE, Wong ST, . Willingness to use tamoxifen to prevent breast cancer among diverse women. Breast Cancer Res. Treat. 2012 May;133(1):357–66. doi: 10.1007/s10549-012-1960-5. PMID: 22315131. Exclusion: 322315131
19 Land SR, Cronin WM, Wickerham DL, . Cigarette smoking, obesity, physical activity, and alcohol use as predictors of chemoprevention adherence in the National Surgical Adjuvant Breast and Bowel Project P-1 Breast Cancer Prevention Trial. Cancer Prev. Res. (Phila.). 2011 Sep;4(9):1393–400. doi: 10.1158/1940-6207.CAPR-11-0172. PMID: 21862698. Exclusion: 621862698
20 Lee EO, Ahn SH, You C, . Determining the main risk factors and high-risk groups of breast cancer using a predictive model for breast cancer risk assessment in South Korea. Cancer Nurs. 2004 Sep–Oct;27(5):400–6. PMID: 15525868. Exclusion: 615525868
21 Martino S, Costantino J, McNabb M, . The role of selective estrogen receptor modulators in the prevention of breast cancer: comparison of the clinical trials. Oncologist. 2004;9(2):116–25. PMID: 15047916. Exclusion: 1115047916
22 McKay A, Martin W, Latosinsky S. How should we inform women at higher risk of creast cancer about tamoxifen? An approach with a decision guide. Breast Cancer Res. Treat. 2005;94(2):153–9. doi: 10.1007/s10549-005-6932-6. PMID: 16261414. Exclusion: 316261414
23 Melnikow J, Paterniti D, Azari R, . Preferences of Women Evaluating Risks of Tamoxifen (POWER) study of preferences for tamoxifen for breast cancer risk reduction. Cancer. 2005 May 15;103(10):1996–2005. doi: 10.1002/cncr.20981. PMID: 15825209. Exclusion: 315825209
24 Ozanne EM, Wittenberg E, Garber JE, . Breast cancer prevention: patient decision making and risk communication in the high risk setting. Breast J. 2010 Jan-Feb;16(1):38–47. doi: 10.1111/j.1524-4741.2009.00857.x. PMID: 19889168. Exclusion: 619889168
25 Port ER, Montgomery LL, Heerdt AS, . Patient reluctance toward tamoxifen use for breast cancer primary prevention. Ann. Surg. Oncol. 2001 Aug;8(7):580–5. PMID: 11508619. Exclusion: 611508619
26 Schonfeld SJ, Pee D, Greenlee RT, . Effect of Changing Breast Cancer Incidence Rates on the Calibration of the Gail Model. J. Clin. Oncol. 2010;28(14):2411–7. doi: 10.1200/JCO.2009.25.2767. PMID: 20368565. Exclusion: 220368565
27 Taylor R, Taguchi K. Tamoxifen for breast cancer chemoprevention: low uptake by high-risk women after evaluation of a breast lump. Ann. Fam. Med. 2005 May-Jun;3(3):242–7. doi: 10.1370/afm.284. PMID: 15928228. Exclusion: 615928228
28 Veronesi A, Pizzichetta MA, Ferlante MA, . Tamoxifen as adjuvant after surgery for breast cancer and tamoxifen or placebo as chemoprevention in healthy women: different compliance with treatment. Tumori. 1998 May–Jun;84(3):372–5. PMID: 9678620. Exclusion: 69678620
29 Veronesi U, Maisonneuve P, Sacchini V, . Tamoxifen for breast cancer among hysterectomised women. Lancet. 2002 Mar 30;359(9312):1122–4. doi: 10.1016/s0140-6736(02)08159-x. PMID: 11943263. Exclusion: 1111943263
30 Vogel VG, Costantino JP, Wickerham DL, . Carcinoma in situ outcomes in National Surgical Adjuvant Breast and Bowel Project Breast Cancer Chemoprevention Trials. J. Natl. Cancer Inst. Monogr. 2010;2010(41):181–6. doi: 10.1093/jncimonographs/lgq041. PMID: 20956826. Exclusion: 1120956826
31 Walsh BW, Kuller LH, Wild RA, . Effects of raloxifene on serum lipids and coagulation factors in healthy postmenopausal women. JAMA. 1998 May 13;279(18):1445–51. PMID: 9600478. Exclusion: 69600478
32 Yeomans Kinney A, Vernon SW, Shui W, . Validation of a model predicting enrollment status in a chemoprevention trial for breast cancer. Cancer Epidemiol. Biomarkers Prev. 1998 Jul;7(7):591–5. PMID: 9681527. Exclusion: 69681527

### Excludes From Searches

1 Raloxifene reduces risk of invasive estrogen-receptor positive breast cancer. J. Natl. Cancer Inst. 2008;100(12):829. doi: 10.1093/jnci/djn220. Exclusion: 7
2 Exemestane reduces breast cancer risk in high-risk postmenopausal women. J. Natl. Med. Assoc. 2012;104(1–2):118. Exclusion: 7
3 NICE guidelines back preventive therapy. Cancer Discov. 2013;3(3):OF5. doi: 10.1158/2159-8290.CD-NB2013-018. Exclusion: 7
4 Aromatase inhibitors versus tamoxifen in early breast cancer: patient-level meta-analysis of the randomised trials. Lancet. 2015 Oct 3;386(10001):1341–52. doi: 10.1016/s0140-6736(15)61074-1. PMID: 26211827. Exclusion: 226211827
5 Aapro MS. The safety profile of aromatase inhibitors used in adjuvant treatment of breast cancer. European J. Clin. Med. Oncol. 2010;2(4). Exclusion: 10
6 Abu-Rustum NR, Herbolsheimer H. Breast cancer risk assessment in indigent women at a public hospital. Gynecol. Oncol. 2001 May;81(2):287–90. doi: 10.1006/gyno.2001.6160. PMID: 11330964. Exclusion: 611330964
7 Advani P, Moreno-Aspitia A. Current strategies for the prevention of breast cancer. Breast Cancer (London). 2014;6:59–71. doi: 10.2147/BCTT.S39114. PMID: 24833917. Exclusion: 1024833917
8 Agrawal A, Fentiman IS. NSAIDs and breast cancer: a possible prevention and treatment strategy. Int. J. Clin. Pract. 2008 Mar;62(3):444–9. doi: 10.1111/j.1742-1241.2007.01668.x. PMID: 18194278. Exclusion: 518194278
9 Ahmad I, Shagufta. Recent developments in steroidal and nonsteroidal aromatase inhibitors for the chemoprevention of estrogen-dependent breast cancer. Eur. J. Med. Chem. 2015 Sep 18;102:375–86. doi: 10.1016/j.ejmech.2015.08.010. PMID: 26301554. Exclusion: 226301554
10 Ales-Martinez JE, Ruiz A, Chacon JI, . Preventive treatments for breast cancer: recent developments. Clinical & Translational Oncology: Official Publication of the Federation of Spanish Oncology Societes & of the National Cancer Institute of Mexico. 2015 Apr;17(4):257–63. doi: 10.1007/s12094-014-1250-2. PMID: 25445174. Exclusion: 1025445174
11 Allen S, Levine EA, Lesko N, . Is Excisional Biopsy and Chemoprevention Warranted in Patients With Atypical Lobular Hyperplasia on Core Biopsy? Am. Surg. 2015 Sep;81(9):876–8. PMID: 26350664. Exclusion: 826350664
12 American Cancer Society. Cancer Facts & Figures 2018. Atlanta: American Cancer Society, Inc.; 2018. https://www.cancer.org/content/dam/cancer-org/research/cancer-facts-and-statistics/annual-cancer-facts-and-figures/2018/cancer-facts-and-figures-2018.pdf. Accessed March 27 2019. Exclusion: 2
13 American Cancer Society. Breast Cancer Facts & Figures 2017-2018. Atlanta: American Cancer Society, Inc.; 2018. https://www.cancer.org/content/dam/cancer-org/research/cancer-facts-and-statistics/breast-cancer-facts-and-figures/breast-cancer-facts-and-figures-2017-2018.pdf. Accessed March 27 2019. Exclusion: 2
14 Amir E, Freedman OC, Seruga B, . Assessing women at high risk of breast cancer: a review of risk assessment models. J. Natl. Cancer Inst. 2010 May 19;102(10):680–91. doi: 10.1093/jnci/djq088. PMID: 20427433. Exclusion: 220427433
15 Anderson GL, Limacher M, Assaf AR, . Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women’s Health Initiative randomized controlled trial. JAMA. 2004 Apr 14;291(14):1701–12. doi: 10.1001/jama.291.14.1701. PMID: 15082697. Exclusion: 515082697
16 Anderson K, Jacobson JS, Heitjan DF, . Cost-effectiveness of preventive strategies for women with a BRCA1 or a BRCA2 mutation. Ann. Intern. Med. 2006 Mar 21;144(6):397–406. PMID: 16549852. Exclusion: 616549852
17 Anonymous. Anastrozole may aid breast cancer prevention. Cancer Discov. 2014 Feb;4(2):OF4. doi: 10.1158/2159-8290.CD-NB2013-179. PMID: 24501316. Exclusion: 724501316
18 Antoniou A, Pharoah PD, Narod S, . Average risks of breast and ovarian cancer associated with BRCA1 or BRCA2 mutations detected in case Series unselected for family history: a combined analysis of 22 studies. Am. J. Hum. Genet. 2003 May;72(5):1117–30. doi: 10.1086/375033. PMID: 12677558. Exclusion: 612677558
19 Antoniou AC, Cunningham AP, Peto J, . The BOADICEA model of genetic susceptibility to breast and ovarian cancers: updates and extensions. Br. J. Cancer. 2008 Apr 22;98(8):1457–66. doi: 10.1038/sj.bjc.6604305. PMID: 18349832. Exclusion: 518349832
20 Arun B, Gong Y, Liu D, . Phase I prevention study of atorvastatin in women at increased risk for breast cancer. Cancer Prev. Res. (Phila.). 2012 Annual AACR International Conference on Frontiers in Cancer Prevention Research Anaheim, CA United States;5(11 SUPPL. 1):CONFERENCE START: 2012 Oct 16 CONFERENCE END: Oct 19. Exclusion: 2
21 Arun BK, Gong Y, Liu D, . Phase I biomarker modulation study of atorvastatin in women at increased risk for breast cancer. Breast Cancer Res. Treat. 2016;158(1):67–77. doi: 10.1007/s10549-016-3849-1. PMID: 27287781. Exclusion: 627287781
22 Astley SM, Harkness EF, Sergeant JC, . A comparison of five methods of measuring mammographic density: a case-control study. Breast Cancer Res. 2018 Feb 5;20(1):10. doi: 10.1186/s13058-018-0932-z. PMID: 29402289. Exclusion: 629402289
23 AstraZeneca Pharmaceuticals LP. NOLVADEX (tamoxifen) Medication Guide. Wilmington, DE; 2004. https://www.fda.gov/downloads/drugs/drugsafety/ucm088661.pdf. Accessed March 27 2019. Exclusion: 2
24 Attri AK. Risk stratification of breast cancer. JIMSA. 2011;24(4):161. Exclusion: 7
25 Bagchi S. Education about tamoxifen lowers its appeal. Lancet Oncol. 2005;6(6):362. doi: 10.1016/S1470-2045(05)70193-5. Exclusion: 7
26 Bambhroliya A, Chavez-MacGregor M, Brewster AM. Barriers to the Use of Breast Cancer Risk Reduction Therapies. J. Natl. Compr. Canc. Netw. 2015 Jul;13(7):927–35. PMID: 26150584. Exclusion: 1026150584
27 Bandera B, Voci A, Lee J, . Disparities in endocrine risk reduction for young adult women with lobular carcinoma in situ. Ann. Surg. Oncol. 2016;23(3):324–5. doi: 10.1245/s10434-016-5195-2. Exclusion: 7
28 Banegas MP, McClure JB, Barlow WE, . Results from a randomized trial of a web-based, tailored decision aid for women at high risk for breast cancer. Patient Educ. Couns. 2013 Jun;91(3):364–71. doi: 10.1016/j.pec.2012.12.014. PMID: 23395006. Exclusion: 623395006
29 Barron TI, Connolly R, Bennett K, . Early discontinuation of tamoxifen: a lesson for oncologists. Cancer. 2007 Mar 01;109(5):832–9. doi: 10.1002/cncr.22485. PMID: 17243168. Exclusion: 617243168
30 Bartels PH, Fabian CJ, Kimler BF, . Karyometry of breast epithelial cells acquired by random periareolar fine needle aspiration in women at high risk for breast cancer. Anal. Quant. Cytol. Histol. 2007 Apr;29(2):63–70. PMID: 17484269. Exclusion: 517484269
31 Barton MK. Exemestane is effective for the chemoprevention of breast cancer. CA Cancer J. Clin. 2011 Nov–Dec;61(6):363–4. doi: 10.3322/caac.20131. PMID: 21898372. Exclusion: 721898372
32 Behan LA, Amir E, Casper RF. Aromatase inhibitors for prevention of breast cancer in postmenopausal women: a narrative review. Menopause. 2015 Mar;22(3):342–50. doi: 10.1097/GME.0000000000000426. PMID: 25692874. Exclusion: 1025692874
33 Bellcross CA, Lemke AA, Pape LS, . Evaluation of a breast/ovarian cancer genetics referral screening tool in a mammography population. Genet. Med. 2009 Nov;11(11):783–9. doi: 10.1097/GIM.0b013e3181b9b04a. PMID: 19752737. Exclusion: 519752737
34 Bevers TB. Breast cancer prevention: An update of the STAR trial. Curr. Treat. Options Oncol. 2010;11(3–4):66–9. doi: 10.1007/s11864-010-0124-2. PMID: 21061192. Exclusion: 721061192
35 Bevers TB, Ward JH, Arun BK, . Breast cancer risk reduction, version 2.2015 clinical practice guidelines in oncology clinical practice guidelines in oncology. J. Natl. Compr. Canc. Netw. 2015;13(7):880–915. Exclusion: 226150582
36 Bevilacqua G, Silingardi V, Marchetti P. Exemestane for the prevention of breast cancer in postmenopausal unaffected carriers of BRACA 1/2 mutations- aromasin prevention study (ApreS). Breast Cancer Res. Treat. 2001;69(3):226. Exclusion: 7
37 Biglia N. Phamacological strategies to prevent breast cancer. Maturitas. 2012;71:S2. doi: 10.1016/S0378-5122(12)70012-9. Exclusion: 7
38 Bilotto S, Spagnuolo C, Russo M, . Dietary phytochemicals in chemoprevention of cancer: An update. Immunology, Endocrine and Metabolic Agents in Medicinal Chemistry. 2013;13(1):2–24. doi: 10.2174/1871522211313010002. Exclusion: 5
39 Blakeslee SB, McCaskill-Stevens W, Parker PA, . Deciding on breast cancer risk reduction: The role of counseling in individual decision-making - A qualitative study. Patient Educ. Couns. 2017 Dec;100(12):2346–54. doi: 10.1016/j.pec.2017.06.033. PMID: 28734560. Exclusion: 528734560
40 Blakeslee SB, Parker PA, Gunn CM, . Decision-making in breast cancer risk reduction: Results from a nested qualitative study from NRG Oncology/NSABP protocol DMP-1. J. Clin. Oncol. 2015;33(15). Exclusion: 7
41 Body JJ. Increased fracture rate in women with breast cancer: a review of the hidden risk. BMC Cancer. 2011 Aug 29;11:384. doi: 10.1186/1471-2407-11-384. PMID: 21875433. Exclusion: 421875433
42 Bosetti C, Rosato V, Gallus S, . Aspirin and cancer risk: a quantitative review to 2011. Ann. Oncol. 2012 Jun;23(6):1403–15. doi: 10.1093/annonc/mds113. PMID: 22517822. Exclusion: 422517822
43 Bozovic-Spasojevic I, Azambuja E, McCaskill-Stevens W, . Chemoprevention for breast cancer. Cancer Treat. Rev. 2012 Aug;38(5):329–39. doi: 10.1016/j.ctrv.2011.07.005. PMID: 21856081. Exclusion: 721856081
44 Braithwaite RS, Chlebowski RT, Lau J, . Meta-analysis of vascular and neoplastic events associated with tamoxifen. J. Gen. Intern. Med. 2003 Nov;18(11):937–47. PMID: 14687281. Exclusion: 1014687281
45 Brentnall A. Relationship of ZNF423 and CTSO with breast cancer risk in two randomised tamoxifen prevention trials. Breast Cancer Res. Treat. 2016;158(3):591–6. PMID: 27400912. Exclusion: 227400912
46 Brentnall AR, Cuzick J, Buist DSM, . Long-term Accuracy of Breast Cancer Risk Assessment Combining Classic Risk Factors and Breast Density. JAMA oncology. 2018 Apr 5:e180174. doi: 10.1001/jamaoncol.2018.0174. PMID: 29621362. Exclusion: 629621362
47 Brewer NT, Defrank JT, Chiu WK, . Patients’ understanding of how genotype variation affects benefits of tamoxifen therapy for breast cancer. Public Health Genomics. 2014;17(1):43–7. doi: 10.1159/000356565. PMID: 24457521. Exclusion: 624457521
48 Brewster AM, Christo DK, Lai H, . Breast carcinoma chemoprevention in the community setting. Estimating risks and benefits. Cancer. 2005 Mar 15;103(6):1147–53. doi: 10.1002/cncr.20882. PMID: 15674856. Exclusion: 615674856
49 Brewster AM, Davidson NE, McCaskill-Stevens W. Chemoprevention for breast cancer: overcoming barriers to treatment. Am Soc Clin Oncol Educ Book. 2012:85–90. doi: 10.14694/EdBook_AM.2012.32.85. PMID: 24451714. Exclusion: 724451714
50 Bryan T, Snyder E, Estrada C, . Education in delivering patient-centered care: Provider comfort level in counseling women ages 40-49 regarding breast cancer. J. Investig. Med. 2013;61(2):524. Exclusion: 5
51 Burns RB, Schonberg MA, Tung NM, . Should we offer medication to reduce breast cancer risk Grand rounds discussion from beth Israel deaconess medical center. Ann. Intern. Med. 2016;165(3):194–204. doi: 10.7326/M16-0940. PMID: 27479221. Exclusion: 227479221
52 Burstein HJ. Aromatase inhibitor-associated arthralgia syndrome. Breast. 2007 Jun;16(3):223–34. doi: 10.1016/j.breast.2007.01.011. PMID: 17368903. Exclusion: 1017368903
53 Buzdar A, Jonat W, Howell A, . Anastrozole, a potent and selective aromatase inhibitor, versus megestrol acetate in postmenopausal women with advanced breast cancer: results of overview analysis of two phase III trials. Arimidex Study Group. J. Clin. Oncol. 1996 Jul;14(7):2000–11. doi: 10.1200/jco.1996.14.7.2000. PMID: 8683230. Exclusion: 48683230
54 Cameron DA. Breast cancer chemoprevention: little progress in practice? Lancet. 2014 Mar 22;383(9922):1018–20. doi: 10.1016/S0140-6736(13)62555-6. PMID: 24333008. Exclusion: 724333008
55 Castagnetta LA, Granata OM, Traina A, . Tissue content of hydroxyestrogens in relation to survival of breast cancer patients. Clin. Cancer Res. 2002 Oct;8(10):3146–55. PMID: 12374682. Exclusion: 412374682
56 Castillo-Fernandez O, Cabreja A, Arauz E, . Do patients and nurses outside clinical trial prefer subcutaneous trastuzumab over conventional intravenous infusion? Instituto Oncologico Nacional experience. Cancer Res. 2017;77(4)doi: 10.1158/1538-7445.SABCS16-P5-11-16. Exclusion: 6
57 Cauley JA. Bone loss associated with prevention of breast cancer. Lancet Oncol. 2012 Mar;13(3):221–2. doi: 10.1016/S1470-2045(12)70030-X. PMID: 22318094. Exclusion: 722318094
58 Cazzaniga M, Bonanni B. Breast cancer chemoprevention: old and new approaches. J. Biomed. Biotechnol. 2012;2012:985620. doi: 10.1155/2012/985620. PMID: 22851887. Exclusion: 1022851887
59 Centers for Disease Control and Prevention. What are the risk factors for breast cancer? Atlanta, GA: U.S Department of Health and Human Services 2016. http://www.cdc.gov/cancer/breast/basic_info/risk_factors.htm. Accessed March 27 2019. Exclusion: 2
60 Chen S, Masri S, Wang X, . What do we know about the mechanisms of aromatase inhibitor resistance? J. Steroid Biochem. Mol. Biol. 2006 Dec;102(1–5):232–40. doi: 10.1016/j.jsbmb.2006.09.012. PMID: 17055257. Exclusion: 717055257
61 Cheung AM, Tile L, Cardew S, . Bone density and structure in healthy postmenopausal women treated with exemestane for the primary prevention of breast cancer: a nested substudy of the MAP.3 randomised controlled trial. Lancet Oncol. 2012 Mar;13(3):275–84. doi: 10.1016/S1470-2045(11)70389-8. PMID: 22318095. Exclusion: 1122318095
62 Chlebowski RT. Changing paradigms for breast cancer chemoprevention? Cancer Res. 2011 Annual CTRC-AACR San Antonio Breast Cancer Symposium San Antonio, TX United States;71(24 SUPPL. 3):CONFERENCE START: 2011 Dec 6 CONFERENCE END: Dec 10. Exclusion: 7
63 Chlebowski RT. Current concepts in breast cancer chemoprevention. Pol. Arch. Med. Wewn. 2014;124(4):191–9. PMID: 24618912. Exclusion: 1024618912
64 Chlebowski RT. IBIS-I tamoxifen update: maturity brings questions. Lancet Oncol. 2015 Jan;16(1):7–9. doi: 10.1016/S1470-2045(14)71184-2. PMID: 25497695. Exclusion: 725497695
65 Chlebowski RT, Kim J, Haque R. Adherence to endocrine therapy in breast cancer adjuvant and prevention settings. Cancer Prev Res (Phila Pa). 2014 Apr;7(4):378–87. doi: 10.1158/1940-6207.CAPR-13-0389. PMID: 24441675. Exclusion: 424441675
66 Chlebowski RT, McTiernan A, Wactawski-Wende J, . Diabetes, metformin, and breast cancer in postmenopausal women. J. Clin. Oncol. 2012 Aug 10;30(23):2844–52. doi: 10.1200/jco.2011.39.7505. PMID: 22689798. Exclusion: 522689798
67 Cigler T, Richardson H, Yaffe MJ, . A randomized, placebo-controlled trial (NCIC CTG MAP.2) examining the effects of exemestane on mammographic breast density, bone density, markers of bone metabolism and serum lipid levels in postmenopausal women. Breast Cancer Res. Treat. 2011 Apr;126(2):453–61. doi: 10.1007/s10549-010-1322-0. PMID: 21221773. Exclusion: 621221773
68 Claus EB, Risch N, Thompson WD. The calculation of breast cancer risk for women with a first degree family history of ovarian cancer. Breast Cancer Res. Treat. 1993 Nov;28(2):115–20. PMID: 8173064. Exclusion: 68173064
69 Claus EB, Risch N, Thompson WD. Autosomal dominant inheritance of early-onset breast cancer. Implications for risk prediction. Cancer. 1994 Feb 01;73(3):643–51. PMID: 8299086. Exclusion: 68299086
70 Clauser P, Marino MA, Baltzer PAT, . Management of atypical lobular hyperplasia, atypical ductal hyperplasia, and lobular carcinoma in situ. Expert Rev. Anticancer Ther. 2016;16(3):335–46. doi: 10.1586/14737140.2016.1143362. PMID: 26780850. Exclusion: 426780850
71 Collins IM, Steel E, Mann GB, . Assessing and managing breast cancer risk: clinicians’ current practice and future needs. Breast. 2014 Oct;23(5):644–50. doi: 10.1016/j.breast.2014.06.014. PMID: 24998452. Exclusion: 624998452
72 Coombes RC, Kilburn LS, Snowdon CF, . Survival and safety of exemestane versus tamoxifen after 2-3 years’ tamoxifen treatment (Intergroup Exemestane Study): a randomised controlled trial. Lancet. 2007 Feb 17;369(9561):559–70. doi: 10.1016/s0140-6736(07)60200-1. PMID: 17307102. Exclusion: 417307102
73 Coopey S, Mazzola E, Cauley CE, . Breast cancer characteristics with and without chemoprevention in patients with atypical breast lesions. Ann. Surg. Oncol. 2014;21(1):S47. doi: 10.1245/s10434-013-3474-8. Exclusion: 7
74 Corbelli J, Borrero S, Bonnema R, . Use of the Gail model and breast cancer preventive therapy among three primary care specialties. J Womens Health (Larchmt). 2014 Sep;23(9):746–52. doi: 10.1089/jwh.2014.4742. PMID: 25115368. Exclusion: 325115368
75 Cossetti R, Gelmon KA. Exemestane for breast cancer risk reduction. Breast Cancer Management. 2015;4(3):159–64. doi: 10.2217/bmt.15.2. Exclusion: 11
76 Costa A. Breast cancer chemoprevention with retinoids and tamoxifen [abstract no: 985]. Eur. J. Cancer. 1995;31A(Suppl 5):S206. Exclusion: 7
77 Costa A, Sacchini V, Bonanni B, . Breast cancer chemoprevention with tamoxifen: The Italian trial. Breast Cancer Res. Treat. 1996;37(Suppl):99–9. Exclusion: 7
78 Costa A, Sacchini V, Luini A, . The Italian chemoprevantion study of breast cancer with tamoxifen. Breast Cancer Res. Treat. 1994;32(Suppl):68–8. Exclusion: 7
79 Costantino JP. Tamoxifen reduced the incidence of breast cancer in women at increased risk, but had more adverse events. Evidence-based Obstetrics and Gynecology. 2003;5(3):141–2. doi: 10.1016/S1361-259X(03)00101-6. Exclusion: 7
80 Craig Jordan V, McDaniel R, Agboke F, . The evolution of nonsteroidal antiestrogens to become selective estrogen receptor modulators. Steroids. 2014 Nov;90:3–12. doi: 10.1016/j.steroids.2014.06.009. PMID: 24949934. Exclusion: 1024949934
81 Crandall C. Raloxifene reduced vertebral fractures and breast cancer regardless of prior hormone therapy use in women. Evid. Based Med. 2005;10(3):84. doi: 10.1136/ebm.10.3.84. Exclusion: 7
82 Cummings SR, Ensrud K, Delmas PD, . Lasofoxifene in postmenopausal women with osteoporosis. N. Engl. J. Med. 2010 Feb 25;362(8):686–96. PMID: 20181970. Exclusion: 520181970
83 Cummings SR, McClung M, Reginster JY, . Arzoxifene for prevention of fractures and invasive breast cancer in postmenopausal women. J. Bone Miner. Res. 2011 Feb;26(2):397–404. doi: 10.1002/jbmr.191. PMID: 20658564. Exclusion: 520658564
84 Cummings SR, Tice JA, Bauer S, . Prevention of breast cancer in postmenopausal women: approaches to estimating and reducing risk. J. Natl. Cancer Inst. 2009 Mar 18;101(6):384–98. doi: 10.1093/jnci/djp018. PMID: 19276457. Exclusion: 1019276457
85 Cunnick GH, Mokbel K. Radiotherapy but not tamoxifen reduced the risk of invasive breast cancer after excision of ductal carcinoma in situ. Evidence-based Obstetrics and Gynecology. 2004;6(1):39–40. doi: 10.1016/j.ebobgyn.2003.12.003. Exclusion: 7
86 Curtis HJ, Walker AJ, Goldacre B. Impact of NICE guidance on tamoxifen prescribing in England 2011–2017: an interrupted time series analysis. Br. J. Cancer. 2018 May 01;118(9):1268–75. doi: 10.1038/s41416-018-0065-2. PMID: 29681615. Exclusion: 629681615
87 Cuzick, Edwards. Drop-outs in tamoxifen prevention trials. The Lancet. 1999(353):(9156):930. PMID: 10094016. Exclusion: 210094016
88 Cuzick J. A brief review of the current breast cancer prevention trials and proposals for future trials. Eur. J. Cancer. 2000 Jun;36(10):1298–302. PMID: 10882870. Exclusion: 1010882870
89 Cuzick J. A brief review of the International Breast Cancer Intervention Study (IBIS), the other current breast cancer prevention trials, and proposals for future trials. Ann. N. Y. Acad. Sci. 2001 Dec;949:123–33. PMID: 11795344. Exclusion: 1011795344
90 Cuzick J. Aromatase inhibitors for breast cancer prevention. J. Clin. Oncol. 2005 Mar 10;23(8):1636–43. doi: 10.1200/JCO.2005.11.027. PMID: 15755971. Exclusion: 1015755971
91 Cuzick J. IBIS II: a breast cancer prevention trial in postmenopausal women using the aromatase inhibitor anastrozole. Expert Rev. Anticancer Ther. 2008 Sep;8(9):1377–85. doi: 10.1586/14737140.8.9.1377. PMID: 18759690. Exclusion: 1018759690
92 Cuzick J. Selecting women for breast cancer chemoprevention and what agents should be used. Hered. Cancer Clin. Pract. 2012;10. Exclusion: 7
93 Cuzick J. Erratum: Anastrozole for prevention of breast cancer in high-risk postmenopausal women (IBIS-II): An international, double-blind, randomised placebo-controlled trial[Lancet 383 (2014);: 1041-48]. Lancet. 2014;383(9922):1040. Exclusion: 11
94 Cuzick J. Progress in breast cancer prevention. Eur. J. Cancer. 2014;50:S7. doi: 10.1016/S0959-8049(14)50026-3. Exclusion: 7
95 Cuzick J. Erratum: anastrozole for prevention of breast cancer in high-risk postmenopausal women (IBIS-II): an international, double-blind, randomised placebo-controlled trial. Lancet. 2014;383(9922):1040. Exclusion: 7
96 Cuzick J, Brentnall AR, Segal C, . Impact of a Panel of 88 Single Nucleotide Polymorphisms on the Risk of Breast Cancer in High-Risk Women: Results From Two Randomized Tamoxifen Prevention Trials. J. Clin. Oncol. 2017 Mar;35(7):743–50. doi: 10.1200/jco.2016.69.8944. PMID: 28029312. Exclusion: 528029312
97 Cuzick J, Chouinard E. Tamoxifen reduced breast cancer risk but increased risks of thromboembolic events and all cause mortality in women. Evid. Based Med. 2003;8(4):110. doi: 10.1136/ebm.8.4.110. Exclusion: 7
98 Cuzick J, DeCensi A, Arun B, . Preventive therapy for breast cancer: a consensus statement. Lancet Oncol. 2011 May;12(5):496–503. doi: 10.1016/S1470-2045(11)70030-4. PMID: 21441069. Exclusion: 221441069
99 Cuzick J, Powles T, Veronesi U, . Overview of the main outcomes in breast-cancer prevention trials. Lancet. 2003 Jan 25;361(9354):296–300. doi: 10.1016/s0140-6736(03)12342-2. PMID: 12559863. Exclusion: 1012559863
100 Cuzick J, Sestak I, Bonanni B, . Selective oestrogen receptor modulators in prevention of breast cancer: an updated meta-analysis of individual participant data. Lancet. 2013 May 25;381(9880):1827–34. doi: 10.1016/s0140-6736(13)60140-3. PMID: 23639488. Exclusion: 223639488
101 Cuzick J, Sestak I, Cawthorn S, . 16 year long-term follow-up of the IBIS-I breast cancer prevention trial. Cancer Res. 2014 Annual CTRC-AACR San Antonio Breast Cancer Symposium San Antonio, TX United States;75(9 SUPPL. 1):CONFERENCE START: 2014 Dec 9 CONFERENCE END: Dec 13. Exclusion: 7
102 Cuzick J, Sestak I, Forbes JF, . Breast cancer prevention using anastrozole in postmenopausal women at high risk. Cancer Res. 2013 Annual CTRC-AACR San Antonio Breast Cancer Symposium San Antonio, TX United States;73(24 SUPPL. 1):CONFERENCE START: 2013 Dec 10 CONFERENCE END: Dec 14. Exclusion: 7
103 Cuzick J, Sestak I, Thorat MA. Impact of preventive therapy on the risk of breast cancer among women with benign breast disease. Breast. 2015 Nov;24: Suppl 2:S51–5. doi: 10.1016/j.breast.2015.07.013. PMID: 26255741. Exclusion: 226255741
104 Cuzick J, Thorat M. Preventing invasive breast cancer in women at high risk based on benign/in situ pathology. Breast. 2015;24:S11. doi: 10.1016/S0960-9776(15)70024-X. Exclusion: 726249119
105 Cuzick J, Warwick J, Pinney E, . Tamoxifen and breast density in women at increased risk of breast cancer. J. Natl. Cancer Inst. 2004 Apr;96(8):621–8. PMID: 15100340. Exclusion: 615100340
106 Cuzick J, Zito R. Genotoxicity of tamoxifen [1]. J. Exp. Clin. Cancer Res. 1994;13(4):417–8. Exclusion: 7
107 Cykert S, Caine GJ, Blann AD, . Tamoxifen for breast-cancer prevention [3] (multiple letters). Lancet. 2003;361(9352):177–8. Exclusion: 7
108 Cyrus-David MS, Strom SS. Chemoprevention of breast cancer with selective estrogen receptor modulators: views from broadly diverse focus groups of women with elevated risk for breast cancer. Psychooncology. 2001 Nov–Dec;10(6):521–33. PMID: 11747064. Exclusion: 611747064
109 Dahhan T, Balkenende E, van Wely M, . Tamoxifen or letrozole versus standard methods for women with estrogen-receptor positive breast cancer undergoing oocyte or embryo cryopreservation in assisted reproduction. Cochrane Database of Systematic Reviews. 2014(1) PMID: 24213953. Exclusion: 424213953
110 Day S, Bevers TB. Cost-effectiveness of chemoprevention of breast cancer using tamoxifen in a postmenopausal US population: Noah-Vanhoucke J, Green LE, Dinh TA, et al. (Archimedes Inc, San Francisco, CA; et al.) Cancer 117:3322-3331, 2011. Breast Diseases. 2012;23(2):195–6. doi: 10.1016/j.breastdis.2012.03.009. Exclusion: 6
111 Day S, Bevers TB. Quality of life in MAP.3 (mammary prevention 3): A randomized, placebo-controlled trial evaluating exemestane for prevention of breast cancer. Breast Diseases. 2014;26(2):123–4. Exclusion: 7
112 Day S, Bevers TB. Guidelines challenge current practice and perceptions of breast cancer risk reduction therapy. Breast Diseases. 2014;25(3):203–5. doi: 10.1016/j.breastdis.2014.07.043. Exclusion: 7
113 Deal CL, Draper MW. Raloxifene: A selective estrogen-receptor modulator for postmenopausal osteoporosis - A clinical update on efficacy and safety. Womens Health. 2006;2(2):199–210. doi: 10.2217/17455057.2.2.199. Exclusion: 8
114 Decensi A, Dunn BK, Puntoni M, . Exemestane for breast cancer prevention: a critical shift? Cancer Discov. 2012 Jan;2(1):25–40. doi: 10.1158/2159-8290.CD-11-0248. PMID: 22585166. Exclusion: 1022585166
115 DeCensi A, Puntoni M, Branchi D, . Randomized, placebo-controlled, phase III trial of low-dose tamoxifen in women with intraepithelial neoplasia. Cancer Prev Res (Phila Pa). 2010;3(12)doi: 10.1158/1940-6207.PREV-10-A70. Exclusion: 4
116 DeCensi A, Thorat MA, Bonanni B, . Barriers to preventive therapy for breast and other major cancers and strategies to improve uptake. Ecancermedicalscience. 2015;9:595. doi: 10.3332/ecancer.2015.595. PMID: 26635899. Exclusion: 1026635899
117 den Hollander P, Savage MI, Brown PH. Targeted therapy for breast cancer prevention. Front. Oncol. 2013;3 SEP doi: 10.3389/fonc.2013.00250. PMID: 24069582. Exclusion: 224069582
118 Detre SI, Ashley S, Mohammed K, . Immunohistochemical phenotype of breast cancer during 25-year follow-up of the royal marsden tamoxifen prevention trial. Cancer Prev Res (Phila Pa). 2017;10(3):171–6. doi: 10.1158/1940-6207.CAPR-16-0247-T. PMID: 28100469. Exclusion: 628100469
119 Donnelly LS, Evans DG, Wiseman J, . Uptake of tamoxifen in consecutive premenopausal women under surveillance in a high-risk breast cancer clinic. Br. J. Cancer. 2014 Apr 02;110(7):1681–7. doi: 10.1038/bjc.2014.109. PMID: 24594998. Exclusion: 624594998
120 Doughty JC. When to start an aromatase inhibitor: now or later? J. Surg. Oncol. 2011 Jun 01;103(7):730–8. doi: 10.1002/jso.21801. PMID: 21360530. Exclusion: 1021360530
121 Dowsett M, Cuzick J, Ingle J, . Meta-analysis of breast cancer outcomes in adjuvant trials of aromatase inhibitors versus tamoxifen. J. Clin. Oncol. 2010 Jan 20;28(3):509–18. doi: 10.1200/jco.2009.23.1274. PMID: 19949017. Exclusion: 419949017
122 Dragnev K, You M, Wang Y, . Lung cancer chemoprevention: difficulties, promise and potential agents? Expert Opinion on Investigational Drugs. 2013 Jan;22(1):35–47. doi: 10.1517/13543784.2013.731392. PMID: 23167766. Exclusion: 623167766
123 Dubin-Rhodin A, Greenlee H, Terry MB, . Development of the Breast Cancer Family‐Based Intervention Trial (BFIT) Database. American Society of Preventive Oncology 36th Annual Meeting; 2012 Washington, DC. Exclusion: 7
124 Eastell R, Hannon R. Long-term effects of aromatase inhibitors on bone. J. Steroid Biochem. Mol. Biol. 2005 May;95(1–5):151–4. doi: 10.1016/j.jsbmb.2005.04.009. PMID: 15970439. Exclusion: 1015970439
125 Eli Lilly and Company. EVISTA (raloxifene) Medication Guide. Indianapolis, IN; 2007. https://www.fda.gov/downloads/Drugs/DrugSafety/ucm088593.pdf. Accessed March 27 2019. Exclusion: 2
126 Ellis AJ, Hendrick VM, Williams R, . Selective estrogen receptor modulators in clinical practice: a safety overview. Expert Opin. Drug Saf. 2015 Jun;14(6):921–34. doi: 10.1517/14740338.2015.1014799. PMID: 25936229. Exclusion: 1025936229
127 Errico A. Breast cancer: tamoxifen - offering a long-term prevention option. Nature Reviews Clinical Oncology. 2015 Feb;12(2):66. doi: 10.1038/nrclinonc.2014.236. PMID: 25583681. Exclusion: 725583681
128 Espina VA, Gallagher RI, Mariani BD, . DCIS neoadjuvant therapy: Targeting the autophagy pathway in malignant precursor cells. J. Clin. Oncol. 2010;28(15). Exclusion: 7
129 Euhus DM, Diaz J. Breast cancer prevention. Breast J. 2015 Jan–Feb;21(1):76–81. doi: 10.1111/tbj.12352. PMID: 25413630. Exclusion: 725413630
130 Evans DG, Astley S, Stavrinos P, . Improvement in risk prediction, early detection and prevention of breast cancer in the NHS Breast Screening Programme and family history clinics: a dual cohort study. Programme Grants for Applied Research. 2016;4(11)doi: 10.3310/pgfar04110. PMID: 27559559. Exclusion: 1027559559
131 Evans DG, Brentnall AR, Harvie M, . Breast cancer risk in young women in the national breast screening programme: implications for applying NICE guidelines for additional screening and chemoprevention. Cancer Prev Res (Phila Pa). 2014 Oct;7(10):993–1001. doi: 10.1158/1940-6207.CAPR-14-0037. PMID: 25047362. Exclusion: 525047362
132 Evans DG, Howell A. Can the breast screening appointment be used to provide risk assessment and prevention advice? Breast Cancer Res. 2015;17(1)doi: 10.1186/s13058-015-0595-y. PMID: 26155950. Exclusion: 1026155950
133 Fabian CJ, Kimler BF. Incorporating biomarkers in studies of chemoprevention. Adv. Exp. Med. Biol. 2016;882(pp 69–94) PMID: 26987531. Exclusion: 226987531
134 Fabian CJ, Kimler BF, Anderson J, . Breast cancer chemoprevention phase I evaluation of biomarker modulation by arzoxifene, a third generation selective estrogen receptor modulator. Clin. Cancer Res. 2004 Aug 15;10(16):5403–17. PMID: 15328178. Exclusion: 515328178
135 Fabian CJ, Kimler BF, Anderson JR, . Phase II breast cancer chemoprevention trial of the third generation selective estrogen receptor modulator arzoxifene. J. Clin. Oncol. 2006;24:(18 Suppl):49s. Exclusion: 7
136 Fabian CJ, Zalles C, Kamel S, . Breast cytology and biomarkers obtained by random fine needle aspiration: Use in risk assessment and early chemoprevention trials. J. Cell. Biochem. 1997;67(Suppl 28/29):101–10. PMID: 9589354. Exclusion: 69589354
137 Facina G, Nazario ACP, Kemp C, . Effects of different tamoxifen doses on Ki-67 labeling index in normal mammary epithelium from premenopausal women. Breast Cancer Res. Treat. 2004. Exclusion: 6
138 Fallowfield L, Fleissig A, Edwards R, . Tamoxifen for the prevention of breast cancer: psychosocial impact on women participating in two randomized controlled trials. J. Clin. Oncol. 2001 Apr 1;19(7):1885–92. doi: 10.1200/jco.2001.19.7.1885. PMID: 11283119. Exclusion: 1111283119
139 Fasching PA, Ekici AB, Adamietz BR, . Breast Cancer Risk - Genes, Environment and Clinics. Geburtshilfe Frauenheilkd. 2011 Dec;71(12):1056–66. doi: 10.1055/s-0031-1280437. PMID: 25253900. Exclusion: 1025253900
140 Felson DT, Cummings SR. Aromatase inhibitors and the syndrome of arthralgias with estrogen deprivation. Arthritis Rheum. 2005 Sep;52(9):2594–8. doi: 10.1002/art.21364. PMID: 16142740. Exclusion: 1016142740
141 Files JA, Stan DL, Allen SV, . Chemoprevention of breast cancer. Womens Health (Lond). 2012 Nov;8(6):635–46. doi: 10.2217/whe.12.56. PMID: 23181529. Exclusion: 723181529
142 Fisher B, Costantino JP, Redmond CK, . Endometrial cancer in tamoxifen-treated breast cancer patients: findings from the National Surgical Adjuvant Breast and Bowel Project (NSABP) B-14. J. Natl. Cancer Inst. 1994 Apr 06;86(7):527–37. PMID: 8133536. Exclusion: 48133536
143 Flanagan MR, Rendi MH, Gadi VK, . Adjuvant Endocrine Therapy in Patients with Ductal Carcinoma In Situ: A Population-Based Retrospective Analysis from 2005 to 2012 in the National Cancer Data Base. Ann. Surg. Oncol. 2015 Oct;22(10):3264–72. doi: 10.1245/s10434-015-4668-z. PMID: 26202556. Exclusion: 626202556
144 Foster SA, Shi N, Curkendall S, . Fractures in women treated with raloxifene or alendronate: a retrospective database analysis. BMC Womens Health. 2013 Mar 23;13:15. doi: 10.1186/1472-6874-13-15. PMID: 23521803. Exclusion: 423521803
145 Francis PA, Regan MM, Fleming GF, . Adjuvant ovarian suppression in premenopausal breast cancer. N. Engl. J. Med. 2015 Jan 29;372(5):436–46. doi: 10.1056/NEJMoa1412379. PMID: 25495490. Exclusion: 425495490
146 Frank DH, Kimler BF, Fabian CJ, . Digital image analysis of breast epithelial cells collected by random periareolar fine-needle aspirates (RPFNA) from women at high risk for breast cancer taking hormone replacement and the aromatase inhibitor, letrozole, for six months. Breast Cancer Res. Treat. 2009 Jun;115(3):661–8. doi: 10.1007/s10549-008-0274-0. PMID: 19125322. Exclusion: 619125322
147 Freedman AN, Graubard BI, McCaskill-Stevens W, . E2. Tamoxifen use for breast cancer chemoprevention among U.S. women. EJC Suppl. 2004;2(9 SPEC. ISS.):17–8. doi: 10.1016/j.ejcsup.2004.08.002. Exclusion: 7
148 Freedman AN, Graubard BI, Rao SR, . Estimates of the number of US women who could benefit from tamoxifen for breast cancer chemoprevention. J. Natl. Cancer Inst. 2003 Apr 02;95(7):526–32. PMID: 12671020. Exclusion: 712671020
149 Freedman AN, Rivera DR, Gail MH, . U.S. women who could benefit from tamoxifen or raloxifene for breast cancer chemoprevention in 2010. Pharmacoepidemiol. Drug Saf. 2015;24:466. doi: 10.1002/pds.3838. Exclusion: 7
150 Gabriel EM, Jatoi I. Breast cancer chemoprevention. Expert Rev. Anticancer Ther. 2012 Feb;12(2):223–8. doi: 10.1586/era.11.206. PMID: 22316370. Exclusion: 1022316370
151 Gail MH. The estimation and use of absolute risk for weighing the risks and benefits of selective estrogen receptor modulators for preventing breast cancer. Ann. N. Y. Acad. Sci. 2001 Dec;949:286–91. PMID: 11795364. Exclusion: 211795364
152 Gail MH. Twenty-five years of breast cancer risk models and their applications. J. Natl. Cancer Inst. 2015 May;107(5)doi: 10.1093/jnci/djv042. PMID: 25722355. Exclusion: 725722355
153 Ganz PA, Kwan L, Somerfield MR, . The role of prevention in oncology practice: results from a 2004 survey of American Society of Clinical Oncology members. J. Clin. Oncol. 2006 Jun 20;24(18):2948–57. doi: 10.1200/jco.2006.05.8321. PMID: 16702579. Exclusion: 416702579
154 Garber JE. Selecting candidates for chemoprevention & choosing among the options: Tamoxifen, raloxifene & aromatase inhibitors. Menopause. 2012;19(12):1366. doi: 10.1097/gme.0b013e3182739e2f. Exclusion: 7
155 Garber JE. Cancer risk-reducing measures for high risk women. Breast. 2012;21:S2. Exclusion: 7
156 Garcia AA. Chemoprevention for breast cancer: Beyond tamoxifen. Women’s Oncology Review. 2006;6(3–4):145–7. doi: 10.1080/14733400601043455. Exclusion: 7
157 Gasco M, Argusti A, Bonanni B, . SERMs in chemoprevention of breast cancer. Eur. J. Cancer. 2005 Sep;41(13):1980–9. doi: 10.1016/j.ejca.2005.04.017. PMID: 15964182. Exclusion: 1015964182
158 Gatti-Mays ME, Venzon D, Galbo CE, . Exemestane Use in Postmenopausal Women at High Risk for Invasive Breast Cancer: Evaluating Biomarkers of Efficacy and Safety. Cancer Prev. Res. (Phila.). 2016 Mar;9(3):225–33. doi: 10.1158/1940-6207.capr-15-0269. PMID: 26758879. Exclusion: 426758879
159 Geisler J, Lonning PE. Resistance to endocrine therapy of breast cancer: recent advances and tomorrow’s challenges. Clin. Breast Cancer. 2001 Jan;1(4):297–308; discussion 9. doi: 10.3816/CBC.2001.n.004. PMID: 11899352. Exclusion: 1011899352
160 Gierach G, Lacey JJ, Schatzkin A, . Nonsteroidal anti-inflammatory drugs and breast cancer risk in the National Institutes of Health-AARP Diet and Health Study. Breast Cancer Res. 2008;10(2)doi: 10.1186/bcr2089. PMID: 18447943. Exclusion: 218447943
161 Giles JT, Kennedy DT, Dunn EC, . Results of a community pharmacy-based breast cancer risk-assessment and education program. Pharmacotherapy. 2001 Feb;21(2):243–53. PMID: 11213861. Exclusion: 711213861
162 Gizzo S, Saccardi C, Patrelli TS, . Update on raloxifene: mechanism of action, clinical efficacy, adverse effects, and contraindications. Obstet. Gynecol. Surv. 2013 Jun;68(6):467–81. doi: 10.1097/OGX.0b013e31828baef9. PMID: 23942473. Exclusion: 1023942473
163 Gogas H, Markopoulos C, Blamey R. Should women be advised to take prophylactic endocrine treatment outside of a clinical trial setting? Ann. Oncol. 2005 Dec;16(12):1861–6. doi: 10.1093/annonc/mdi302. PMID: 15980159. Exclusion: 1015980159
164 Goldenberg VK, Seewaldt VL, Scott V, . Atypia in random periareolar fine-needle aspiration affects the decision of women at high risk to take tamoxifen for breast cancer chemoprevention. Cancer Epidemiol. Biomarkers Prev. 2007 May;16(5):1032–4. doi: 10.1158/1055-9965.epi-06-0910. PMID: 17507634. Exclusion: 617507634
165 Goodwin PJ, Stambolic V, Lemieux J, . Evaluation of metformin in early breast cancer: a modification of the traditional paradigm for clinical testing of anti-cancer agents. Breast Cancer Res. Treat. 2011 Feb;126(1):215–20. doi: 10.1007/s10549-010-1224-1. PMID: 20976543. Exclusion: 520976543
166 Gorin MB, Costantino JP, Kulacoglu DN, . Is tamoxifen a risk factor for retinal vaso-occlusive disease? Retina. 2005 Jun;25(4):523–6. PMID: 15933605. Exclusion: 1115933605
167 Goss PE. The promise of breast cancer prevention. Menopause (New York, N.Y.). 2012 START: 2012 Oct 3 CONFERENCE END: 2012 Oct 6, 23rd Annual Meeting of the North American Menopause Society, NAMS 2012 Orlando, FL United States;19(12):1366. Exclusion: 7
168 Goss PE, Ingle JN, Ales-Martinez J, . Exemestane for primary prevention of breast cancer in postmenopausal women: NCIC CTG MAP.3-A randomized, placebo-controlled clinical trial. J. Clin. Oncol. 2011 Jun 20;29(18_suppl):Lba504. PMID: 27937160. Exclusion: 11
169 Goss PE, Ingle JN, Martino S, . A randomized trial of letrozole in postmenopausal women after five years of tamoxifen therapy for early-stage breast cancer. N. Engl. J. Med. 2003 Nov 06;349(19):1793–802. doi: 10.1056/NEJMoa032312. PMID: 14551341. Exclusion: 414551341
170 Goss PE, Ingle JN, Pritchard KI, . Exemestane versus anastrozole in postmenopausal women with early breast cancer: NCIC CTG MA.27-a randomized controlled phase III trial. J. Clin. Oncol. 2013 Apr 10;31(11):1398–404. doi: 10.1200/jco.2012.44.7805. PMID: 23358971. Exclusion: 423358971
171 Goss PE, Richardson H, Chlebowski R, . National Cancer Institute of Canada Clinical Trials Group MAP.3 Trial: evaluation of exemestane to prevent breast cancer in postmenopausal women. Clin. Breast Cancer. 2007 Dec;7(11):895–900. doi: 10.3816/CBC.2007.n.057. PMID: 18269782. Exclusion: 1118269782
172 Goss PE, Strasser K. Aromatase inhibitors in the treatment and prevention of breast cancer. J. Clin. Oncol. 2001 Feb 01;19(3):881–94. doi: 10.1200/JCO.2001.19.3.881. PMID: 11157042. Exclusion: 1011157042
173 Goss PE, Willett LR. Exemestane prevented invasive breast cancer in postmenopausal women at moderately increased risk. Ann. Intern. Med. 2011;155(8):JC4–03. PMID: 22007062. Exclusion: 722007062
174 Gould K, Gates ML, Miaskowski C. Breast cancer prevention: a summary of the chemoprevention trial with tamoxifen. Oncol. Nurs. Forum. 1994 Jun;21(5):835–40. PMID: 7937245. Exclusion: 107937245
175 Gradishar, Ward. Reducing the risk of recurrence in premenopausal women with breast cancer. J. Natl. Compr. Canc. Netw. 2009;7(SPEC. ISS.):26–7. Exclusion: 4
176 Gradishar WJ. Raloxifene is as effective as tamoxifen in preventing primary invasive breast cancer: Comment. Oncology Report. 2006(FALL):19. Exclusion: 7
177 Gradishar WJ. Exemestane prevents 65% of invasive Ca post menopause: Commentary. Oncology Report. 2011(JULY–AUGUST):12. Exclusion: 7
178 Gradishar WJ, Anderson BO, Balassanian R, . Breast cancer version 2.2015: Clinical practice guidelines in oncology. J. Natl. Compr. Canc. Netw. 2015;13(4):448–75. Exclusion: 225870381
179 Graham L. ASCO updates guideline on the use of pharmacologic interventions to reduce breast cancer risk. Am. Fam. Physician. 2010;81(6):799. Exclusion: 7
180 Graham PH. Anastrozole for malignant and benign conditions: present applications and future therapeutic integrations. Expert Opin. Pharmacother. 2007 Oct;8(14):2347–57. doi: 10.1517/14656566.8.14.2347. PMID: 17927488. Exclusion: 1017927488
181 Grana G. Shifting paradigms in hormonal therapy for breast cancer. Cancer Biol. Ther. 2004 Sep;3(9):797–805. PMID: 15467423. Exclusion: 1015467423
182 Grann VR, Jacobson JS, Troxel AB, . Barriers to minority participation in breast carcinoma prevention trials. Cancer. 2005 Jul 15;104(2):374–9. doi: 10.1002/cncr.21164. PMID: 15937913. Exclusion: 615937913
183 Grann VR, Patel PR, Jacobson JS, . Comparative effectiveness of screening and prevention strategies among BRCA1/2-affected mutation carriers. Breast Cancer Res. Treat. 2011 Feb;125(3):837–47. doi: 10.1007/s10549-010-1043-4. PMID: 20644999. Exclusion: 620644999
184 Green LE, Dinh TA, Hinds DA, . Economic evaluation of using a genetic test to direct breast cancer chemoprevention in white women with a previous breast biopsy. Applied Health Economics & Health Policy. 2014 Apr;12(2):203–17. doi: 10.1007/s40258-014-0089-6. PMID: 24595521. Exclusion: 224595521
185 Gregor MCM, Lei X, Zhao H, . Use and adherence to breast cancer risk-reduction agents: A population-based study. J. Clin. Oncol. 2016;34. Exclusion: 7
186 Guerra CE, Sherman M, Armstrong K. Diffusion of breast cancer risk assessment in primary care. J. Am. Board Fam. Med. 2009 May–Jun;22(3):272–9. doi: 10.3122/jabfm.2009.03.080153. PMID: 19429733. Exclusion: 619429733
187 Guerrieri-Gonzaga A, Galli A, Rotmensz N, . The Italian breast cancer prevention trial with tamoxifen: findings and new perspectives. Ann. N. Y. Acad. Sci. 2001;949:113–22. PMID: 11795343. Exclusion: 1011795343
188 Guerrieri-Gonzaga A, Lazzeroni M, Botteri E, . Effect of low-dose tamoxifen after surgical excision of ductal intraepithelial neoplasia: results of a large retrospective monoinstitutional cohort study. Ann. Oncol. 2013 Jul;24(7):1859–66. doi: 10.1093/annonc/mdt113. PMID: 23532115. Exclusion: 423532115
189 Guidozzi F. Hormone therapy after prophylactic risk-reducing bilateral salpingo-oophorectomy in women who have BRCA gene mutation. Climacteric. 2016;19(5):419–22. doi: 10.1080/13697137.2016.1209396. Exclusion: 727426853
190 Hackett J, Thorneloe R, Side L, . Uptake of breast cancer preventive therapy in the UK: results from a multicentre prospective survey and qualitative interviews. Breast Cancer Res. Treat. 2018 Apr 24 doi: 10.1007/s10549-018-4775-1. PMID: 29687178. Exclusion: 329687178
191 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Stat. Med. 1996 Mar 30;15(6):619–29. doi: 10.1002/(sici)1097-0258(19960330)15:6<619::aid-sim188>3.0.co;2-a. PMID: 8731004. Exclusion: 28731004
192 Harper-Wynne C, Ross G, Sacks N, . Effects of the aromatase inhibitor letrozole on normal breast epithelial cell proliferation and metabolic indices in postmenopausal women: a pilot study for breast cancer prevention. Cancer Epidemiol. Biomarkers Prev. 2002 Jul;11(7):614–21. PMID: 12101108. Exclusion: 612101108
193 Hartmann LC, Lindor NM. The Role of Risk-Reducing Surgery in Hereditary Breast and Ovarian Cancer. N. Engl. J. Med. 2016 Feb 04;374(5):454–68. doi: 10.1056/NEJMra1503523. PMID: 26840135. Exclusion: 726840135
194 Hartmann LC, Radisky DC, Frost MH, . Understanding the premalignant potential of atypical hyperplasia through its natural history: a longitudinal cohort study. Cancer Prev. Res. (Phila.). 2014 Feb;7(2):211–7. doi: 10.1158/1940-6207.capr-13-0222. PMID: 24480577. Exclusion: 624480577
195 Harvey S, Francis J, Pillips K. Medical prevention of breast cancer in women at increased familial risk: let’s make it personal Asia Pac. J. Clin. Oncol. 2010;6(S3):e213. Exclusion: 7
196 Heisey R, Pimlott N, Clemons M, . Women’s views on chemoprevention of breast cancer: qualitative study. Can. Fam. Physician. 2006 May;52:624–5. PMID: 17327893. Exclusion: 617327893
197 Hendrix SL, Wassertheil-Smoller S, Johnson KC, . Effects of conjugated equine estrogen on stroke in the Women’s Health Initiative. Circulation. 2006 May 23;113(20):2425–34. doi: 10.1161/circulationaha.105.594077. PMID: 16702472. Exclusion: 516702472
198 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat. Med. 2002 Jun 15;21(11):1539–58. doi: 10.1002/sim.1186. PMID: 12111919. Exclusion: 212111919
199 Hoerger M, Scherer LD, Fagerlin A. Affective forecasting and medication decision making in breast-cancer prevention. Health Psychol. 2016 Jun;35(6):594–603. doi: 10.1037/hea0000324. PMID: 26867042. Exclusion: 626867042
200 Hoffman A, Pellenberg R, Drendall CI, . Comparison of Random Periareolar Fine Needle Aspirate versus Ductal Lavage for Risk Assessment and Prevention of Breast Cancer. Curr. Breast Cancer Rep. 2012;4(3):180–7. doi: 10.1007/s12609-012-0081-9. PMID: 22924092. Exclusion: 522924092
201 Holmberg C, Bandos H, Fagerlin A, . NRG oncology/national surgical adjuvant breast and bowel project decision-making project-1 results: Decision making in breast cancer risk reduction. Cancer Prev. Res. (Phila.). 2017 Nov;10(11):625–34. doi: 10.1158/1940-6207.capr-17-0076. PMID: 28978566. Exclusion: 328978566
202 Homer D, Lemeshow S. Applied logistic regression. 2nd ed. New York, NY: John Wiley & Sons Inc.; 2000. Exclusion: 2
203 Honig SF. Tamoxifen for the reduction in the incidence of breast cancer in women at high risk for breast cancer. Ann. N. Y. Acad. Sci. 2001 Dec;949:345–8. PMID: 11795374. Exclusion: 811795374
204 Howell A, Anderson AS, Clarke RB, . Risk determination and prevention of breast cancer. Breast Cancer Res. 2014 Sep 28;16(5):446. doi: 10.1186/s13058-014-0446-2. PMID: 25467785. Exclusion: 225467785
205 Huiart L, Bouhnik AD, Rey D, . Early discontinuation of tamoxifen intake in younger women with breast cancer: is it time to rethink the way it is prescribed? Eur. J. Cancer. 2012 Sep;48(13):1939–46. doi: 10.1016/j.ejca.2012.03.004. PMID: 22464016. Exclusion: 422464016
206 Ingle JN, Liu M, Wickerham DL, . Selective estrogen receptor modulators and pharmacogenomic variation in ZNF423 regulation of BRCA1 expression: individualized breast cancer prevention. Cancer Discov. 2013 Jul;3(7):812–25. doi: 10.1158/2159-8290.CD-13-0038. PMID: 23764426. Exclusion: 623764426
207 Jadav S, Sansgiry SS. Economic evaluation of breast cancer prevention agents: Comparing tamoxifen, raloxifene and exemestane. Value Health. 2013;16(3):A140–A1. doi: 10.1016/j.jval.2013.03.688. Exclusion: 7
208 Jatoi I, Benson JR. Management of women with a hereditary predisposition for breast cancer. Future Oncology. 2016;12(19):2277–88. doi: 10.2217/fon-2016-0186. PMID: 27384952. Exclusion: 1027384952
209 Johansson H, Bonanni B, Gandini S, . Circulating hormones and breast cancer risk in premenopausal women: a randomized trial of low-dose tamoxifen and fenretinide. Breast Cancer Res. Treat. 2013 Dec;142(3):569–78. doi: 10.1007/s10549-013-2768-7. PMID: 24241787. Exclusion: 624241787
210 Johansson H, DeCensi A, Gandini S, . Effects of cytochrome P450 2D6 polymorphisms on tamoxifen metabolism in a pooled analysis of breast cancer prevention trials designed to define the minimal active dose of the drug. Cancer Res. 2011;71(8)doi: 10.1158/1538-7445.AM2011-3675. Exclusion: 6
211 Johansson H, Gandini S, Serrano D, . A pooled analysis of CYP2D6 genotype in breast cancer prevention trials of low-dose tamoxifen. Breast Cancer Res. Treat. 2016;159(1):97–108. PMID: 27484880. Exclusion: 627484880
212 Jones A. Feasibility of tamoxifen in chemoprevention of breast cancer (meeting abstract). Br. J. Cancer. 1990;62:(Suppl 12):3. Exclusion: 7
213 Jones A, Powles TJ, Ashley S, . Feasibility of Tamoxifen in chemoprevention of breast cancer. Br. J. Cancer. 1990;62:(Suppl 12):3. Exclusion: 7
214 Jones AL. Chemoprevention of breast cancer (The British tamoxifen trials). Journal canadien des maladies infectieuses [Can J Infect Dis Med Microbiol]. 1995;6(Suppl C):193C. Exclusion: 7
215 Jones S, Vogel C, Arkhipov A, . Multicenter, phase II trial of exemestane as third-line hormonal therapy of postmenopausal women with metastatic breast cancer. Aromasin Study Group. J. Clin. Oncol. 1999 Nov;17(11):3418–25. doi: 10.1200/jco.1999.17.11.3418. PMID: 10550136. Exclusion: 410550136
216 Jordan VC. Differing Perspectives on Breast Cancer Chemoprevention. JAMA oncology. 2016 Feb;2(2):276. doi: 10.1001/jamaoncol.2015.3906. PMID: 26868999. Exclusion: 726868999
217 Jubelirer SJ. Quality-of-life considerations in selecting raloxifene or tamoxifen. Community Oncol. 2006;3(11):700+3. Exclusion: 7
218 Juraskova I, Bonner C. Decision aids for breast cancer chemoprevention. Breast Cancer Res. 2013;15(5):106. doi: 10.1186/bcr3479. PMID: 24050596. Exclusion: 724050596
219 Kaplan CP, Haas JS, Perez-Stable EJ, . Factors affecting breast cancer risk reduction practices among California physicians. Prev. Med. 2005 Jul;41(1):7–15. doi: 10.1016/j.ypmed.2004.09.041. PMID: 15916987. Exclusion: 315916987
220 Keogh LA, Hopper JL, Rosenthal D, . Australian clinicians and chemoprevention for women at high familial risk for breast cancer. Hered. Cancer Clin. Pract. 2009;7(1)doi: 10.1186/1897-4287-7-9. PMID: 19409108. Exclusion: 519409108
221 King MC, Wieand S, Hale K, . Tamoxifen and breast cancer incidence among women with inherited mutations in BRCA1 and BRCA2: National Surgical Adjuvant Breast and Bowel Project (NSABP-P1) Breast Cancer Prevention Trial. JAMA. 2001 Nov 14;286(18):2251–6. PMID: 11710890. Exclusion: 611710890
222 Kinney AY, Richards C, Vernon SW, . The effect of physician recommendation on enrollment in the Breast Cancer Chemoprevention Trial. Prev. Med. 1998 Sep-Oct;27(5 Pt 1):713–9. doi: 10.1006/pmed.1998.0349. PMID: 9808803. Exclusion: 69808803
223 Koslow S, Park A, Muhsen S, . Lobular carcinoma in situ (LCIS): What happens after chemoprevention (CP)? Ann. Surg. Oncol. 2014;21(1):S55. doi: 10.1245/s10434-013-3474-8. Exclusion: 7
224 Kote-Jarai Z, Powles TJ, Mitchell G, . BRCA1/BRCA2 mutation status and analysis of cancer family history in participants of the Royal Marsden Hospital tamoxifen chemoprevention trial. Cancer Lett. 2007 Mar 18;247(2):259–65. doi: 10.1016/j.canlet.2006.05.003. PMID: 16777318. Exclusion: 216777318
225 Kukafka R, Yi H, Xiao T, . Why Breast Cancer Risk by the Numbers Is Not Enough: Evaluation of a Decision Aid in Multi-Ethnic, Low-Numerate Women. J. Med. Internet Res. 2015 Jul 14;17(7):e165. doi: 10.2196/jmir.4028. PMID: 26175193. Exclusion: 526175193
226 Kulacoglu DN, Costantino J, Demirci FY, . Tamoxifen and Retinal Vaso-Occlusive Disease. Iovs. 2004;45. Exclusion: 7
227 Kurian AW, Munoz DF, Rust P, . Online tool to guide decisions for BRCA1/2 mutation carriers. J. Clin. Oncol. 2012 Feb 10;30(5):497–506. doi: 10.1200/jco.2011.38.6060. PMID: 22231042. Exclusion: 522231042
228 Kurz-Milcke E, Gigerenzer G, Martignon L. Transparency in risk communication: graphical and analog tools. Ann. N. Y. Acad. Sci. 2008;18(28)doi: 10.1196/annals.1399.004. PMID: 8469211 Exclusion: 28469211
229 LaCroix A, Powles T, Osborne C. Breast cancer incidence in the randomized PEARL trial of lasofoxifene in postmenopausal osteoporotic women. Breast Diseases. 2011;22(2):178–80. doi: 10.1016/j.breastdis.2011.03.052. Exclusion: 5
230 LaCroix AZ, Powles T, Osborne CK, . Breast cancer incidence in the randomized PEARL trial of lasofoxifene in postmenopausal osteoporotic women. J. Natl. Cancer Inst. 2010 Nov 17;102(22):1706–15. PMID: 21051656. Exclusion: 521051656
231 Laroche M, Borg S, Lassoued S, . Joint pain with aromatase inhibitors: abnormal frequency of Sjogren’s syndrome. J. Rheumatol. 2007 Nov;34(11):2259–63. PMID: 17937464. Exclusion: 417937464
232 Layeequr Rahman R, Crawford S. Chemoprevention Indication Score: a user-friendly tool for prevention of breast cancer - pilot analysis. Breast. 2009 Oct;18(5):289–93. doi: 10.1016/j.breast.2009.08.001. PMID: 19716702. Exclusion: 619716702
233 Lazarus P, Sun D. Potential role of UGT pharmacogenetics in cancer treatment and prevention: focus on tamoxifen and aromatase inhibitors. Drug Metab. Rev. 2010 Feb;42(1):182–94. doi: 10.3109/03602530903208652. PMID: 19821643. Exclusion: 1019821643
234 Lazzeroni M, DeCensi A. Breast cancer prevention by antihormones and other drugs: where do we stand? Hematology - Oncology Clinics of North America. 2013 Aug;27(4):657–72, vii. doi: 10.1016/j.hoc.2013.05.009. PMID: 23915737. Exclusion: 1023915737
235 Leader JB, Bengier A, Darer J, . Identifying women at increased risk for breast cancer using the electronic health record in an integrated health system. Cancer Res. 2012;72(24)doi: 10.1158/0008-5472.SABCS12-P4-13-12. Exclusion: 6
236 Lee AJ, Cunningham AP, Kuchenbaecker KB, . BOADICEA breast cancer risk prediction model: updates to cancer incidences, tumour pathology and web interface. Br. J. Cancer. 2014 Jan 21;110(2):535–45. doi: 10.1038/bjc.2013.730. PMID: 24346285. Exclusion: 524346285
237 Li F, Dou J, Wei L, . The selective estrogen receptor modulators in breast cancer prevention. Cancer Chemother. Pharmacol. 2016 05;77(5):895–903. doi: 10.1007/s00280-016-2959-0. PMID: 26787504. Exclusion: 1026787504
238 Li Y, Brasky TM, Nie J, . Use of nonsteroidal anti-inflammatory drugs and survival following breast cancer diagnosis. Cancer Epidemiol. Biomarkers Prev. 2012 Jan;21(1):239–42. doi: 10.1158/1055-9965.epi-11-1012. PMID: 22068285. Exclusion: 422068285
239 Liede A, Mansfield CA, Metcalfe KA, . Preferences for breast cancer risk reduction among BRCA1/BRCA2 mutation carriers: a discrete-choice experiment. Breast Cancer Res. Treat. 2017 Sep;165(2):433–44. doi: 10.1007/s10549-017-4332-3. PMID: 28624978. Exclusion: 328624978
240 Litton JK, Arun BK, Brown PH, . Aromatase inhibitors and breast cancer prevention. Expert Opin. Pharmacother. 2012 Feb;13(3):325–31. doi: 10.1517/14656566.2012.651459. PMID: 22242911. Exclusion: 722242911
241 Litzenburger BC, Brown PH. Anastrozole for prevention of breast cancer in high-risk postmenopausal women (IBIS-II): An international, double-blind, randomised placebo-controlled trial. Breast Diseases. 2014;25(3):214–6. Exclusion: 7
242 Litzenburger BC, Brown PH. Advances in preventive therapy for estrogen-receptor-negative breast cancer. Curr. Breast Cancer Rep. 2014;6(2):96–109. doi: 10.1007/s12609-014-0144-1. PMID: 24829621. Exclusion: 1024829621
243 Loehberg CR, Jud SM, Haeberle L, . Breast cancer risk assessment in a mammography screening program and participation in the IBIS-II chemoprevention trial. Breast Cancer Res. Treat. 2010 May;121(1):101–10. doi: 10.1007/s10549-010-0845-8. PMID: 20306293. Exclusion: 620306293
244 Lopez AM, Pruthi S, Boughey JC, . Double-Blind, Randomized Trial of Alternative Letrozole Dosing Regimens in Postmenopausal Women with Increased Breast Cancer Risk. Cancer Prev. Res. (Phila.). 2016 Feb;9(2):142–8. doi: 10.1158/1940-6207.capr-15-0322. PMID: 26667449. Exclusion: 626667449
245 Mahoney MC, Bevers T, Linos E, . Opportunities and strategies for breast cancer prevention through risk reduction. CA Cancer J. Clin. 2008 Nov–Dec;58(6):347–71. doi: 10.3322/ca.2008.0016. PMID: 18981297. Exclusion: 1018981297
246 Mallick S, Benson R, Julka PK. Breast cancer prevention with anti-estrogens: review of the current evidence and future directions. Breast cancer (Tokyo, Japan). 2016;23(2):170–7. PMID: 26439380. Exclusion: 1026439380
247 Mann GJ, Thorne H, Balleine RL, . Analysis of cancer risk and BRCA1 and BRCA2 mutation prevalence in the kConFab familial breast cancer resource. Breast Cancer Res. 2006;8(1):R12. doi: 10.1186/bcr1377. PMID: 16507150. Exclusion: 816507150
248 Mannucci PM, Bettega D, Chantarangkul V, . Effect of tamoxifen on measurements of hemostasis in healthy women. Arch. Intern. Med. 1996 Sep 9;156(16):1806–10. PMID: 8790074. Exclusion: 68790074
249 Marsden J, Jacobs C. Breast cancer chemoprevention: A challenge for doctors and patients. Prescriber. 2013;24(21):7–8. doi: 10.1002/psb.1125. Exclusion: 10
250 Martinez KA, Fagerlin A, Witteman HO, . What matters to women when making decisions about breast cancer chemoprevention? Patient. 2016 Apr;9(2):149–59. doi: 10.1007/s40271-015-0134-z. PMID: 26115846. Exclusion: 326115846
251 Maunsell E, Richardson H, Ingle JN, . Menopause-specific and health-related qualities of life among post-menopausal women taking exemestane for prevention of breast cancer: Results from the NCIC CTG MAP.3 placebo-controlled randomized controlled trial. Cancer Res. 2011 Annual CTRC-AACR San Antonio Breast Cancer Symposium San Antonio, TX United States;71(24 SUPPL. 3):CONFERENCE START: 2011 Dec 6 CONFERENCE END: Dec 10. Exclusion: 7
252 Maurice A, Howell A, Evans DG, . Predicting compliance in a breast cancer prevention trial. Breast J. 2006 Sep–Oct;12(5):446–50. PMID: 16958964. Exclusion: 216958964
253 McCaskill-Stevens W, Wilson JW, Cook ED, . National Surgical Adjuvant Breast and Bowel Project Study of Tamoxifen and Raloxifene trial: advancing the science of recruitment and breast cancer risk assessment in minority communities. Clinical Trials. 2013 Apr;10(2):280–91. doi: 10.1177/1740774512470315. PMID: 23335675. Exclusion: 623335675
254 McCormack VA, dos Santos Silva I. Breast density and parenchymal patterns as markers of breast cancer risk: a meta-analysis. Cancer Epidemiol. Biomarkers Prev. 2006 Jun;15(6):1159–69. doi: 10.1158/1055-9965.epi-06-0034. PMID: 16775176. Exclusion: 516775176
255 McTiernan, Wang, Sorensen. No effect of aspirin on mammographic density in a randomized controlled clinical trial. Cancer Epidemiol. Biomarkers Prev. 2009;18(5):1524–30. PMID: 19423529. Exclusion: 219423529
256 Meiser B, Butow P, Price M, . Attitudes to prophylactic surgery and chemoprevention in Australian women at increased risk for breast cancer. J Womens Health (Larchmt). 2003 Oct;12(8):769–78. doi: 10.1089/154099903322447738. PMID: 14588127. Exclusion: 614588127
257 Meiser B, Wong WKT, Peate M, . Motivators and barriers of tamoxifen use as risk-reducing medication amongst women at increased breast cancer risk: a systematic literature review. Hered. Cancer Clin. Pract. 2017;15:14. doi: 10.1186/s13053-017-0075-8. PMID: 28943990. Exclusion: 328943990
258 Metcalfe KA, Dennis CL, Poll A, . Effect of decision aid for breast cancer prevention on decisional conflict in women with a BRCA1 or BRCA2 mutation: A multisite, randomized, controlled trial. Genet. Med. 2017;19(3):330–6. doi: 10.1038/gim.2016.108. PMID: 27584910. Exclusion: 627584910
259 Metcalfe KA, Foulkes WD, Kim-Sing C, . Family history as a predictor of uptake of cancer preventive procedures by women with a BRCA1 or BRCA2 mutation. Clin. Genet. 2008 May;73(5):474–9. doi: 10.1111/j.1399-0004.2008.00988.x. PMID: 18341607. Exclusion: 618341607
260 Metcalfe KA, Poll A, O’Connor A, . Development and testing of a decision aid for breast cancer prevention for women with a BRCA1 or BRCA2 mutation. Clin. Genet. 2007 Sep;72(3):208–17. doi: 10.1111/j.1399-0004.2007.00859.x. PMID: 17718858. Exclusion: 517718858
261 Metcalfe KA, Snyder C, Seidel J, . The use of preventive measures among healthy women who carry a BRCA1 or BRCA2 mutation. Fam. Cancer. 2005;4(2):97–103. doi: 10.1007/s10689-005-4215-3. PMID: 15951959. Exclusion: 315951959
262 Micallef S, Micallef D, Schembri-Wismayer P, . Chemoprevention of breast cancer among women at elevated risk as defined by Gail Score. Minerva Ginecol. 2015 Aug;67(4):335–52. PMID: 25668503. Exclusion: 1025668503
263 Miller WR, Dixon JM. Local endocrine effects of aromatase inhibitors within the breast. J. Steroid Biochem. Mol. Biol. 2001 Dec;79(1–5):93–102. PMID: 11850212. Exclusion: 411850212
264 Millstine D, David P, Pruthi S. Tools of the trade: individualized breast cancer risk assessment. J. Womens Health. 2014 May;23(5):434–6. doi: 10.1089/jwh.2014.4761. PMID: 24707809. Exclusion: 724707809
265 Mocellin S, Pilati P, Briarava M, . Breast Cancer Chemoprevention: A Network Meta-Analysis of Randomized Controlled Trials. J. Natl. Cancer Inst. 2016 Feb;108(2)doi: 10.1093/jnci/djv318. PMID: 26582062. Exclusion: 826582062
266 Mokbel K. Risk-reducing strategies for breast cancer-a review of recent literature. Int. J. Fertil. Womens Med. 2003 Nov–Dec;48(6):274–7. PMID: 15646397. Exclusion: 1015646397
267 Monnier A. FACE: The barefaced facts of AI potency. 2010. p. 267–76. Exclusion: 4
268 Moon KT. Effectiveness of medications to prevent primary breast cancer. Am. Fam. Physician. 2010;81(9):1149–50. Exclusion: 7
269 Mouridsen H. Aromatase inhibitors in the early adjuvant setting - the latest evidence. EJC Suppl. 2006;4(9):3–9. doi: 10.1016/j.ejcsup.2006.06.001. Exclusion: 10
270 Moy B, Richardson H, Johnston D. NCIC CTG MAP.3: enrollment and study drug adherence of ethnic minority women in a breast cancer prevention trial. Breast Cancer Res. Treat. 2007;106(1):S141–S2. Exclusion: 7
271 Moyer. Using medications to decrease the risk for breast cancer in women: recommendations from the U.S. Preventive Services Task Force. Ann. Intern. Med. 2013 Nov 19;159(10):I–28. doi: 10.7326/0003-4819-159-10-201311190-00717. PMID: 24400336. Exclusion: 724400336
272 Moyer VA. Medications to decrease the risk for breast cancer in women: recommendations from the U.S. Preventive Services Task Force recommendation statement. Ann. Intern. Med. 2013 Nov 19;159(10):698–708. doi: 10.7326/0003-4819-159-10-201311190-00717. PMID: 24061412. Exclusion: 224061412
273 Moyer VA. Risk assessment, genetic counseling, and genetic testing for BRCA-related cancer in women: U.S. Preventive Services Task Force recommendation statement. Ann. Intern. Med. 2014 Feb 18;160(4):271–81. doi: 10.7326/m13-2747. PMID: 24366376. Exclusion: 224366376
274 Moyer VA, Force USPST. Medications to decrease the risk for breast cancer in women: recommendations from the U.S. Preventive Services Task Force recommendation statement.[Summary for patients in Ann Intern Med. 2013 Nov 19;159(10):I-28; PMID: 24400336]. Ann. Intern. Med. 2013 Nov 19;159(10):698–708. doi: 10.7326/0003-4819-159-10-201311190-00717. PMID: 24061412. Exclusion: 724061412
275 Muhammad A, Ibrahim MA, Erukainure OL, . Metabolism and toxicological implications of commonly used chemopreventive drugs against breast cancer/carcinogenesis. Curr. Drug Metab. 2016;17(10):930–6. PMID: 27848887. Exclusion: 427848887
276 Nabholtz JM. Role of anastrozole across the breast cancer continuum: from advanced to early disease and prevention. Oncology. 2006;70(1):1–12. doi: 10.1159/000091180. PMID: 16439860. Exclusion: 1016439860
277 Namburi S, Coe AM, Thomas P, . Effect of chemoprevention uptake on mammographic density over time in women at high risk for breast cancer. Cancer Res. 2016;76(4)doi: 10.1158/1538-7445.SABCS15-P6-10-09. Exclusion: 8
278 Namer M. Breast cancer prevention. Medecine Nucleaire. 2010;34(1):3–13. doi: 10.1016/j.mednuc.2009.11.005. Exclusion: 9
279 Narod SA. Tamoxifen Chemoprevention-End of the Road? JAMA oncology. 2015 Nov;1(8):1033–4. doi: 10.1001/jamaoncol.2015.2247. PMID: 26247918. Exclusion: 226247918
280 Narod SA. Breast cancer prevention in the era of precision medicine. J. Natl. Cancer Inst. 2015 May;107(5)doi: 10.1093/jnci/djv078. PMID: 25855708. Exclusion: 725855708
281 National Cancer Institute. Breast cancer risk assessment tool. National Institutes of Health 2011. https://www.cancer.gov/bcrisktool/. Accessed March 27 2019. Exclusion: 2
282 National Cancer Institute. NCI dictionary of cancer terms: breast cancer. National Institute of Health; 2016. https://www.cancer.gov/publications/dictionaries/cancer-terms?cdrid=444971. Accessed March 27 2019. Exclusion: 2
283 National Cancer Institute. NCI dictionary of cancer terms: lobular carcinoma. National Institute of Health; 2016. https://www.cancer.gov/publications/dictionaries/cancer-terms?search=lobular%20carcinoma. Accessed March 27 2019. Exclusion: 2
284 National Cancer Institute. Cancer stat facts: female breast cancer. National Institute of Health; 2016. https://seer.cancer.gov/statfacts/html/breast.html. Accessed March 27 2019. Exclusion: 2
285 National Cancer Institute. Cancer Stat Facts: Female Breast Cancer. National Institute of Health; 2018. https://seer.cancer.gov/statfacts/html/breast.html. Accessed March 27 2019. Exclusion: 2
286 National Comprehensive Cancer Network. Breast Cancer Risk Reduction. 2016. Exclusion: 2
287 Nattinger AB, Mitchell JL. Breast cancer screening and prevention. Ann. Intern. Med. 2016;164(11):ITC81–ITC94. doi: 10.7326/AITC201606070. Exclusion: 727270661
288 Nazarali SA, Narod SA. Tamoxifen for women at high risk of breast cancer. Breast Cancer (London). 2014;6:29–36. doi: 10.2147/BCTT.S43763. PMID: 24648767. Exclusion: 224648767
289 Neibergs H. Molecular genetics and cancer: The role of BRCA1 and BRCA2. Women’s Oncology Review. 2002;2(1):19–29. Exclusion: 10
290 Nelson HD, Fu R, Griffin JC, . Systematic review: comparative effectiveness of medications to reduce risk for primary breast cancer. Ann. Intern. Med. 2009 Nov 17;151(10):703–15, w-226–35. doi: 10.7326/0003-4819-151-10-200911170-00147. PMID: 19920271. Exclusion: 219920271
291 Nelson HD, Fu R, McDonagh M, . Medication use for the risk reduction of primary breast cancer in women: a systematic review for the U.S. Preventive Services Task Force [in press]. Rockville, MD: Agency for Healthcare Research and Quality; 2019. Exclusion: 2
292 Nelson HD, Smith ME, Griffin JC, . Use of medications to reduce risk for primary breast cancer: a systematic review for the U.S. Preventive Services Task Force. Ann. Intern. Med. 2013 Apr 16;158(8):604–14. doi: 10.7326/0003-4819-158-8-201304160-00005. PMID: 23588749. Exclusion: 223588749
293 Nelson HD, Zakher B, Cantor A, . Risk factors for breast cancer for women aged 40 to 49 years: a systematic review and meta-analysis. Ann. Intern. Med. 2012 May 01;156(9):635–48. doi: 10.7326/0003-4819-156-9-201205010-00006. PMID: 22547473. Exclusion: 222547473
294 Nelson NJ. Breast cancer prevention in high-risk women: searching for new options. J. Natl. Cancer Inst. 2011 May 04;103(9):710–1. doi: 10.1093/jnci/djr159. PMID: 21515834. Exclusion: 721515834
295 Nichols HB, DeRoo LA, Sandler DP. Characteristics associated with tamoxifen use for chemoprevention after age 50: Results from the sister study. Am. J. Epidemiol. 2012;175:S45. doi: 10.1093/aje/kws258. Exclusion: 7
296 Nichols HB, DeRoo LA, Scharf DR, . Risk-benefit profiles of women using tamoxifen for chemoprevention. J. Natl. Cancer Inst. 2015 Jan;107(1):354. doi: 10.1093/jnci/dju354. PMID: 25475563. Exclusion: 625475563
297 Nimmons S, Bambhroliya A, Teresa B, . The evaluation of breast cancer chemoprevention uptake in a high-risk cohort. Cancer Prev Res (Phila Pa). 2013;6(11). Exclusion: 7
298 Niravath P, Rimawi MF, Osborne CK. Aromatase inhibitor adverse effects: are we sweeping them under the rug? J. Clin. Oncol. 2014 Nov 20;32(33):3779. doi: 10.1200/JCO.2014.56.9640. PMID: 25154832. Exclusion: 725154832
299 Nyante SJ, Sherman ME, Pfeiffer RM, . Patterns of longitudinal change in mammographic density among tamoxifen users. Cancer Prev Res (Phila Pa). 2013;6(11). Exclusion: 7
300 Obiorah I, Jordan VC. Progress in endocrine approaches to the treatment and prevention of breast cancer. Maturitas. 2011 Dec;70(4):315–21. doi: 10.1016/j.maturitas.2011.09.006. PMID: 21982237. Exclusion: 1021982237
301 Olin JL, St Pierre M. Aromatase inhibitors in breast cancer prevention. Ann. Pharmacother. 2014 Dec;48(12):1605–10. doi: 10.1177/1060028014548416. PMID: 25159003. Exclusion: 1025159003
302 Oliveira VM, Aldrighi JM, Rinaldi JF. [Current status of breast cancer chemoprevention]. Rev. Assoc. Med. Bras. 2006 Nov–Dec;52(6):453–9. PMID: 17242785. Exclusion: 917242785
303 Oppong BA, King TA. Recommendations for women with lobular carcinoma in situ (LCIS). Oncology (Williston Park). 2011 Oct;25(11):1051–6, 8. PMID: 22106556. Exclusion: 1022106556
304 O’Regan RM. Chemoprevention of breast cancer. Lancet. 2006 Apr 29;367(9520):1382–3. doi: 10.1016/S0140-6736(06)68594-2. PMID: 16650636. Exclusion: 716650636
305 Owens WL, Gallagher TJ, Kincheloe MJ, . Implementation in a large health system of a program to identify women at high risk for breast cancer. J. Oncol. Pract. 2011;7(2):85–8. doi: 10.1200/JOP.2010.000107. PMID: 21731514. Exclusion: 621731514
306 Ozanne EM, Annis C, Adduci K, . Pilot trial of a computerized decision aid for breast cancer prevention. Breast J. 2007 Mar–Apr;13(2):147–54. doi: 10.1111/j.1524-4741.2007.00395.x. PMID: 17319855. Exclusion: 517319855
307 Ozanne EM, Howe R, Omer Z, . Development of a personalized decision aid for breast cancer risk reduction and management. BMC Med. Inform. Decis. Mak. 2014 Jan 14;14:4. doi: 10.1186/1472-6947-14-4. PMID: 24422989. Exclusion: 524422989
308 Ozanne EM, Klemp JR, Esserman LJ. Breast cancer risk assessment and prevention: a framework for shared decision-making consultations. Breast J. 2006 Mar-Apr;12(2):103–13. doi: 10.1111/j.1075-122X.2006.00217.x. PMID: 16509834. Exclusion: 616509834
309 Padamsee TJ, Wills CE, Yee LD, . Decision making for breast cancer prevention among women at elevated risk. Breast Cancer Res. 2017;19(1)doi: 10.1186/s13058-017-0826-5. PMID: 28340626. Exclusion: 1028340626
310 Palomares MR, Banzet M, Lu K, . Breast cancer risk reduction among patients with DCIS. J. Clin. Oncol. 2012;30(15). Exclusion: 7
311 Paluch-Shimon S, Cardoso F, Sessa C, . Prevention and screening in BRCA mutation carriers and other breast/ovarian hereditary cancer syndromes: ESMO clinical practice guidelines for cancer prevention and screening. Ann. Oncol. 2016;27:v103–v10. doi: 10.1093/annonc/mdw327. PMID: 27664246. Exclusion: 227664246
312 Palva T, Ranta H, Koivisto AM, . A double-blind placebo-controlled study to evaluate endometrial safety and gynaecological symptoms in women treated for up to 5 years with tamoxifen or placebo - a substudy for IBIS I Breast Cancer Prevention Trial. Eur. J. Cancer. 2013 Jan;49(1):45–51. doi: 10.1016/j.ejca.2012.06.015. PMID: 22832202. Exclusion: 1122832202
313 Pankratz VS, Hartmann LC, Degnim AC, . Assessment of the accuracy of the Gail model in women with atypical hyperplasia. J. Clin. Oncol. 2008 Nov 20;26(33):5374–9. doi: 10.1200/jco.2007.14.8833. PMID: 18854574. Exclusion: 818854574
314 Park HL, Tran SM, Lee J, . A pilot study comparing breast cancer risk scores using models with and without breast density among women of different race/ethnicities undergoing breast screening in the University of California, Irvine Athena Breast Health Network cohort. Cancer Res. 2014;74(19)doi: 10.1158/1538-7445.AM2014-3243. Exclusion: 7
315 Parmigiani G, Berry D, Aguilar O. Determining carrier probabilities for breast cancer-susceptibility genes BRCA1 and BRCA2. Am. J. Hum. Genet. 1998 Jan;62(1):145–58. PMID: 9443863. Exclusion: 69443863
316 Parsons H, Stearns V. ACP Journal Club. Tamoxifen for 5 years reduced 16-year risk for breast cancer in women at increased risk. Ann. Intern. Med. 2015 May 19;162(10):JC11. doi: 10.7326/ACPJC-2015-162-10-011. PMID: 25984872. Exclusion: 725984872
317 Patel RR, Sharma CG, Jordan VC. Optimizing the antihormonal treatment and prevention of breast cancer. Breast Cancer. 2007;14(2):113–22. PMID: 17485895. Exclusion: 1017485895
318 Paterniti DA, Melnikow J, Nuovo J, . “I’m going to die of something anyway”: women’s perceptions of tamoxifen for breast cancer risk reduction. Ethn. Dis. 2005 Summer;15(3):365–72. PMID: 16108294. Exclusion: 316108294
319 Peck S, O’Shaughnessy JA, Mariani S. Advances in the use of aromatase inhibitors: Updates from San Antonio and St. Gallen. Clin. Breast Cancer. 2005;6(1):23–6. Exclusion: 10
320 Pepe S, Pensabene M, Condello C. Modifiers of risk in BRCA1/2 mutation carriers. Current Women’s Health Reviews. 2012;8(1):23–9. doi: 10.2174/157340412799079246. Exclusion: 2
321 Perez EA, Weilbaecher K. Aromatase inhibitors and bone loss. Oncology (Williston Park). 2006 Aug;20(9):1029–39; discussion 39-40, 42, 48. PMID: 16986348. Exclusion: 1016986348
322 Phillips KA, Lindeman GJ. Breast cancer prevention for BRCA1 and BRCA2 mutation carriers: is there a role for tamoxifen? Future Oncology. 2014 Mar;10(4):499–502. doi: 10.2217/fon.13.278. PMID: 24754577. Exclusion: 724754577
323 Pinsky P, Miller E, Heckman-Stoddard B, . Use of raloxifene and tamoxifen by breast cancer risk level in a Medicare-eligible cohort. Am. J. Obstet. Gynecol. 2018 doi: 10.1016/j.ajog.2018.03.031. PMID: 29630889. Exclusion: 229630889
324 Ponzone R, Mininanni P, Cassina E, . Aromatase inhibitors for breast cancer: different structures, same effects? Endocr. Relat. Cancer. 2008 Mar;15(1):27–36. doi: 10.1677/ERC-07-0249. PMID: 18310273. Exclusion: 518310273
325 Powles T. Tamoxifen and bone: Data from breast cancer prevention studies. Obstet. Gynecol. Surv. 1998;53(10 SUPPL.):S45–S6. PMID: 9672274. Exclusion: 79672274
326 Powles TJ. Chemoprevention of breast cancer - a randomised trial. Ann-Oncol. 1992;3:(Suppl 1):60. Exclusion: 7
327 Powles TJ. Chemoprevention of breast cancer with tamoxifen [abstract no: 984]. Eur. J. Cancer. 1995;31A(Suppl 5):S206. Exclusion: 7
328 Powles TJ. Chemoprevention of breast cancer using tamoxifen. Endocrine related cancer. 1997;4:255–60. Exclusion: 10
329 Powles TJ. Ii.1 Tamoxifen’s oestrogen-like effects in a breast cancer chemoprevention trial. Eur. J. Cancer. 1998;34:(Suppl 4):S17–S8. Exclusion: 7
330 Powles TJ. Use of tamoxifen for chemoprevention of breast cancer. Ann-Oncol. 1998;9:(Suppl 2):1. Exclusion: 7
331 Powles TJ. Prevetion of breast cancer using selective oestrogen receptor modulators (SERMs). Breast Cancer Res. 2006;8(5)doi: 10.1186/bcr1601. PMID: 17049068. Exclusion: 717049068
332 Powles TJ. Selective oestrogen receptor modulators (SERMs) for prevention of breast cancer. Natl. Med. J. India. 2013 Jul–Aug;26(4):194–6. PMID: 24758440. Exclusion: 1024758440
333 Powles TJ, Bourne T, Athanasiou S, . The effects of norethisterone on endometrial abnormalities identified by transvaginal ultrasound screening of healthy post-menopausal women on tamoxifen or placebo. Br. J. Cancer. 1998;78(2):272–5. PMID: 9683306. Exclusion: 59683306
334 Powles TJ, Diem SJ, Fabian CJ, . Breast cancer incidence in postmenopausal women with osteoporosis or low bone mass using arzoxifene. Breast Cancer Res. Treat. 2012 Jul;134(1):299–306. doi: 10.1007/s10549-012-2041-5. PMID: 22484799. Exclusion: 422484799
335 Powles TJ, Eeles R, Salmon A, . Update of the Royal Marsden Hospital tamoxifen breast cancer chemoprevention trial. Proceedings of American Society of Clinical Oncology. 2003;22(94). Exclusion: 7
336 Powles TJ, Hardy JR, Ashley SE, . Chemoprevention of breast cancer. Breast Cancer Res. Treat. 1989 Oct;14(1):23–31. Exclusion: 82690969
337 Powles TJ, Hardy JR, Ashley SE, . A pilot trial to evaluate the acute toxicity and feasibility of tamoxifen for prevention of breast cancer. Br. J. Cancer. 1989 Jul;60(1):126–31. PMID: 2679843. Exclusion: 112679843
338 Powles TJ, Hickish T, Kanis JA, . Effect of tamoxifen on bone mineral density measured by dual-energy x-ray absorptiometry in healthy premenopausal and postmenopausal women. J. Clin. Oncol. 1996;14(1):78–84. PMID: 8558225. Exclusion: 68558225
339 Powles TJ, Jones AL, Ashley SE, . The Royal Marsden Hospital pilot tamoxifen chemoprevention trial. Breast Cancer Res. Treat. 1994;31(1):73–82. PMID: 7981459. Exclusion: 117981459
340 Powles TJ, McKinna A, Davey J. Chemoprevention of breast cancer. J. Endocrinol. 1993;137(Suppl):S32. Exclusion: 6
341 Powles TJ, Tillyer CR, Jones AL, . Prevention of breast cancer with tamoxifen-an update on the Royal Marsden Hospital pilot programme. Eur. J. Cancer. 1990;26(6):680–4. PMID: 2144154. Exclusion: 112144154
342 Prasad V, Diener-West M. Primary chemoprevention of breast cancer: Are the adverse effects too burdensome? CMAJ. 2015 Jun 16;187(9):E276–8. doi: 10.1503/cmaj.141627. PMID: 25802306. Exclusion: 725802306
343 Prichard RS, Hill AD, Dijkstra B, . The prevention of breast cancer. Br. J. Surg. 2003 Jul;90(7):772–83. doi: 10.1002/bjs.4218. PMID: 12854100. Exclusion: 1012854100
344 Printz C. Developments in precision medicine: Studies highlight new applications for cancer chemoprevention, treatment. Cancer. 2016 Mar 01;122(5):661–2. doi: 10.1002/cncr.29909. PMID: 26901830. Exclusion: 726901830
345 Pritchard KI, Goss PE, Shepherd L. The extended adjuvant NCIC CTG MA.17 trials: initial and rerandomization studies. Breast. 2006 Feb;15: Suppl 1:S14–20. doi: 10.1016/j.breast.2006.01.002. PMID: 16500236. Exclusion: 416500236
346 Provinciali N, Suen C, Dunn BK, . Raloxifene hydrochloride for breast cancer risk reduction in postmenopausal women. Expert Rev. Clin. Pharmacol. 2016;9(10):1263–72. doi: 10.1080/17512433.2016.1231575. PMID: 27583816. Exclusion: 1027583816
347 Pruthi S, Heisey R, Bevers T. Personalized assessment and management of women at risk for breast cancer in North America. Womens Health. 2015 Mar;11(2):213–23; quiz 23-4. doi: 10.2217/whe.14.79. PMID: 25776295. Exclusion: 225776295
348 Pruthi S, Heisey RE, Bevers TB. Chemoprevention for Breast Cancer. Ann. Surg. Oncol. 2015;22(10):3230–5. doi: 10.1245/s10434-015-4715-9. PMID: 26202562. Exclusion: 226202562
349 Pujol P, Lasset C, Berthet P, . Uptake of a randomized breast cancer prevention trial comparing letrozole to placebo in BRCA1/2 mutations carriers: the LIBER trial. Fam. Cancer. 2012 Mar;11(1):77–84. doi: 10.1007/s10689-011-9484-4. PMID: 22076253. Exclusion: 222076253
350 Pujol P, Mijonnet S, Dugast C, . Abstract P1-07-02: Acceptability of Breast Cancer Medical Prevention by Letrozole in Post-Menopausal Women with a BRCA1/2 Mutation in the LIBER Trial. 2010. Exclusion: 7
351 Puntoni M, Decensi A. The rationale and potential of cancer chemoprevention with special emphasis on breast cancer. Eur. J. Cancer. 2009 Sep;45: Suppl 1:346–54. doi: 10.1016/S0959-8049(09)70049-8. PMID: 19775631. Exclusion: 719775631
352 Rahman RL, Pruthi S. Chemoprevention of breast cancer: The Paradox of evidence versus advocacy inaction. Cancers (Basel). 2012;4(4):1146–60. doi: 10.3390/cancers4041146. PMID: 24213502. Exclusion: 724213502
353 Ralph AF, Ager B, Bell ML, . Women’s preferences for selective estrogen reuptake modulators: an investigation using protection motivation theory. Patient Educ. Couns. 2014 Jul;96(1):106–12. doi: 10.1016/j.pec.2014.04.011. PMID: 24856850. Exclusion: 624856850
354 Rastogi P, Vogel VG. Update on breast cancer prevention. Oncology (Williston Park). 2003 Jun;17(6):799–805; discussion 8-10, 13. PMID: 12846124. Exclusion: 1012846124
355 Ravdin PM. The lack, need, and opportunities for decision-making and informational tools to educate primary-care physicians and women about breast cancer chemoprevention. Cancer Prev. Res. (Phila.). 2010 Jun;3(6):686–8. doi: 10.1158/1940-6207.capr-10-0100. PMID: 20522798. Exclusion: 620522798
356 Razzaboni E, Toss A, Cortesi L, . Acceptability and adherence in a chemoprevention trial among women at increased risk for breast cancer attending the Modena Familial Breast and Ovarian Cancer Center (Italy). Breast J. 2013 Jan–Feb;19(1):10–21. PMID: 23252601. Exclusion: 623252601
357 Refinetti AP, Chun J, Schnabel F, . Chemoprevention in patients with newly diagnosed breast cancers. Cancer Res. 2012;72(24)doi: 10.1158/0008-5472.SABCS12-P1-09-03. Exclusion: 7
358 Reimers L, Crew KD. Tamoxifen versus raloxifene versus exemestane for chemoprevention. Curr. Breast Cancer Rep. 2012;4(3):207–15. doi: 10.1007/s12609-012-0082-8. PMID: 23956815. Exclusion: 1023956815
359 Reimers LL, Campbell J, Hershman D, . Uptake of selective estrogen receptor modulators and other breast cancer prevention strategies among high-risk women seen in a breast center. Cancer Res. 2011;71(24)doi: 10.1158/0008-5472.SABCS11-P4-11-06. Exclusion: 7
360 Reimers LL, Sivasubramanian PS, Hershman D, . Breast cancer chemoprevention among high-risk women and those with ductal carcinoma in situ. Breast J. 2015 Jul-Aug;21(4):377–86. doi: 10.1111/tbj.12418. PMID: 25879521. Exclusion: 325879521
361 Reis SE, Costantino JP, Wickerham DL, . Cardiovascular effects of tamoxifen in women with and without heart disease: breast cancer prevention trial. National Surgical Adjuvant Breast and Bowel Project Breast Cancer Prevention Trial Investigators. J. Natl. Cancer Inst. 2001 Jan 3;93(1):16–21. PMID: 11136837. Exclusion: 1111136837
362 Rice LW. Hormone prevention strategies for breast, endometrial and ovarian cancers. Gynecol. Oncol. 2010 Aug 01;118(2):202–7. doi: 10.1016/j.ygyno.2010.03.014. PMID: 20471672. Exclusion: 1020471672
363 Richardson H, Johnston D, Pater J, . The National Cancer Institute of Canada Clinical Trials Group MAP.3 trial: an international breast cancer prevention trial. Curr. Oncol. 2007 Jun;14(3):89–96. PMID: 17593981. Exclusion: 217593981
364 Roesch EE, Wei L, Ramaswamy B. Higher tamoxifen use as chemoprophylaxis in patients with ductal carcinoma in situ (DCIS) in the last decade. J. Clin. Oncol. 2012;30(27). Exclusion: 7
365 Roetzheim RG, Lee JH, Fulp W, . Acceptance and adherence to chemoprevention among women at increased risk of breast cancer. Breast. 2015 Feb;24(1):51–6. doi: 10.1016/j.breast.2014.11.006. PMID: 25491191. Exclusion: 325491191
366 Rondanina G, Puntoni M, Guerrieri-Gonzaga A, . Worry and risk perception of breast cancer in a prevention trial of low dose tamoxifen in midlife postmenopausal hormone users. Breast. 2017 Aug;34:108–14. doi: 10.1016/j.breast.2017.05.008. PMID: 28570956. Exclusion: 628570956
367 Rondanina G, Puntoni M, Severi G, . Psychological and clinical factors implicated in decision making about a trial of low-dose tamoxifen in hormone replacement therapy users. J. Clin. Oncol. 2008 Mar 20;26(9):1537–43. doi: 10.1200/jco.2007.13.6739. PMID: 18349406. Exclusion: 418349406
368 Ropka ME, Keim J, Philbrick JT. Patient decisions about breast cancer chemoprevention: a systematic review and meta-analysis. J. Clin. Oncol. 2010 Jun 20;28(18):3090–5. doi: 10.1200/jco.2009.27.8077. PMID: 20458026. Exclusion: 320458026
369 Roses RE, Kuerer HM. Ductal carcinoma in situ: Clinical trials update and resolving controversies. Curr. Cancer Ther. Rev. 2012;8(3):182–8. doi: 10.2174/157339412802653173. Exclusion: 10
370 Ross PJ, Powles TJ. Results and implications of the Royal Marsden and other tamoxifen chemoprevention trials. Clin. Breast Cancer. 2001;2(1):33–6. PMID: 11899380. Exclusion: 1011899380
371 RXList.com. Top 200 drugs by prescriptions. 2010. https://www.rxlist.com/script/main/art.asp?articlekey=166587. Accessed March 27 2019. Exclusion: 2
372 Sabatino SA, McCarthy EP, Phillips RS, . Breast cancer risk assessment and management in primary care: provider attitudes, practices, and barriers. Cancer Detect. Prev. 2007;31(5):375–83. doi: 10.1016/j.cdp.2007.08.003. PMID: 18037249. Exclusion: 618037249
373 Sacchini V, Costa A, Bonanni B, . Chemoprevention of breast cancer: update of the Italian trial in hysterectomised women. Eur. J. Cancer. 1996(32):S23. Exclusion: 78958039
374 Saha D, Paul S, Emran TB, . Role of chemoprevention in cancers. Pharmacologyonline. 2012;2:29–35. Exclusion: 10
375 Salant T, Ganschow PS, Olopade OI, . “Why take it if you don’t have anything?” breast cancer risk perceptions and prevention choices at a public hospital. J. Gen. Intern. Med. 2006 Jul;21(7):779–85. doi: 10.1111/j.1525-1497.2006.00461.x. PMID: 16808782. Exclusion: 616808782
376 Schaefer KM, Ladd E, Gergits MA, . Backing and forthing: the process of decision making by women considering participation in a breast cancer prevention trial. Oncol. Nurs. Forum. 2001 May;28(4):703–9. PMID: 11383184. Exclusion: 611383184
377 Schnabel FR, Pivo S, Chun J, . Breast cancer profile among patients with a history of chemoprevention. Int. J. Breast Cancer. 2016;2016 doi: 10.1155/2016/9216375. PMID: 28078143. Exclusion: 428078143
378 Schwartz MD, Valdimarsdottir HB, DeMarco TA, . Randomized trial of a decision aid for BRCA1/BRCA2 mutation carriers: impact on measures of decision making and satisfaction. Health Psychol. 2009 Jan;28(1):11–9. doi: 10.1037/a0013147. PMID: 19210013. Exclusion: 619210013
379 Sestak I. Preventative therapies for healthy women at high risk of breast cancer. Cancer Manag. Res. 2014;6:423–30. doi: 10.2147/CMAR.S55219. PMID: 25378950. Exclusion: 225378950
380 Sestak I, Cuzick J. Update on breast cancer risk prediction and prevention. Curr. Opin. Obstet. Gynecol. 2015 Feb;27(1):92–7. doi: 10.1097/GCO.0000000000000153. PMID: 25517358. Exclusion: 225517358
381 Sestak I, Smith SG, Howell A, . Early participant-reported symptoms as predictors of adherence to anastrozole in the International Breast Cancer Intervention Studies II. Ann. Oncol. 2018;29(2):504–9. PMID: 29126161. Exclusion: 629126161
382 Sexton S. Medications for risk reduction of primary breast cancer in women: Recommendation statement. Am. Fam. Physician. 2014;90(9):652A–D. Exclusion: 10
383 Shen Y, Costantino JP, Qin J. Tamoxifen chemoprevention treatment and time to first diagnosis of estrogen receptor-negative breast cancer. J. Natl. Cancer Inst. 2008;100(20):1448–53. PMID: 18840821. Exclusion: 618840821
384 Shepherd JH, Chan F. III.8 Tamoxifen and endometrial cancer: How should we screen? Eur. J. Cancer. 1998;34(SUPPL. 4):S39. Exclusion: 7
385 Simmons S. Pharmaceutical reduction of breast cancer risk. Nurse Pract. 2010 Sep;35(9):10–1. doi: 10.1097/01.NPR.0000387149.45852.70. PMID: 20720461. Exclusion: 1020720461
386 Singh S, Cuzick J, Mesher D, . Effect of baseline serum vitamin D levels on aromatase inhibitors induced musculoskeletal symptoms: results from the IBIS-II, chemoprevention study using anastrozole. Breast Cancer Res. Treat. 2012 Apr;132(2):625–9. doi: 10.1007/s10549-011-1911-6. PMID: 22198469. Exclusion: 422198469
387 Sismondi P, D’Alonzo M, Pecchio S, . Chemoprevention or mastectomy for women at high risk of developing breast cancer. Maturitas. 2015 Nov;82(3):271–3. doi: 10.1016/j.maturitas.2015.07.002. PMID: 26276104. Exclusion: 1026276104
388 Sivasubramanian PS, Crew KD. Biomarker endpoints for early-phase cancer-prevention studies. Curr. Breast Cancer Rep. 2013;5(3):194–201. doi: 10.1007/s12609-013-0116-x. Exclusion: 7
389 Skandarajah AR, Thomas S, Shackleton K, . Patient and medical barriers preclude uptake of tamoxifen preventative therapy in women with a strong family history. Breast. 2017 Apr;32:93–7. doi: 10.1016/j.breast.2017.01.002. PMID: 28107734. Exclusion: 328107734
390 Smith J, Dilawari A, Ursin G, . A pilot study of letrozole for one year in women at enhanced risk of developing breast cancer: effects on mammographic density. Anticancer Res. 2012 Apr;32(4):1327–31. PMID: 22493366. Exclusion: 422493366
391 Smith SG, Sestak I, Forster A, . Factors affecting uptake and adherence to breast cancer chemoprevention: A systematic review and meta-analysis. Cancer Res. 2016;76(4)doi: 10.1158/1538-7445.SABCS15-PD1-08. PMID: 26646754. Exclusion: 326646754
392 Smith SG, Sestak I, Howell A, . Participant-Reported Symptoms and Their Effect on Long-Term Adherence in the International Breast Cancer Intervention Study I (IBIS I). J. Clin. Oncol. 2017 Aug 10;35(23):2666–73. doi: 10.1200/jco.2016.71.7439. PMID: 28661758. Exclusion: 628661758
393 Sopik V, Narod S. Overdiagnosis in breast cancer chemoprevention trials. Current Oncology. 2015;22(1):e6–e10. doi: 10.3747/co.22.219. PMID: 25684995. Exclusion: 1025684995
394 Sorkin M, Lapolt D, Pusztai L, . Clinical experience with exemestane in postmenopausal women at increased risk of breast cancer. J. Clin. Oncol. 2013;31(15). Exclusion: 7
395 Stacey D, Legare F, Lewis K, . Decision aids for people facing health treatment or screening decisions. Cochrane Database of Systematic Reviews. 2017(4) PMID: 28402085. Exclusion: 528402085
396 Stacey D, O’Connor AM, DeGrasse C, . Development and evaluation of a breast cancer prevention decision aid for higher-risk women. Health Expect. 2003 Mar;6(1):3–18. PMID: 12603624. Exclusion: 612603624
397 Stakelum A, Evoy D, Rothwell J, . Comparison of family history risk stratification models in irish women at increased personal risk of breast cancer. Ir. J. Med. Sci. 2018;187:S147. doi: 10.1007/s11845-018-1861-7. Exclusion: 7
398 Staley H, McCallum I, Bruce J. Postoperative Tamoxifen for ductal carcinoma in situ: Cochrane systematic review and meta-analysis. Breast. 2014 Oct;23(5):546–51. doi: 10.1016/j.breast.2014.06.015. PMID: 25023044. Exclusion: 425023044
399 Stearns V. Raloxifene and tamoxifen had simialr efficacy for preventing invasive breast cancer in women at increased risk. Evid. Based Med. 2006;11(6):177. doi: 10.1136/ebm.11.6.177. PMID: 17213171. Exclusion: 717213171
400 Stubert J, Dieterich M, Gerber B. Medical prevention of breast cancer. Breast Care. 2014;9(6):391–6. doi: 10.1159/000369573. PMID: 25759621. Exclusion: 225759621
401 Tchou J, Hou N, Rademaker A, . Acceptance of tamoxifen chemoprevention by physicians and women at risk. Cancer. 2004 May 1;100(9):1800–6. doi: 10.1002/cncr.20205. PMID: 15112259. Exclusion: 615112259
402 Thacker HL. Raloxifene produced both harms and benefits in postmenopausal women, with no reduction in cardiovascular disease risk. Evid. Based Med. 2006;11(6):178. doi: 10.1136/ebm.11.6.178. PMID: 17213172. Exclusion: 717213172
403 The Lancet. NCI and the STELLAR trial. Lancet. 2007 Jun 30;369(9580):2134. doi: 10.1016/s0140-6736(07)60987-8. PMID: 17604779. Exclusion: 717604779
404 Tice JA, Cummings SR, Ziv E, . Mammographic breast density and the Gail model for breast cancer risk prediction in a screening population. Breast Cancer Res. Treat. 2005 Nov;94(2):115–22. doi: 10.1007/s10549-005-5152-4. PMID: 16261410. Exclusion: 1116261410
405 Tile L, Tomlinson G, Gakhal N, . Skeletal health in healthy postmenopausal women treated with exemestane for the primary prevention of breast cancer: 3-year data from the nested bone strength substudy of the MAP.3 trial (MAP3BSS). J. Bone Miner. Res. 2015;30(Supplement 1). Exclusion: 6
406 Tiller K, Meiser B, Gaff C, . A randomized controlled trial of a decision aid for women at increased risk of ovarian cancer. Med. Decis. Making. 2006 Jul-Aug;26(4):360–72. doi: 10.1177/0272989x06290486. PMID: 16855125. Exclusion: 516855125
407 Toriola AT, Colditz GA. Trends in breast cancer incidence and mortality in the United States: implications for prevention. Breast Cancer Res. Treat. 2013 Apr;138(3):665–73. doi: 10.1007/s10549-013-2500-7. PMID: 23546552. Exclusion: 623546552
408 Toss A, Sebastiani F, Razzaboni E, . Chemoprevention strategies for high risk women. Current Women’s Health Reviews. 2012;8(1):86–93. doi: 10.2174/157340412799079174. Exclusion: 10
409 Trafalis DTP, Athanassiou AE. A guideline for the management of women at substantially increased risk of breast cancer development. J. BUON. 2005;10(4):443–58. PMID: 17357201. Exclusion: 717357201
410 Tran G, Helm M, Litton J. Current Approach to Breast Cancer Risk Reduction for Women with Hereditary Predispositions to Breast Cancer. Curr. Breast Cancer Rep. 2016;8(3):165–74. doi: 10.1007/s12609-016-0220-9. Exclusion: 10
411 Treadwell JR, Singh S, Talati R, . A framework for best evidence approaches can improve the transparency of systematic reviews. J. Clin. Epidemiol. 2012 Nov;65(11):1159–62. doi: 10.1016/j.jclinepi.2012.06.001. PMID: 23017634. Exclusion: 223017634
412 Trikalinos TA, Wieland LS, Adam GP, . Decision Aids for Cancer Screening and Treatment. AHRQ Comparative Effectiveness Reviews Rockville (MD): Agency for Healthcare Research and Quality (US); 2014. Exclusion: 5
413 Turner B, Williams S, Taichman D, . Breast cancer screening and prevention. Ann. Intern. Med. 2010;152(7):ITC4-1–ITC4-16. Exclusion: 10
414 U.S. Department of Health and Human Services. NOLVADEX (TAMOXIFEN CITRATE). Silver Spring, MD: U.S. Food and Drug Administration; 2017. http://www.accessdata.fda.gov/scripts/cder/daf/index.cfm?event=overview.process&ApplNo=017970. Accessed March 27 2019. Exclusion: 2
415 U.S. Food & Drug Administration. Drugs@FDA: FDA Approved Drug Products. Silver Spring, MD: U.S. Department of Health and Human Services; 2018. https://www.accessdata.fda.gov/scripts/cder/daf/. Accessed March 27 2019. Exclusion: 2
416 U.S. Preventive Services Task Force. Screening for skin cancer: U.S. Preventive Services Task Force recommendation statement. Ann. Intern. Med. 2009;150(3):188–93. PMID: 19189908. Exclusion: 219189908
417 U.S. Preventive Services Task Force. Final Update Summary: Breast Cancer: Medications for Risk Reduction. 2013. https://www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryFinal/breast-cancer-medications-for-risk-reduction. Exclusion: 2
418 U.S. Preventive Services Task Force. Final Recommendation Statement: Breast Cancer: Screening.; 2016. https://www.uspreventiveservicestaskforce.org/Page/Document/RecommendationStatementFinal/breast-cancer-screening1. Exclusion: 2
419 U.S. Preventive Services Task Force. Methods and processes. 2018. https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes. Accessed March 27 2019. Exclusion: 2
420 Vachon CM, Schaid DJ, Ingle JN, . The contribution of common genetic variation to breast cancer risk among women receiving tamoxifen or raloxifene within the National Surgical Adjuvant Breast and Bowel Project (NSABP) P-1 and P-2 trials. Cancer Res. 2015;75(9)doi: 10.1158/1538-7445.SABCS14-P6-10-03. Exclusion: 6
421 Vachon CM, Schaid DJ, Ingle JN, . A polygenic risk score for breast cancer in women receiving tamoxifen or raloxifene on NSABP P-1 and P-2. Breast Cancer Res. Treat. 2015 Jan;149(2):517–23. doi: 10.1007/s10549-014-3175-4. PMID: 25575444. Exclusion: 625575444
422 van de Velde CJ, Rea D, Seynaeve C, . Adjuvant tamoxifen and exemestane in early breast cancer (TEAM): a randomised phase 3 trial. Lancet. 2011 Jan 22;377(9762):321–31. doi: 10.1016/S0140-6736(10)62312-4. PMID: 21247627. Exclusion: 221247627
423 van Roosmalen MS, Stalmeier PF, Verhoef LC, . Randomized trial of a shared decision-making intervention consisting of trade-offs and individualized treatment information for BRCA1/2 mutation carriers. J. Clin. Oncol. 2004 Aug 15;22(16):3293–301. doi: 10.1200/jco.2004.05.066. PMID: 15310772. Exclusion: 515310772
424 van Veen EM, Brentnall AR, Byers H, . Use of Single-Nucleotide Polymorphisms and Mammographic Density Plus Classic Risk Factors for Breast Cancer Risk Prediction. JAMA oncology. 2018 Apr 1;4(4):476–82. doi: 10.1001/jamaoncol.2017.4881. PMID: 29346471. Exclusion: 529346471
425 Veronesi U, Costa A. Prevention of breast cancer with tamoxifen: The Italian study in hysterectomized women. Breast. 1995;4(4):267–72. Exclusion: 11
426 Visvanathan K, Chlebowski RT, Hurley P, . American society of clinical oncology clinical practice guideline update on the use of pharmacologic interventions including tamoxifen, raloxifene, and aromatase inhibition for breast cancer risk reduction. J. Clin. Oncol. 2009 Jul 01;27(19):3235–58. doi: 10.1200/JCO.2008.20.5179. PMID: 19470930. Exclusion: 719470930
427 Visvanathan K, Hurley P, Bantug E, . Use of pharmacologic interventions for breast cancer risk reduction: American Society of Clinical Oncology clinical practice guideline. J. Clin. Oncol. 2013 Aug 10;31(23):2942–62. doi: 10.1200/JCO.2013.49.3122. PMID: 23835710. Exclusion: 723835710
428 Visvanathan K, Lippman SM, Hurley P, . American Society of Clinical Oncology clinical practice guideline update on the use of pharmacologic interventions including tamoxifen, raloxifene, and aromatase inhibition for breast cancer risk reduction.[Erratum appears in Gynecol Oncol. 2010 Mar;116(3):592 Note: Visvanathan, Kala [added]; Lippman, Scott M [added]; Hurley, Patricia [added]]. Gynecol. Oncol. 2009 Oct;115(1):132–4. doi: 10.1016/j.ygyno.2009.06.006. PMID: 19716939. Exclusion: 219716939
429 Vogel VG. Follow-up of the breast cancer prevention trial and the future of breast cancer prevention efforts. Clin. Cancer Res. 2001 Dec;7:(12 Suppl):4413s–8s; discussion 1s-2s. PMID: 11916233. Exclusion: 1111916233
430 Vogel VG. Tamoxifen, raloxifene and tibolone decrease risk of invasive breast cancer in healthy women but increase risk of thromboembolism (tamoxifen, raloxifene), endometrial cancer (tamoxifen) or stroke (tibolone). Evid. Based Med. 2010;15(4):122. doi: 10.1136/ebm1044. PMID: 20682726. Exclusion: 720682726
431 Vogel VG. Role of hormones in cancer prevention. American Society of Clinical Oncology Educational Book. 2014:34–40. doi: 10.14694/EdBook_AM.2014.34.34. PMID: 24857058. Exclusion: 1024857058
432 Vogel VG. Chemoprevention: Who, what, when? Menopause. 2014;21(12):1320–1. doi: 10.1097/gme.0000000000000370. Exclusion: 7
433 Vogel VG. Ongoing data from the breast cancer prevention trials: opportunity for breast cancer risk reduction. BMC Med. 2015 Mar 26;13:63. doi: 10.1186/s12916-015-0300-0. PMID: 25888872. Exclusion: 225888872
434 Vogel VG. Update on Breast Cancer Risk Reduction Therapy. Curr. Breast Cancer Rep. 2016;8(3):175–82. doi: 10.1007/s12609-016-0221-8. Exclusion: 10
435 von Minckwitz G, Loibl S, Jackisch C, . The GISS trial: a phase II prevention trial of screening plus goserelin, ibandronate, versus screening alone in premenopausal women at increased risk of breast cancer. Cancer epidemiology, biomarkers & prevention : a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. 2011 Oct;20(10):2141–9. PMID: 21795500. Exclusion: 521795500
436 Vukicevic S, Grgurevi L. The PEARL trial: Lasofoxifene and incidence of fractures, breast cancer and cardiovascular events in postmenopausal osteoporotic women. Int. J. Clin. Rheumtol. 2011;6(4):387–91. doi: 10.2217/ijr.11.37. Exclusion: 5
437 Walcott FL, Land SR, Costantino JP, . Vasomotor symptoms, BMI, and adherence to tamoxifen in the National Surgical Adjuvant Breast and Bowel Project (NSABP) Breast Cancer Prevention Trial (P-1). J. Clin. Oncol. 2015 Annual Meeting of the American Society of Clinical Oncology, ASCO Chicago, IL United States;33(15 SUPPL. 1):CONFERENCE START: 2015 May 29 CONFERENCE END: Jun 2. Exclusion: 7
438 Wang X, Oldani MJ, Zhao X, . A review of cancer risk prediction models with genetic variants. Cancer Inform. 2014;13:19–28. doi: 10.4137/CIN.S13788. PMID: 25288876. Exclusion: 1025288876
439 Warner E, Lockwood G, Tritchler D, . The risk of breast cancer associated with mammographic parenchymal patterns: a meta-analysis of the published literature to examine the effect of method of classification. Cancer Detect. Prev. 1992;16(1):67–72. PMID: 1532349. Exclusion: 51532349
440 Waters EA, Cronin KA, Graubard BI, . Prevalence of tamoxifen use for breast cancer chemoprevention among U.S. women. Cancer Epidemiol. Biomarkers Prev. 2010 Feb;19(2):443–6. doi: 10.1158/1055-9965.epi-09-0930. PMID: 20142242. Exclusion: 620142242
441 Waters EA, McNeel TS, Stevens WM, . Use of tamoxifen and raloxifene for breast cancer chemoprevention in 2010. Breast Cancer Res. Treat. 2012 Jul;134(2):875–80. doi: 10.1007/s10549-012-2089-2. PMID: 22622807. Exclusion: 622622807
442 Wickerham DL, Cecchini RS, Vogel VG, . Final updated results of the NRG Oncology/NSABP Protocol P-2: Study of Tamoxifen and Raloxifene (STAR) in preventing breast cancer. J. Clin. Oncol. 2015 Annual Meeting of the American Society of Clinical Oncology, ASCO Chicago, IL United States;33(15 SUPPL. 1):CONFERENCE START: 2015 May 29 CONFERENCE END: Jun 2. Exclusion: 7
443 Wise J. NICE recommends preventive drugs for breast cancer. BMJ. 2013 Jun 25;346:f4116. doi: 10.1136/bmj.f4116. PMID: 23801701. Exclusion: 223801701
444 Wolff T, Tai E, Miller T. Screening for skin cancer: an update of the evidence for the U.S. Preventive Services Task Force. Ann. Intern. Med. 2009;150(3):194–8. PMID: 19189909. Exclusion: 219189909
445 Wuttke M, Phillips KA. Risk reduction strategies in familial breast and ovarian cancer. Asia Pac. J. Clin. Oncol. 2014;10:79–80. doi: 10.1111/ajco.12304. Exclusion: 7
446 Wuttke M, Phillips KA. Clinical management of women at high risk of breast cancer. Curr. Opin. Obstet. Gynecol. 2015 Feb;27(1):6–13. doi: 10.1097/GCO.0000000000000140. PMID: 25502281. Exclusion: 1025502281
447 Yaffe MJ, Boyd NF. Mammographic image analysis for breast cancer risk assessment. Semin. Breast Dis. 2002;5(4):238–46. Exclusion: 7
448 Yiannakopoulou E. Aspirin and NSAIDs for breast cancer chemoprevention. Eur. J. Cancer Prev. 2015 Sep;24(5):416–21. doi: 10.1097/CEJ.0000000000000098. PMID: 25380191. Exclusion: 425380191
449 Yoshida R, Yotsumoto J, Watanabe C, . Evaluation of the BRCA1 and BRCA2 mutation prediction models in Japanese patients with breast cancer. J. Clin. Oncol. 2014;32(26). Exclusion: 7
450 Zelnak AB, O’Regan RM. Chemoprevention of breast cancer. Curr. Probl. Cancer. 2004 Jul–Aug;28(4):201–17. PMID: 15318323. Exclusion: 1015318323
451 Zeng YC, Xiao YP, Xue M. Exemestane for breast-cancer prevention. N. Engl. J. Med. 2011 Sep 15;365(11):1057; author reply -8. doi: 10.1056/NEJMc1108287#SA3. PMID: 21916644. Exclusion: 221916644
452 Zhang Y, Simondsen K, Kolesar JM. Exemestane for primary prevention of breast cancer in postmenopausal women. Am. J. Health Syst. Pharm. 2012 Aug 15;69(16):1384–8. doi: 10.2146/ajhp110585. PMID: 22855103. Exclusion: 822855103
453 Zhao X, Li L, Wang Z. Chemoprevention of breast cancer: current status and future prospects. Front. Biosci. 2006 Sep 01;11:2249–56. PMID: 16720311. Exclusion: 1016720311
454 Ziv E, Tice JA, Sprague B, . Using breast cancer risk associated polymorphisms to identify women for breast cancer chemoprevention. PLoS One. 2017;12(1)doi: 10.1371/journal.pone.0168601. PMID: 28107349. Exclusion: 528107349

## Appendix A5 Criteria for Assessing Internal Validity of Individual Studies^*^

### Randomized, Controlled Trials (RCTs) and Cohort Studies

#### Criteria

- Initial assembly of comparable groups
- For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
- For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Single arm cohort studies were rated based on initial assembly of group, consideration of potential confounders, important outcomes considered, measurements: equal, reliable, and valid (includes masking of outcome assessment), and reporting of attrition if applicable.

#### Definition of ratings based on above criteria

Good:: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair:: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
Poor:: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

#### Definition of ratings based on above criteria

Good:: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease
Fair:: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients
Poor:: Has a fatal flaw, such as: Uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

* Reference: U.S. Preventive Services Task Force Procedure Manual. December 2015. Accessed at https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes

## Appendix A6 Expert Reviewers of the Draft Report

- Therese Bartholomew Bevers, MD, FAAFP, Medical Director, Cancer Prevention Center, Professor of Clinical Cancer Prevention, The University of Texas MD Anderson Cancer Center; Houston, TX.
- Jack Cuzick, PhD, FRS, CBE, Director and Head of Centre for Cancer Prevention, Wolfson Institute of Preventive Medicine; London, UK.
- Leslie Ford, MD, Associate Director for Clinical Research, Division of Cancer Prevention, National Cancer Institute; Washington DC.
- Brandy Heckman-Stoddard, PhD, MPH, Chief, Division of Cancer Prevention, National Cancer Institute; Washington DC.
- Barry Kramer, MD, MPH, Director, Division of Cancer Prevention, National Cancer Institute; Washington DC.
- Sam G. Smith, MSc, PhD, Cancer Research UK Postdoctoral Fellow, University Academic Fellow, Leeds Institute of Health Sciences; London, UK.
- Diana Petitti, MD, MPH, Department of Biomedical Informatics, University of Arizona; Tucson, AZ.
- Brandy Peaker, MD, MPH, Centers for Disease Control and Prevention; Atlanta, GA.

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the final report findings.