# Glossary for Tables 1 Through 12

Alt | Alternative
Avg | Average
BRFSS | Behavioral Risk Factor Surveillance Survey
C | Combined
Cal | Calorie
CAD | Coronary artery disease
CHD | Coronary heart disease
Chol | Cholesterol
Cnslg | Counseling
Cont | Control group
Crit | Criterion
CSI | Cholesterol/saturated fat index
CVD | Cardiovascular disease
D-gm SFA | Dietary grams of saturated fatty acids
DINE | Dietary Instrument for Nutrition Education
F | Female
F & V | Fruits and vegetables
F/U | Follow-up
g | Gram(s)
G/d | Grams per day
HMO | Health Maintenance Organization
Hr | Hour(s)
Hx/o | History of
Intv | Intervention group
M | Male
MD | Medical doctor
Mo | Months
Modif | Modification
MPH | Master of Public Health
Msg | Message
NA | Not available
NCEP | National Cholesterol Education Panel
NP | Nurse practitioner
NR | Not reported
Poly | Polyunsaturated
Poly fat | Polyunsaturated fat
Pts | Patients
q | every
RD | Registered Dietician
RN | Registered Nurse
ROS | Review of systems
RR | Relative Risk
RRR | Relative Risk Reduction
Sat fat | Saturated fat
Trans | Trans-saturated fat
Unsat | Unsaturated
vs. | versus
w/ | With
Wkly | Weekly
Wk(s) | Week(s)
Yr(s) | Year(s)