# References

1 Whitlock EP, Orleans CT, Pender N, Allan J. Behavioral Counseling Interventions for Health Promotion & Disease Prevention in Health Care Settings. Overview Chapter Prepared by Oregon Health and Science University Evidence-Based Practice Center. Contract No. 290-97-0018. AHRQ Publications No. XX-XXX. Rockville, Md.: Agency for Healthcare Research and Quality; In Press.
2 US. Preventive Services Task Force. Counseling to Promote a Healthy Diet. Guide to Clinical Preventive Services (2nd Ed.). Baltimore: Williams and Wilkins. 1996:625-642. [pmcid: 167828].
3 US. Department of Agriculture and the U.S. Department of Health and Human Services. Nutrition and Your Health: Dietary Guidelines for Americans. 5th ed. Washington, D.C. 2000. [pmcid: 384376].
4 McTigue K, Harris R, Hemphill MB, Bunton A. Screening and Interventions for Overweight and Obesity in Adults. Systematic Evidence Review No. X. Prepared by RTI-University of North Carolina at Chapel Hill Evidence-Based Practice Center. Contract No. 290-97-011. AHRQ Publications No. XX-XXX. Rockville, Md.: Agency for Healthcare Research and Quality. 2002. [pmid: 12069559]. [pmcid: 321147].
5 Katan MB, Grundy SM, Willett WC. Should a low-fat, high-carbohydrate diet be recommended for everyone?. N Engl J Med. 1997. [pmid: 9262504].
6 Posner B.M., Cobb J.L., Bealnger A.J., Cupples L.A., D'Agostino R.B., Stokes J. Dietary lipid predictors of coronary heart disease in men. Arch Intern Med. 1991;151:1181-1187. [pmid: 2043019].
7 LaRosa JC, Hunninghake D, Bush D, et al. The cholesterol facts. A summary of the evidence relating dietary fats, serum cholesterol, and coronary heart disease. A joint statement by the American Heart Association and the National Heart, Lung, and Blood Institute. The Task Force on Cholesterol Issues, American Heart Association. Circulation. 1990;81:1721-1733. [pmid: 2184951].
8 Ascherio A, Katan MB, Zock PL, Stampfer MJ, Willett WC. Trans fatty acids and coronary heart disease. N Engl J Med. 1999;340:1994-8. [pmid: 10379026].
9 Oomen CM, Ocke MC, Feskens EJ, van Erp-Baart MA, Kok FJ, Kromhout D. Association between trans fatty acid intake and 10-year risk of coronary heart disease in the Zutphen Elderly Study: a prospective population-based study. Lancet. 2001;357:746-51. [pmid: 11253967].
10 Hooper L, Summerbell C, Higgins J, et al. ver. Issue 3. Oxford: Update Software: The Cochrane Library. 2000. [pmcid: 384376].
11 Ebrahim S, Smith GD. Systematic review of randomised controlled trials of multiple risk factor interventions for preventing coronary heart disease. BMJ. 1997;314:1666-1674. [pmid: 9193292].
12 Hjermann I, Velve Byre K, Holme I, Leren P. Effect of diet and smoking intervention on the incidence of coronary heart disease. Report from the Oslo Study Group of a randomised trial in healthy men. Lancet. 1981;2:1303-1310. [pmid: 6118715].
13 Neaton JD, Broste S, Cohen L, Fishman EL, Kjelsberg MO, Schoenberger J. The multiple risk factor intervention trial (MRFIT). VII. A comparison of risk factor changes between the two study groups. Prev Med. 1981;10:519-543. [pmid: 7027241].
14 Webber LS, Srinivasan SR, Wattigney WA, Berenson GS. Tracking of serum lipids and lipoproteins from childhood to adulthood: The Bogalusa Heart Study. Am J Epidemiol. 1991;133:884-899. [pmid: 2028978].
15 Obarzanek E, Hunsberger SA, Van Horn L, et al. Safety of a fat-reduced diet: the Dietary Intervention Study in Children (DISC). Pediatrics. 1997;100:51-59. [pmid: 9200359].
16 Gillman MW, Cupples LA, Millen BE, Ellison RC, Wolf PA. Inverse association of dietary fat with development of ischemic stroke in men. JAMA. 1997;278:2145-50. [pmid: 9417007].
17 Lewis CJ, Yetley EA. Health claims and observational human data: relation between dietary fat and cancer. Am J Clin Nutr. 1999;69:1357S-1364S. [pmid: 10359237].
18 Kolonel LN, Nomura AM, Cooney RV. Dietary fat and prostate cancer: current status. J Natl Cancer Inst. 1999;91:414-428. [pmid: 10070940].
19 Hunter DJ, Spiegelman D, Adami HO, et al. Cohort studies of fat intake and the risk of breast cancer--a pooled analysis. N Engl J Med. 1996;334:356-361. [pmid: 8538706].
20 Lipkin M, Reddy B, Newmark H, Lamprecht SA. Dietary factors in human colorectal cancer. Annu Rev Nutr. 1999;19:545-586. [pmid: 10448536].
21 Howe GR, Aronson KJ, Benito E, et al. The relationship between dietary fat intake and risk of colorectal cancer: evidence from the combined analysis of 13 case-control studies. Cancer Causes Control. 1997;8:215-228. [pmid: 9134246].
22 Hopkins PN. Effects of dietary cholesterol on serum cholesterol: a meta-analysis and review. Am J Clin Nutr. 1992;55:1060-70. [pmid: 1534437].
23 McNamara DJ. Dietary cholesterol and atherosclerosis. Biochim Biophys Acta. 2000;1529:310-320. [pmid: 11111098].
24 Key T, Fraser G, Thorogood M, et al. Mortality in vegetarians and nonvegetarians: detailed findings from a collaborative analysis of 5 prospective studies. Am J Clin Nutr. 1999;70:516S-524S. [pmid: 10479225].
25 Ness AR, Powles JW. Fruit and vegetables, and cardiovascular disease: a review. Int J Epidemiol. 1997;26:1-13. [pmid: 9126498].
26 Law MR, Morris JK. By how much does fruit and vegetable consumption reduce the risk of ischaemic heart disease?. Eur J Clin Nutr. 1998;52:549-556. [pmid: 9725654].
27 Pietinen P, Rimm EB, Korhonen P, et al Intake of dietary fiber and risk of coronary heart disease in a cohort of Finnish men: the alpha-tocopherol, beta-carotene cancer prevention study Circulation 1996 9411:2720 2727 8941095
28 Mann JI, Appleby PN, Key TJ, Thorogood M. Dietary determinants of ischaemic heart disease in health conscious individuals. Heart. 1997;78:450-455. [pmid: 9415002].
29 Key TJ, Thorogood M, Appleby PN, Burr ML. Dietary habits and mortality in 11,000 vegetarians and health conscious people: results of a 17 year follow-up. BMJ. 1996;313:775-779. [pmid: 8842068].
30 Joshipura KJ, Hu FB, Manson JE, et al. The effect of fruit and vegetable intake on risk for coronary heart disease. Ann Intern Med. 2001;134:1106-1114. [pmid: 11412050].
31 Ascherio A, Hennekens C, Willett WC, et al. Prospective study of nutritional factors, blood pressure, and hypertension among US women. Hypertension. 1996;27:1065-1072. [pmid: 8621198].
32 Appel LJ, Moore TJ, Obarzanek E, et al. A clinical trial of the effects of dietary patterns on blood pressure. DASH Collaborative Research Group. N Engl J Med. 1997;336:1117-1124. [pmid: 9099655].
33 Rouse IL, Beilin LJ, Armstrong BK, Vandongen R. Blood-pressure-lowering effect of a vegetarian diet: controlled trial in normotensive subjects. Lancet. 1983;1:5-10. [pmid: 6129380].
34 Margetts BM, Beilin LJ, Vandongen R, Armstrong BK. Vegetarian diet in mild hypertension: a randomized controlled trial. Br Med J. 1986;293:1468-1471. [pmid: 3026552].
35 Zino S, Skeaff M, Williams S, Mann J. Randomized controlled trial of effect of fruit and vegetable consumption on plasma concentrations of lipids and antioxidants. BMJ. 1997;314:1787-1791. [pmid: 9224079].
36 Steinmetz K, Potter J. Vegetables, fruit, and cancer prevention: a review. J Am Diet Assoc. 1996;96:1027-1039. [pmid: 8841165].
37 Feskanich D, Ziegler RG, Michaud DS, et al. Prospective study of fruit and vegetable consumption and risk of lung cancer among men and women. J Natl Cancer Inst. 2000;92:1812-1823. [pmid: 11078758].
38 Smith-Warner SA, Spiegelman D, Adami HO, et al. Types of dietary fat and breast cancer: a pooled analysis of cohort studies. Int J Cancer. 2001;92:767-774. [pmid: 11340585].
39 Gandini S, Merzenich H, Robertson C, Boyle P. Meta-analysis of studies on breast cancer risk and diet: the role of fruit and vegetable consumption and the intake of associated micronutrients. Eur J Cancer. 2000;36:636-646. [pmid: 10738129].
40 Bazzano LA, He J, Ogden LG, et al. Legume consumption and risk of coronary heart disease in US men and women: NHANES I Epidemiologic Follow-up Study. Arch Intern Med. 2001;161:2573-2578. [pmid: 11718588].
41 Kushi LH, Meyer KA, Jacobs DR. Cereals, legumes, and chronic disease risk reduction: evidence from epidemiologic studies. Am J Clin Nutr. 1999;70:451S-458S. [pmid: 10479217].
42 Jacobs DR, Pereira MA, Meyer KA, Kushi LH. Fiber from whole grains, but not refined grains, is inversely associated with all-cause mortality in older women: the Iowa women's health study. J Am Coll Nutr. 2000;19:326S-330S. [pmid: 10875605].
43 Liu S, Manson JE, Stampfer MJ, et al. Whole grain consumption and risk of ischemic stroke in women: A prospective study. JAMA. 2000;284:1534-1540. [pmid: 11000647].
44 Kromhout D, Bosschieter EB, de Lezenne Coulander C. Dietary fibre and 10-year mortality from coronary heart disease, cancer, and all causes. The Zutphen study. Lancet. 1982;2:518-522. [pmid: 6125679].
45 Burr ML, Fehily AM, Gilbert JF, et al. Effects of changes in fat, fish, and fibre intakes on death and myocardial reinfarction: diet and reinfarction trial (DART). Lancet. 1989;2:757-761. [pmid: 2571009].
46 Glore S, Van Treeck D, Knehans A, Guild. M. Soluble Fiber and serum lipids. J Am Diet Assoc. 1994;94:425-436. [pmid: 8144811].
47 Brown L, Rosner B, Willett WW, Sacks FM. Cholesterol-lowering effects of dietary fiber: a meta-analysis. Am J Clin Nutr. 1999;69:30-42. [pmid: 9925120].
48 He J, Whelton PK. Effect of dietary fiber and protein intake on blood pressure: a review of epidemiologic evidence. Clin Exp Hypertens. 1999;21:785-796. [pmid: 10423101].
49 Howe GR, Hirohata T, Hislop TG, Iscovich JM, Yuan JM, Katsouyanni K. Dietary Factors and Risk of Breast Cancer: Combined Analysis of 12 case-Control Studies. J Nat Cancer Inst. 1990;82:561-569. [pmid: 2156081].
50 Kim Y. AGA technical review: impact of dietary fiber on colon cancer occurrence. Gastroenterology. 2000;118:1235-1257. [pmid: 10833499].
51 Schatzkin A, Lanza E, Corle D, et al. Lack of effect of a low-fat, high-fiber diet on the recurrence of colorectal adenomas. Polyp Prevention Trial Study Group. N Engl J Med. 2000;342:1149-1155. [pmid: 10770979].
52 Alberts D, Martinez M, Roe D, et al. Lack of effect of a high-fiber cereal supplement on the recurrence of colorectal adenomas. N Engl J Med. 2000;342:1156-1162. [pmid: 10770980].
53 Marckmann P, Gronbaek M. Fish consumption and coronary heart disease mortality. A systematic review of prospective cohort studies. Eur J Clin Nutr. 1999;53:585-590. [pmid: 10477243].
54 Singh RB, Rastogi SS, Sircar AR, Mehta PJ, Sharma KK. Dietary strategies for risk-factor modification to prevent cardiovascular diseases. Nutrition. 1991;7:210-214. [pmid: 1666320].
55 GISSI-Prevenzione Investigators (Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto miocardico). Dietary supplementation with n-3 polyunsaturated fatty acids and vitamin E after myocardial infarction: results of the GISSI-Prevenzione trial. Lancet. 1999;354:447-455. [pmid: 10465168].
56 Law MR, Frost CD, Wald NJ. By how much does dietary salt reduction lower blood pressure?. BMJ. 1991;302:811-815. [pmid: 2025703].
57 Midgley J, Matthew A, Greenwood C, Logan A. Effect of reduced dietary sodium on blood pressure: a meta-analysis of randomized controlled trials. JAMA. 1996;275:1590-1597. [pmid: 8622251].
58 Cutler J, Follmann D, Allender P. Randomized trials of sodium reduction: an overview. Am J Clin Nutr. 1997;65:643S-651S. [pmid: 9022560].
59 The Trials of Hypertension Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high- normal blood pressure. The Trials of Hypertension Prevention, phase II. Arch Intern Med. 1997;157:657-667. [pmid: 9080920].
60 Hypertension Prevention Trial Research Group. The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Arch Intern Med. 1990;150:153-62. [pmid: 2404477].
61 Siani A, Strazzullo P. Dietary potassium and cardiovascular disease: clinical applications. J Cardiovasc Risk. 2000;7:15-21. [pmid: 10785869].
62 Whelton PK, He J, Cutler JA, et al. Effects of oral potassium on blood pressure. Meta-analysis of randomized controlled clinical trials. JAMA. 1997;277:1624-1632. [pmid: 9168293].
63 Feskanich D, Willett WC, Stampfer MJ, Colditz GA. Milk, dietary calcium, and bone fractures in women: a 12-year prospective study. Am J Public Health. 1997;87:992-997. [pmid: 9224182].
64 Cumming R. Calcium intake and bone mass: a quantitative review of the evidence. Calcified Tissue International. 1990;47:194-201. [pmid: 2146986].
65 Heaney RP. Calcium, dairy products and osteoporosis. J Am Coll Nutr. 2000;19:83S-99S. [pmid: 10759135].
66 Giovannucci E, Rimm EB, Wolk A, et al. Calcium and fructose intake in relation to risk of prostate cancer. Cancer Res. 1998;58:442-7. [pmid: 9458087].
67 Antonov A. Children born during the siege in Leningrad in 1942. J Pediatr. 1947;30:250-295. [pmid: 20290348].
68 Stein A, Susser M, Saenger G, et al. Famine and human development: the Dutch hunger winter of 1944/45. New York, NY: Oxford University Press. 1974. [pmcid: 434367].
69 Singer JE, Westphal M, Niswander K. Relationship of weight gain during pregnancy to birth weight and infant growth and development in the first year of life. Obstet Gynecol. 1968;31:417-23. [pmid: 5639199].
70 Institute of Medicine, Subcommittee on Nutritional Status and Weight Gain During Pregnancy. Nutrition during pregnancy. Washington, D.C.: National Academy Press. 1990. [pmcid: 362864].
71 Institute of Medicine. Preventing low birthweight. Washington, D.C.: National Academy Press. 1985. [pmcid: 425569].
72 National Research Council, Food and Nutrition Board. Committee on Dietary Allowances. Washington, D.C.: National Academy Press. 1989. [pmcid: 361432].
73 Ammerman A, Haines P, DeVellis R, et al. A brief dietary assessment to guide cholesterol reduction in low-income individuals: design and validation. J Am Diet Assoc. 1991;91:1385-1390. [pmid: 1939975].
74 Angus RM, Sambrook PN, Pocock NA, Eisman JA. A simple method for assessing calcium intake in Caucasian women. J Am Diet Assoc. 1989;89:209-214. [pmid: 2915093].
75 Block G, Gillespie C, Rosenbaum EH, Jenson C. A rapid food screener to assess fat and fruit and vegetable intake. Am J Prev Med. 2000;18:284-288. [pmid: 10788730].
76 Blumberg SJ, Bialostosky K, Hamilton WL, Briefel RR. The effectiveness of a short form of the Household Food Security Scale. Am J Public Health. 1999;89:1231-1234. [pmid: 10432912].
77 Conner SJ, Gustafson JR, Sexton G, Becker N, Artaud-Wild S, Conner WE. The diet habit survey: a new method of dietary assessment that relates to plasma choolesterol changes. J Am Diet Assoc. 1992;92:41-47. [pmid: 1728622].
78 Gans K, Sundaram SMJ, Hixson M, Linnan L, Carleton R. Rate your plate: an eating pattern assessment and educational tool used at cholesterol screening and education programs. J Nutr Educ. 1993;25:29-36.
79 Heller RF, Pedoe HD, Rose G. A simple method of assessing the effect of dietary advice to reduce plasma cholesterol. Prev Med. 1981;10:364-370. [pmid: 7267631].
80 Knapp JA, Hazuda HP, Haffner SM, Yonug EA, Stern MP. A saturated fat/cholesterol avoidance scale: sex and ethnic differences in a biethnic population. J Am Diet Assoc. 1988;88:172-177. [pmid: 3339203].
81 Kris-Etherton P, Eissenstat B, Jaax S, et al. Validation for MEDFICTS, a dietary assessment instrument for evaluating adherence to total and saturated fat recommendations of the National Cholesterol Education Program Step 1 and Step 2 diets. J Am Diet Assoc. 2001;101:81-86. [pmid: 11209589].
82 Kristal A, Shattuck A, Henry H, Fowler A. Rapid assessment of dietary intake of fat, fiber, and saturated fat: validity of an instrument suitable for community intervention research and nutritional surveilllance. Am J Health Promot. 1990;4:288-295.
83 Kristal A, Shattuck A, Henry H. Patterns of dietary behavior associated with selecting diets low in fat: reliability and validity of a behavioral approach to dietary assessment. J Am Diet Assoc. 1990;90:214-220. [pmid: 2303658].
84 Pietinen P, Hartman AM, Haapa E, et al. Reproducibility and validity of dietary assessment instruments. I. A self-administered food use questionnaire with a portion size picture booklet. Am J Epidemiol. 1988;128:655-666. [pmid: 2458036].
85 Peters JR, Quiter ES, Brekke ML, et al. The Eating Pattern Assessment Tool: a simple instrument for assessing dietary fat and cholesterol intake. J Am Diet Assoc. 1994;94:1008-1013. [pmid: 8071482].
86 Retzlaff BM, Dowdy AA, Walden CE, Bovbjerg VE, Knopp RH. The Northwest Lipid Research Clinic Fat Intake Scale: validation and utility. Am J Public Health. 1997;87:181-185. [pmid: 9103094].
87 Rifas-Shiman SL, Willett WC, Lobb R, Kotch J, Dart C, Gillman MW. PrimeScreen, a brief dietary screening tool: reproducibility and comparability with both a longer food frequency questionnaire and biomarkers. Public Health Nutr. 2001;4:249-254. [pmid: 11299098].
88 Roe L, Strong C, Whiteside C, Neil A, Mant D. Dietary intervention in primary care: validity of the DINE method for diet assessment. Fam Pract. 1994;11:375-381. [pmid: 7895964].
89 Serdula M, Coates R, Byers T, et al. Evaluation of a brief telephone questionnaire to estimate fruit and vegetable consumption in diverse study populations. Epidemiology. 1993;4:455-463. [pmid: 8399695].
90 Shannon J, Kristal AR, Curry SJ, Beresford SA. Application of a behavioral approach to measuring dietary change: the fat- and fiber-related diet behavior questionnaire. Cancer Epidemiol Biomarkers Prev. 1997;6:355-361. [pmid: 9149896].
91 Kuczmarski RJ, Ogden CL, Grummer-Strawn LM, et al. CDC growth charts: United States. Adv Data. 2000:1-27. [pmid: 11183293].
92 Boutry M, Needlman R. Use of diet history in the screening of iron deficiency. Pediatrics. 1996;98:1138-1142. [pmid: 8951266].
93 US Department of Health and Human Services. Recommendations to prevent and control iron deficiency in the United States. Morb Mortal Wkly Rep. 1998;47:1-29.
94 Bogen DL, Duggan AK, Dover GJ, Wilson MH. Screening for iron deficiency anemia by dietary history in a high-risk population. Pediatrics. 2000;105:1254-1259. [pmid: 10835066].
95 Rockett HR, Colditz GA. Assessing diets of children and adolescents. Am J Clin Nutr. 1997;65:1116S-1122S. [pmid: 9094907].
96 Van Horn LV, Gernhofer N, Moag-Stahlberg A, et al. Dietary assessment in children using electronic methods: telephones and tape recorders. J Am Diet Assoc. 1990;90:412-416. [pmid: 2307817].
97 Lytle LA, Nichaman MZ, Obarzanek E, et al. Validation of 24-hour recalls assisted by food records in third-grade children. The CATCH Collaborative Group. J Am Diet Assoc. 1993;93:1431-1436. [pmid: 8245378].
98 Calfas KJ, Zabinski MF, Rupp J. Practical nutrition assessment in primary care settings: a review. Am J Prev Med. 2000;18:289-299. [pmid: 10788731].
99 Little P, Barnett J, Margetts B, et al. The validity of dietary assessment in general practice. J Epidemiol Commun Health. 1999;53:165-172.
100 Johnsen C, East JM, Glassman P. Management of malnutrition in the elderly and the appropriate use of commercially manufactured oral nutritional supplements. J Nutr Health Aging. 2000;4:42-46. [pmid: 10840476].
101 Boult CB, Krinke UB, Urdangarin CF, Skarin V. The validity of nutritional status as a marker for future disability and depressive symptoms among high-risk older adults. Am J Prev Med. 1999;47:995-999.
102 Vellas B, Guigoz Y, Garry PJ, et al. The Mini Nutritional Assessment (MNA) and its use in grading the nutritional state of elderly patients. Nutrition. 1999;15:116-122. [pmid: 9990575].
103 Levine BS, Wigren MM, Chapman DS, Kerner JF, Bergman RL, Rivlin RS. A national survey of attitudes and practices of primary-care physicians relating to nutrition: strategies for enhancing the use of clinical nutrition in medical practice. Am J Clin Nutr. 1993;57:115-119. [pmid: 8424377].
104 Thomas DR, Ashmen W, Morley JE, Evans WJ. Nutritional management in long-term care: development of a clinical guideline. Council for Nutritional Strategies in Long-Term Care. J Gerontol A Biol Sci Med Sci. 2000;55:M725-M734. [pmid: 11129394].
105 Wolinsky FD, Coe RM, McIntosh WmA, et al. Progress in the development of a nutritional risk index. 1990;120:1549-1553. [pmid: 2243304].
106 Wellman NS The nutrition screening initiative 1994 528:S44 S47 7970305
107 Contento I, Randell J, Basch C. Review and analysis of evaluation measures used in nutrition education intervention research. J Nutr Educ Behav. 2002;34:2-25. [pmid: 11917668].
108 Prochaska JO, DiClemente CC, Norcross JC. In search of how people change. Applications to addictive behaviors. Am Psychol. 1992;47:1102-1114. [pmid: 1329589].
109 Greene G, Rossi S, Reed G, Willey C, Prochaska J. Stages of change for reducing dietary fat to 30% of energy or less. J Am Diet Assoc. 1994;94:1105-1110. quiz. 1111. 1112. [pmid: 7930314].
110 Greene G, Rossi S, Rossi J, Velicer W, Fava J, Prochaska J. Dietary applications of the stages of change model. J Am Diet Assoc. 1999;99:673-678. [pmid: 10361528].
111 Glanz K, Patterson RE, Kristal AR, et al. Stages of change in adopting healthy diets: fat, fiber, and correlates of nutrient intake. Health Educ Q. 1994;21:499-519. [pmid: 7843980].
112 Haire-Joshu D, Auslander W, Houston C, Williams J. Staging of dietary patterns among African American women. Health Educ Behav. 1999;26:90-102. [pmid: 9952054].
113 Contento I, Balch G, Bronner Y, et al. The effectiveness of nutrition education and implications for nutrition education policy, programs, and research: A review of research. J Nutr Educ. 1995.
114 Life Sciences Research Office, Federation of American Societies for Experimental Biology Core indicators of nutritional state for difficult-to-sample populations J Nutr. 1990 120(Suppl):1559 1600 2243305
115 Hamilton W, Cook J, Thompson W, et al. Household food insecurity in the United States in 1995: Summary report of the Food Security Measurement Project. Alexandria, VA: US Dept. of Agriculture, Food and Consumer Service. 1997. [pmcid: 176006].
116 Carlson S, Andrews M, Bickel G Measuring food insecurity and hunger in the United States: development of a national benchmark measure and prevalence estimates J Nutr. 1999 129(Suppl):510S 516S 10064320
117 Elkeles RS, Diamond JR, Poulter C, et al. Cardiovascular outcomes in type 2 diabetes: A double-blind placebo-controlled study of bezafibrate: the St. Mary's, Ealing, Northwick Park Diabetes Cardiovascular Disease Prevention (SENDCAP) Study. Diabetes Care. 1998;21:641-648. [pmid: 9571357].
118 Coates RJ, Bowen DJ, Kristal AR, et al. The Women's Health Trial Feasibility Study in Minority Populations: changes in dietary intakes. Am J Epidemiol. 1999;149:1104-1112. [pmid: 10369504].
119 Heller RF, Walker RJ, Boyle CA, O'Connell DL, Rusakaniko S, Dobson AJ. A randomised controlled trial of a dietary advice program for relatives of heart attack victims. Med J Aust. 1994;161:529-531. [pmid: 7968751].
120 Lee-Han H, Cousins M, Beaton M, et al. Compliance in a randomized clinical trial of dietary fat reduction in patients with breast dysplasia. Am J Clin Nutr. 1988;48:575-586. [pmid: 3046298].
121 Ornish D, Brown SE, Scherwitz LW, et al. Can lifestyle changes reverse coronary heart disease? The Lifestyle Heart Trial. Lancet. 1990;336:129-133. [pmid: 1973470].
122 Simkin-Silverman LR, Wing RR. Management of obesity in primary care. Obesity Research. 1997;5:603-612. [pmid: 9449146].
123 Campbell MK, DeVellis BM, Strecher VJ, Ammerman AS, DeVellis RF, Sandler RS. Improving dietary behavior: the effectiveness of tailored messages in primary care settings. Am J Public Health. 1994;84:783-787. [pmid: 8179049].
124 Campbell NC, Ritchie LD, Thain J, Deans HG, Rawles JM, Squair JL. Secondary prevention in coronary heart disease: a randomised trial of nurse led clinics in primary care. Heart. 1998;80:447-452. [pmid: 9930042].
125 Delichatsios HK, Friedman RH, Glanz K, et al. Randomized trial of a "talking computer" to improve adults' eating habits. Am J Health Promot. 2001;15:215-24. [pmid: 11349340].
126 Keyserling TC, Ammerman AS, Davis CE, Mok MC, Garrett J, Simpson RJ. A randomized controlled trial of a physician-directed treatment program for low-income patients with high blood cholesterol: the Southeast Cholesterol Project. Arch Fam Med. 1997;6:135-145. [pmid: 9075448].
127 Knutsen SF, Knutsen R. The Tromso Survey: the Family Intervention study--the effect of intervention on some coronary risk factors and dietary habits, a 6-year follow-up. Prev Med. 1991;20:197-212. [pmid: 2057468].
128 Lindholm LH, Ekbom T, Dash C, Eriksson M, Tibblin G, Schersten B. The impact of health care advice given in primary care on cardiovascular risk. CELL Study Group. BMJ. 1995;310:1105-1109. [pmid: 7742677].
129 Steptoe A, Doherty S, Rink E, Kerry S, Kendrick T, Hilton S. Behavioural counselling in general practice for the promotion of healthy behaviour among adults at increased risk of coronary heart disease: randomised trial. BMJ. 1999;319:943-947. discussion. 947. 948. [pmid: 10514155]. [pmcid: 28246].
130 Beresford SA, Farmer EM, Feingold L, Graves KL, Sumner SK, Baker RM. Evaluation of a self-help dietary intervention in a primary care setting. Am J Public Health. 1992;82:79-84. [pmid: 1311152].
131 Beresford SA, Curry SJ, Kristal AR, Lazovich D, Feng Z, Wagner EH. A dietary intervention in primary care practice: the Eating Patterns Study. Am J Public Health. 1997;87:610-616. [pmid: 9146440].
132 Kristal AR, Curry SJ, Shattuck AL, Feng Z, Li S. A randomized trial of a tailored, self-help dietary intervention: the Puget Sound Eating Patterns study. Prev Med. 2000;31:380-9. [pmid: 11006063].
133 Cupples ME, McKnight A. Randomised controlled trial of health promotion in general practice for patients at high cardiovascular risk. BMJ. 1994;309:993-996. [pmid: 7950723].
134 Delichatsios HK, Hunt MK, Lobb R, Emmons K, Gillman MW. EatSmart: efficacy of a multifaceted preventive nutrition intervention in clinical practice. Prev Med. 2001;33:91-98. [pmid: 11493041].
135 Hunt IF, Jacob M, Ostegard NJ, Masri G, Clark VA, Coulson AH. Effect of nutrition education on the nutritional status of low-income pregnant women of Mexican descent. Am J Clin Nutr. 1976;29:675-684. [pmid: 1274890].
136 Mojonnier ML, Hall Y, Berkson DM, et al. Experience in changing food habits of hyperlipidemic men and women. J Am Diet Assoc. 1980;77:140-148. [pmid: 7400495].
137 Ockene IS, Hebert JR, Ockene JK, et al. Effect of physician-delivered nutrition counseling training and an office-support program on saturated fat intake, weight, and serum lipid measurements in a hyperlipidemic population: Worcester Area Trial for Counseling in Hyperlipidemia (WATCH). Arch Int Med. 1999;159:725-731. [pmid: 10218753].
138 Roderick P, Ruddock V, Hunt P, Miller G. A randomized trial to evaluate the effectiveness of dietary advice by practice nurses in lowering diet-related coronary heart disease risk. Br J Gen Pract. 1997;47:7-12. [pmid: 9115804].
139 Ockene IS, Hebert JR, Ockene JK, Merriam PA, Hurley TG, Saperia GM. Effect of training and a structured office practice on physician-delivered nutrition counseling: the Worcester-Area Trial for Counseling in Hyperlipidemia (WATCH). Am J Prev Med. 1996;12:252-258. [pmid: 8874688].
140 Masley S, Phillips S, Copeland JR. Group office visits change dietary habits of patients with coronary artery disease-the dietary intervention and evaluation trial (D.I.E.T.). J Fam Pract. 2001;50:235-239. [pmid: 11252212].
141 Henderson MM, Kushi LH, Thompson DJ, et al. Feasibility of a randomized trial of a low-fat diet for the prevention of breast cancer: dietary compliance in the Women's Health Trial Vanguard Study. Prev Med. 1990.
142 Insull W Jr, Henderson MM, Prentice RL, et al. Results of a randomized feasibility study of a low-fat diet. Arch Intern Med. 1990;150:421-427. [pmid: 2405805].
143 Kristal AR, White E, Shattuck AL, et al. Long-term maintenance of a low-fat diet: durability of fat-related dietary habits in the Women's Health Trial. J Am Diet Assoc. 1992;92:553-559. [pmid: 1573135].
144 White E, Shattuck AL, Kristal AR, et al. Maintenance of a low-fat diet: follow-up of the Women's Health Trial. Cancer Epidemiol Biomarkers Prev. 1992;1:315-323. [pmid: 1338896].
145 Maskarinec G, Chan CL, Meng L, Franke AA, Cooney RV. Exploring the feasibility and effects of a high-fruit and -vegetable diet in healthy women. Cancer Epidemiol Biomarkers Prev. 1999;8:919-924. [pmid: 10548322].
146 Siero FW, Broer J, Bemelmans WJ, Meyboom-de Jong BM. Impact of group nutrition education and surplus value of Prochaska- based stage-matched information on health-related cognitions and on Mediterranean nutrition behavior. Health Educ Res. 2000;15:635-647. [pmid: 11184222].
147 Lutz SF, Ammerman AS, Atwood JR, Campbell MK, DeVellis RF, Rosamond WD. Innovative newsletter interventions improve fruit and vegetable consumption in healthy adults. J Am Diet Assoc. 1999;99:705-709. [pmid: 10361533].
148 Baron JA, Gleason R, Crowe B, Mann JI. Preliminary trial of the effect of general practice based nutritional advice. Br J Gen Pract. 1990;40:137-141. [pmid: 2115348].
149 Fiore M, Bailey W, Cohen S, et al. Treating Tobacco Use and Dependence. Clinical Practice Guideline. Rockville, Md.: US Department of Health and Human Services, PHS. 2000. [pmcid: 384376].
150 Ammerman A, Lindquist C, Hersey J, et al. Evidence report on the efficacy of interventions to modify dietary behavior related to evidence risk. Rockville, MD: Agency for Healthcare Research and Quality. 2001. [pmid: 11759784]. [pmcid: 320826].
151 Mullen PD, Simons-Morton DG, Ramirez G, Frankowski RF, Green LW, Mains DA. A meta-analysis of trials evaluating patient education and counseling for three groups of preventive health behaviors. Patient Educ Couns. 1997;32:157-173. [pmid: 9423498].
152 Thompson R, Summerbell C, Hooper L, et al. Dietary advice given by a dietician versus other health professional or self-help resources to reduce blood cholesterol (Cochrane review). The Cochrane Libray. 2001.
153 Shannon BM, Tershakovec AM, Martel JK, et al. Reduction of elevated LDL-cholesterol levels of 4- to 10-year-old children through home-based dietary education. Pediatrics. 1994;94:923-927. [pmid: 7971012].
154 Kottke TE, Foels JK, Hill C, Choi T, Fenderson DA. Perceived palatability of the prudent diet: results of a dietary demonstration for physicians. Prev Med. 1983;12:588-594. [pmid: 6622440].
155 Jack BW, Gans KM, McQuade W, et al. A successful physician training program in cholesterol screening and management. Prev Med. 1991;20:364-377. [pmid: 1862058].
156 Lazarus K, Weinsier RL, Boker JR. Nutrition knowledge and practices of physicians in a family-practice residency program: the effect of an education program provided by a physician nutrition specialist. Am J Clin Nutr. 1993;58:319-335. [pmid: 8237840].
157 Kirby RK, Chauncey KB, Jones BG. The effectiveness of a nutrition education program for family practice residents conducted by a family practice resident-dietitian. Fam Med. 1995;27:576-580. [pmid: 8829982].
158 McPhee SJ, Bird JA, Fordham D, Rodnick JE, Osborn EH. Promoting cancer prevention activities by primary care physicians. Results of a randomized, controlled trial. JAMA. 1991;266:538-544. [pmid: 2061981].
159 Olson RE. The dietary recommendations of the American Academy of Pediatrics. Am J Clin Nutr. 1995;61:271-273. [pmid: 7840062].
160 Anderson G. Factors affecting nutritional lifestyle changes in children. Prevention of Athersclerosis and Hypertension Beginning in Youth. Philadelphia, PA. 1994:3-10.
161 Pugliese MT, Weyman-Daum M, Moses N, Lifshitz F. Parental health beliefs as a cause of nonorganic failure to thrive. Pediatrics. 1987;80:175-182. [pmid: 3615087].
162 Lifshitz F, Moses N. Growth failure. A complication of dietary treatment of hypercholesterolemia. Am J Dis Child. 1989;143:537-542. [pmid: 2718985].
163 Mauer AM. Should there be intervention to alter serum lipids in children?. Annu Rev Nutr. 1991;11:375-391. [pmid: 1892706].
164 Kaplan RM, Toshima MT. Does a reduced fat diet cause retardation in child growth?. Prev Med. 1992;21:33-52. [pmid: 1738767].
165 Obarzanek E, Kimm SY, Barton BA, et al. Long-Term Safety and Efficacy of a Cholesterol-Lowering Diet in Children With Elevated Low-Density Lipoprotein Cholesterol: Seven-Year Results of the Dietary Intervention Study in Children (DISC). Pediatrics. 2001;107:256-264. [pmid: 11158455].
166 Hiddink GJ, Hautvast JG, van Woerkum CM, Fieren CJ, van 't Hof MA. Information sources and strategies of nutrition guidance used by primary care physicians. Am J Clin Nutr. 1997;65:1996S-2003S. [pmid: 9174509].
167 Serra-Majem LL, Calvo JR, Male ML, Ribas L, Lainez P Population attitudes towards changing dietary habits and reliance on general practitioners in Spain Eur J Clin Nutr. 1999 53Suppl 2:S58 S61 10406439
168 Schucker B, Wittes JT, Cutler JA, et al. Change in physician perspective on cholesterol and heart disease. JAMA. 1987;258: 24:3521-3526. [pmid: 3682155].
169 Schucker B, Wittes JT, Santanello NC, et al. Change in cholesterol awareness and action. Results from national physician and public surveys. Arch Intern Med. 1991;151:666-673. [pmid: 2012446].
170 Ammerman AS, DeVellis RF, Carey TS, et al. Physician-based diet counseling for cholesterol reduction: current practices, determinants, and strategies for improvement. Prev Med. 1993;22:96-109. [pmid: 8475015].
171 Morris SE, Lean ME, Hankey CR, Hunter C Who gets what treatment for obesity? A survey of GPs in Scotland Eur J Clin Nutr. 1999 53Suppl 2:S44 S48 10406436
172 Zoorob RJ, Mainous AG3. Practice patterns of rural family physicians based on the American Diabetes Association standards of care. J Commun Health. 1996;21:175-182.
173 Rafferty M. Prevention services in primary care: taking time, setting priorities. West J Med. 1998;169:269-275. [pmid: 9830354].
174 Troiano RP, Flegal KM, Kuczmarski RJ, Campbell SM, Johnson CL. Overweight prevalence and trends for children and adolescents. The National Health and Nutrition Examination Surveys, 1963 to 1991. Arch Pediatr Adolesc Med. 1995;149:1085-1091. [pmid: 7550810].
175 Hiddink GJ, Hautvast JG, van Woerkum CM, van't Hof MA, Fieren CJ Cross-sectional and longitudinal analyses of nutrition guidance by primary care physicians Eur J Clin Nutri. 1999 53Suppl 2:S35 S43
176 Mann KV, Putnam W. Physicians' perceptions of their role in cardiovascular risk reduction. Prev Med. 1989;18:45-48. [pmid: 2710762].
177 Holund U, Thomassen A, Boysen G, et al. Importance of diet and sex in prevention of coronary artery disease, cancer, osteoporosis, and overweight or underweight: a study of attitudes and practices of Danish primary care physicians. Am J Clin Nutr. 1997;65:2004S-2006S. [pmid: 9174510].
178 Kottke TE, Foels JK, Hill C, Choi T, Fenderson DA. Nutrition counseling in private practice: attitudes and activities of family physicians. Prev Med. 1984;13:219-225. [pmid: 6330723].
179 Secker-Walker RH, Morrow AL, Kresnow M, Flynn BS, Hochheiser LI. Family physicians' attitudes about dietary advice. Fam Pract Res J. 1991;11:161-170. [pmid: 2058408].
180 Kushner RF. Barriers to providing nutrition counseling by physicians: a survey of primary care practitioners. Prev Med. 1995;24:546-552. [pmid: 8610076].
181 Shea S, Basch CE, Zybert P. Correlates of internists' practices in caring for patients with elevated serum cholesterol. Nutrition. 1990;4:421-428.
182 Glanz K. Review of nutritional attitudes and counseling practices of primary care physicians. Am J Clin Nutr. 1997;65:2016S-2019S. [pmid: 9174514].
183 Potter J, Langhorne P, Roberts M. Routine protein energy supplementation in adults: systematic review. BMJ. 1998;317:495-501. [pmid: 9712593]. [pmcid: 28640].
184 Aubin M, Godin G, Vezina L, Maziade J, Desharnais R. Hypercholesterolemia screening. Does knowledge of blood cholesterol level affect dietary fat intake?. Can Fam Physician. 1998;44:1289-1297. [pmid: 9640523].
185 Bakx JC, Stafleu A, van Staveren WA, van den Hoogen HJ, van Weel C. Long-term effect of nutritional counseling: a study in family medicine. Am J Clin Nutr. 1997;65:1946S-1950S. [pmid: 9174500].
186 Barratt A, Reznik R, Irwig L, et al. Work-site cholesterol screening and dietary intervention: the Staff Healthy Heart Project. Steering Committee. Am J Public Health. 1994;84:779-82. [pmid: 8179048].
187 Brannon SD, Tershakovec AM, Shannon BM. The cost-effectiveness of alternative methods of nutrition education for hypercholesterolemic children. Am J Public Health. 1997;87:1967-1970. [pmid: 9431285].
188 Caggiula AW, Watson JE, Kuller LH, et al. Cholesterol-lowering intervention program. Effect of the step I diet in community office practices. Arch Intern Med. 1996;156:1205-1213. [pmid: 8639015].
189 Crouch M, Sallis JF, Farquhar JW, et al. Personal and mediated health counseling for sustained dietary reduction of hypercholesterolemia. Prev Med. 1986;15:282-91. [pmid: 3749008].
190 DeBusk RF, Miller NH, Superko HR, et al. A case-management system for coronary risk factor modification after acute myocardial infarction. Ann Intern Med. 1994;120:721-9. [pmid: 8147544].
191 de Lorgeril M. [Oxidative stress and lipid-protein peroxidation after cardiac transplantation. New hypotheses for explaining pathogenesis of accelerated forms of ischemic heart disease]. Arch Mal Coeur Vaiss. 1994;87:1467-73. [pmid: 7771894].
192 Dyson PA, Hammersley MS, Morris RJ, Holman RR, Turner RC. The Fasting Hyperglycaemia Study: II. Randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metabolism. 1997;46:50-55. [pmid: 9439560].
193 Ershoff DH, Aaronson NK, Danaher BG, Wasserman FW. Behavioral, health, and cost outcomes of an HMO-based prenatal health education program. Public Health Reports. 1983;98:536-547. [pmid: 6419268].
194 Family Heart Study Group. Randomised controlled trial evaluating cardiovascular screening and intervention in general practice: principal results of British family heart study. BMJ. 1994;308:313-320. [pmid: 8124121].
195 Fletcher V. An individualized teaching programme following primary uncomplicated myocardial infarction. J Adv Nurs. 1987;12:195-200. [pmid: 3646271].
196 Foreyt JP, Scott LW, Mitchell RE, Gotto AM. Plasma lipid changes in the normal population following behavioral treatment. J Consult Clin Psychol. 1979;47:440-452. [pmid: 528712].
197 George SM, Latham MC, Abel R, Ethirajan N, Frongillo EAJ. Evaluation of effectiveness of good growth monitoring in south Indian villages. Lancet. 1993;342:348-352. [pmid: 8101589].
198 Gosselin P, Verreault R, Gaudreault C, Guillemette J. [Dietary treatment of mild to moderate hypercholesterolemia. Effectiveness of different interventions]. [French]. Can Fam Physician. 1996;42:2160-2167. [pmid: 8974552].
199 Heller RF, Elliott H, Bray AE, Alabaster M. Reducing blood cholesterol levels in patients with peripheral vascular disease: dietitian or diet fact sheet?. Med J Aust. 1989;151:566-568. [pmid: 2593891].
200 Henkin Y, Shai I, Zuk R, et al. Dietary treatment of hypercholesterolemia: do dieticians do it better? A randomized, controlled trial. Am J Med. 2000;109:549-555. [pmid: 11063956].
201 Howard-Pitney B, Winkleby MA, Albright CL, Bruce B, Fortmann SP. The Stanford Nutrition Action Program: a dietary fat intervention for low-literacy adults. Am J Public Health. 1997;87:1971-1976. [pmid: 9431286].
202 Kuehl KS, Cockerham JT, Hitchings M, Slater D, Nixon G, Rifai N. Effective control of hypercholesterolemia in children with dietary interventions based in pediatric practice. Prev Med. 1993;22:154-166. [pmid: 8483855].
203 Luepker RV, Smith LK, Rothchild SS, Gillis A, Kochman L, Warbasse JR. Management of hypercholesterolemia: evaluation of practical clinical approaches in healthy young adults. Am J Cardiol. 1978;41:590-596. [pmid: 204183].
204 Lytle LA, Stone EJ, Nichaman MZ, et al. Changes in nutrient intakes of elementary school children following a school-based intervention: results from the CATCH Study. Prev Med. 1996;25:465-477. [pmid: 8818069].
205 Miettinen TA, Huttunen JK, Naukkarinen V, et al. Multifactorial primary prevention of cardiovascular diseases in middle- aged men. Risk factor changes, incidence, and mortality. JAMA. 1985;254:2097-2102. [pmid: 4046137].
206 Multiple Risk Factor Intervention Trial Research Group. JAMA. 1982 248 1465 1477 7050440
207 Naglak M, Mitchell DC, Kris-Etherton P, Harkness W, Pearson TA. What to consider when conducting a cost-effectiveness analysis in a clinical setting. J Am Diet Assoc. 1998;98:1149-1154. [pmid: 9787721].
208 Neil HA, Roe L, Godlee RJ, et al. Randomised trial of lipid lowering dietary advice in general practice: the effects on serum lipids, lipoproteins, and antioxidants. BMJ. 1995;310:569-573. [pmid: 7888933].
209 Neyses L, Dorst K, Michaelis J, et al. Compliance with salt restriction as a limiting factor in the primary prevention of hypertension. J Hypertens Suppl. 1985;3:S87-S90. [pmid: 3916444].
210 Nikolaus T, Schlierf G, Vogel G, Schuler G, Wagner I. Treatment of coronary heart disease with diet and exercise--problems of compliance. Ann Nutr Metab. 1991;35:1-7. [pmid: 2058997].
211 Ornish D. Avoiding revascularization with lifestyle changes: The Multicenter Lifestyle Demonstration Project. Am J Cardiol. 1998;82:72T-76T. [pmid: 9860380].
212 Imperial Cancer Research Fund OXCHECK Study Group. Effectiveness of health checks conducted by nurses in primary care: results of the OXCHECK study after one year. Imperial Cancer Research Fund OXCHECK Study Group. BMJ. 1994;308:308-312. [pmid: 8124120].
213 Imperial Cancer Research Fund OXCHECK Study Group. Effectiveness of health checks conducted by nurses in primary care: final results of the OXCHECK study. Imperial Cancer Research Fund OXCHECK Study Group. BMJ. 1995;310:1099-1104. [pmid: 7742676].
214 Pritchard DA, Hyndman J, Taba F. Nutritional counseling in general practice: a cost effective analysis. J Epidemiol Community Health. 1999;53:311-316. [pmid: 10396539].
215 Ridgeway NA, Harvill DR, Harvill LM, Falin TM, Forester GM, Gose OD. Improved control of type 2 diabetes mellitus: a practical education/behavior modification program in a primary care clinic. South Med J. 1999;92:667-672. [pmid: 10414474].
216 Smith LK, Luepker RV, Rothchild SS, Gillis A, Kochman L, Warbasse JR. Management of type IV hyperlipoproteinemia. Evaluation of practical clinical approaches. Ann Intern Med. 1976;84:22-28. [pmid: 1106289].
217 Tershakovec AM, Shannon BM, Achterberg CL, et al. One-year follow-up of nutrition education for hypercholesterolemic children. Am J Public Health. 1998;88:258-261. [pmid: 9491017].
218 Tomson Y, Johannesson M, Aberg H. The costs and effects of two different lipid intervention programmes in primary health care. J Intern Med. 1995;237:13-17. [pmid: 7830025].
219 Waber DP, Vuori-Christiansen L, Ortiz N, et al. Nutritional supplementation, maternal education, and cognitive development of infants at risk of malnutrition. Am J Clin Nutr. 1981;34:807-813. [pmid: 7223696].
220 Winkleby MA, Howard-Pitney B, Albright CA, Bruce B, Kraemer HC, Fortmann SP. Predicting achievement of a low-fat diet: a nutrition intervention for adults with low literacy skills. Prev Med. 1997;26:874-882. [pmid: 9388800].
221 Harris RP, Helfand M, Woolf SH, et al Current Methods of the US Preventive Services Task Force: A Review of the Process Am J Prev Med. 2001 2(3S):21 35
222 Centers for Disease Control and Prevention. Physician advice and individual behaviors about cardiovascular disease risk reduction: seven states and Puerto Rico. MMWR Morb Mortal Wkly Rpt. 1997;48:74-77.
223 Centers for Disease Control and Prevention. Missed opportunities in preventive counseling for cardiovascular disease. MMWR Morb Mortal Wkly Rep. 1998;47:91-95. [pmid: 9480410].
224 Neighbor WEJ, Scott CS, Schaad DC, Macdonald SC, Van Citters R. Assessment and counseling of coronary risk factors by family practice residents. J Fam Pract. 1991;32:273-281. [pmid: 2002318].
225 Ross EM, Rosenberg IH, Dawson-Hughes B, Col NF, Wong JB Fitting nutrition into the medical model: the role of decision analytic cost-effectiveness techniques Eur J Clin Nutr. 1999 53Suppl 2:S25 S28 10406433
226 Curry S, Kristal A, Bowen D. An application of the stage model of behavior change to dietary fat reduction. Health Educ Res. 1992;7:97-105. [pmid: 10148734].