# Results

We present here the results of our systematic review for the US Preventive Services Task Force (USPSTF) of issues relating to promoting healthy diets; the chapter is organized in terms of the key questions introduced in our analytic framework (Figure 1) and the text of Chapter II. As explained in Chapter I, the first part of the results concerns the relationships between numerous dietary constituents and a variety of important health outcomes. The remainder of the chapter deals with questions about the efficacy or effectiveness of counseling activities to change dietary behaviors for the better, including the availability of reasonably brief instruments to assess dietary behaviors feasible for use in primary care settings and populations. Tables and Figure 2 can be found at the end of the chapter. A glossary defining all abbreviations and acronyms used in one or more of these tables is found just ahead of Table 1.

Table 1. Dietary assessment tools

Citation and Instrument | Nutrients or Foods Assessed* | Number of Items, Time to Administer, ^†^ Scoring | Response Metric | Diet Intake Validity ^‡^ : Correlations Criterion Measures | Population or Comments
Ammerman et al., 1991^ 73 ^ Dietary Risk Assessment | Sat fat Cholesterol F & V | 38 items 10-15 minutes Weighted score for dietary atherogenic risk | Frequency Food choices Amount Food preparation | Total score: r = .60 Crit: Keys score calculated from three 24-hour recalls | Low literacy
Angus et al., 1989^ 74 ^ Frequency Questionnaire for Calcium Intake | Calcium | 24 items Time NR Calculated from master list | Frequency Amount | r = .79 Crit: 4 day weighed food record | Caucasian
Block et al., 2000^ 75 ^ Food Intake Screener | Fat F&V Fiber | 22 items Less than 6 minutes Self-scored | Frequency | r = .60 to .70 for total fat, saturated fat, cholesterol, fruit & vegetable intake Crit: 100 item Block Food Frequency Questionnaire | Multi-ethnic
Blumberg, 1999^ 76 ^ | Food insecurity and hunger | 6 items responses scored to distinguish levels of severity | Yes, no and scaled response options | Sensitivity: .92, Specificity: .99 6 item subset of 18 item survey Crit: comprehensive assessment of food insecurity in Current Population Survey | Food security supplement to 1995 Current Populations Survey (nationally representative sample)
Conner et al., 1992^ 77 ^ Diet Habit Survey | Sat fat Cholesterol Crude fiber | 32 items 30 minutes Calculated Carbohydrate Score and a Chol/Sat Fat Score [based on the Chol/Sat fat Index (CSI)] | Frequency Food choices Amount Food preparation | Chol/sat fat index: r = .42 Chol score: r = .14 Crit: 24-hour diet recall | Coronary heart disease prevention study
Gans et al., 1993^ 78 ^ Rate Your Plate | Fat Sat fat Cholesterol | 18 items Weighted score indicates low, medium, or highly heart-healthy diet | Food choices Amount Food preparation | Total fat: r = −.43 Sat fat: r = −.48 Cholesterol: r = −.37 Crit: Willet Food Frequency Questionnaire | Portuguese and Anglo
Heller et al., 1981^ 79 ^ | Sat fat | 8 items Time NR Weighted score | Frequency Amount Food preparation | r = .60 for diet score with sat fat Crit: 3-day diet record | British
Knapp et al., 1988^ 80 ^ Sat. fat and Cholesterol Avoidance Scale | Sat fat Cholesterol | 24 items Time NR Score = sum of point value for each response item | Frequency of avoidance behaviors Food choices | Statistically significant (p < 0.001) ability to differentiate between high-fat and low-fat diets Crit: food frequency questionnaire and 24-hour recall | Hispanic
Kris-Etherton et al., 2001^ 81 ^ MEDFICTS Assessment Tool | Total fat Sat fat Cholesterol | 20 items Time NR Weighted composite score indicative of compliance with NCEP Step 1 or 2 diets | Frequency Amount | Two validation studies % calories as total fat: r = .79, r = .52 % calories as sat fat: r = .60, r = .54 Cholesterol: r = .71, r = .39 Crit: two 3-day diet records | Developed for use in cardiovascular health screening, clinical practice, or research to identify adherence to NCEP Step 1 or 2 diets
Kristal et al., 1990^ 82 ^ | Total fat % cal fat Sat fat Fiber | 18 items 4.2 minutes Scores for three parts: core foods, secondary core foods, & dietary behaviors | Frequency, Food choice, Amount Food preparation | r's with food record & food frequency, respectively: Total fat: r = .52, r = .61 % cal fat: r = .53, r = .65 Sat fat: r = .61, r= .58 Fiber: r = .40, r = .47 Crit: 4-day food record and food frequency questionnaire | Women from HMO very interested in diet and health
Kristal et al., 1990 ^ 83 ^ Eating Patterns Questionnaire | Fat Meat | 18 items Time NR 5 subscales Weighted score | Avoidance, frequency, food choice, food prep. | Avoid fat: r = .57 Avoid meat: r = − .34 Low fat modif: r = − .35 Choose low fat alt: r = .42 Replace high w/ low fat: r = −.50 Crit: % total kcal from fat | Identifies behavioral goals but not quantities consumed Also validated in 900 women in Women's Health Trial
Pietinen et al., 1988^ 84 ^ Qualitative Food Frequency Questionnaire | Total fat Sat fat Poly fat Fiber Antioxidant | 44 items Time NR Total fat, sat fat, unsat fat, fiber & selected nutrients are ranked into quintiles | Frequency | Total fat: r = .41 Sat. fat: r = .56 Poly: r = .64 Fiber: r = .63 Crit: 2-day food records | Finnish
Peters et al., 1994^ 85 ^ Eating Patterns Assessment Tool | Total fat Cholesterol | 8 multi-component items 11 minutes 4 response columns correspond to diet very high or high in fat, and to Step 1 & 2 NCEP diets | Frequency | Range of r's for concurrent validity: High fat scale: r = .54 to .56 Low fat scale: r = −.18 to −.21 Crit: 5 4-day food records | Employees of large manufacturing corporation
Retzlaff et al., 1997^ 86 ^ NW Lipid Clinic Fat and Intake Scale | Total fat Sat fat Cholesterol | 12 items Time NR Score is summed across all items indicating low-to-moderate or high fat & cholesterol diet | Frequency Food choices Food preparation | Total fat: r = .51 Sat fat: r = .51 Cholesterol: r = .52 Crit: 4-day food records (avg for men and women) | Identifies goals for specific foods as well as for general practices with the option for positively framed ("do more of X") recommendations
Rifas-Shiman et al., 2001^ 87 ^ Prime Screen | Fat (animal, sat, trans) Cholesterol Fiber Multiple nutrients and micro-nutrients | 26 items 5 minutes Score indicates level of risk for common chronic diseases of adulthood | Frequency Use of supplements | Foods and food groups: mean r = .61 Nutrients: mean r = .56 (sat fat: r = .59; trans fat: r = .64; cholesterol: r = .63) Crit: semi-quantitative food frequency questionnaire Vitamin E: r= .30 Beta-carotene: r = .43 Lutein/ zeaxanthin: r = .43 Crit: plasma levels | Large managed care organization in New England
Roe et al., 1994^ 88 ^ Dietary Instrument for Nutrition Education | Total fat Sat fat Unsat fat Fiber | 19 groups of food less than 10 minutes Score is sum of individual scores for fiber, fat, sat fat, & unsat fat -- all categorized as low, medium, or high intake | Frequency | Total fat: r = .51 Sat fat: r = .57 Unsat fat: r = .43 Fiber: r = .46 Crit: 4-day diet record | British
Serdula et al., 1993^ 89 ^ Telephone Questionnaire for Behavioral Risk Factor Surveillance System (BRFSS) | F & V | 6 items Time NR Score is index created from sum of daily frequency of consumption of food items in fruit & vegetable module | Frequency Food choices | r = .47 to .57 with food frequency r = .29 to .54 with multiple recall Crit: varied by site | 5 diverse populations BRFSS questions ^†^
Shannon et al., 1997^ 90 ^ | Total fat Fiber | 33 items Time NR Fat scale score Fiber scale score | Food choices Amount Food preparation ("dietary behavior") | Fat scale: r = .53 Fiber: r = .50 Crit: food frequency questionnaire | Eating Patterns Study population (primary care)

*Sat fat: saturated fat; unsat fat: unsaturated fat; F&V: fruits and vegetables; poly fat: polyunsaturated fat; trans: trans-saturated fat.

† NR, not reported. NCEP, National Cholesterol Education Panel.

‡ r = correlation coefficient; crit, criterion; modif, modification; alt, alternative; kcal, kilocalorie; avg, average.

§ BRFSS, Behavioral Risk Factor Surveillance Survey.

Figure 2. Dietary behavioral counseling literature search

## Key Question No. 1: Relationship Between Dietary Patterns and Health Outcomes

Our search of the Database of Reviews of Effectiveness for systematic reviews using the key word "diet" produced 215 results. Through this search and subsequent targeted MEDLINE searches, we identified 58 references on the diet-health relationship that we included in our final review.

Eating habits over a lifetime can have a significant impact on the incidence and severity of many health disorders. The complete body of literature regarding the health effects of foods is beyond the scope of this report and has been the subject of extensive reviews.^ 3 ^

A direct relationship exists between nutritional risk factors and certain key diseases. We focus here on the relationship between several different dietary elements and the risk of important health outcomes. When data on health outcomes are lacking but reasonable surrogate measures exist, we examine the surrogate measures instead. For each dietary element, we first consider the epidemiologic evidence regarding the association between that element and various health studies. Next, we consider any studies that examine the effect of change consumption of the dietary element and change in health states or a well-validated surrogate outcome. Another USPSTF review will address the crucial question of the effect of diet on obesity.^ 4 ^

### Effects of Diets High in Fat Intake

The effects of dietary fat intake, including the effect of changes in the subfractions of saturated, polyunsaturated, and monounsaturated fats, have been examined in relation to a wide range of health outcomes using a variety of study designs. Whether dietary goals should recommend limiting total fat intake or should keep the total proportion of dietary fat constant while changing the balance of subfractions remains a topic for substantial debate and research. This debate has not been fully elucidated through research comparing the two approaches; its full description is beyond the scope of this review.^ 5 ^ Nevertheless, we will attempt to summarize current findings with respect to the relationship between dietary fat intake and important health outcomes such as those relating to coronary heart disease (CHD), stroke, or cancer.

#### Dietary Fat and Coronary Heart Disease

##### Observational studies

Observational studies of the relationship between the level of dietary saturated fat and the incidence of CHD and stroke have generally, but not always, found a positive association.^ 6 ^ Much of this relationship appears to be mediated through total cholesterol (TC) and low-density lipoprotein (LDL) cholesterol levels, which are related to both dietary saturated fat intake and the incidence of CHD events.^ 7 ^ A recent development is the greater appreciation that another fat subtype, trans-unsaturated fats, which are commonly used in oils for fried foods, is also associated with unhealthy lipid levels and an increased risk of heart disease.^8,9^

##### Effect of interventions to change dietary fat on CHD and stroke

Hooper et al. reviewed the effect of dietary interventions to lower fat intake or the incidence of CHD.^ 10 ^ They identified 26 randomized trials published through January 1999 that had been intended to modify fat or cholesterol intake, were not multi-factorial, and lasted at least 6 months. Their overall analysis found no effect on total mortality (relative risk [RR] 0.98; 95% confidence interval [CI], 0.86-1.12), a small, statistically nonsignificant effect on cardiovascular mortality (RR, 0.91; 95% CI, 0.77-1.07), and a 16% reduction in total cardiovascular events (RR, 0.84; 95% CI, 0.72-0.99). Most of the trials included patients with previous history of CHD; 2 included patients without known CHD living in institutional settings and being fed controlled diets. The data were insufficient to measure the effect of fat-restricted diets among free-living patients without previous CHD.^ 10 ^

The best data about the effect of dietary counseling on CHD incidence in persons without previously known CHD come from several large trials that addressed multiple CHD risk factors. Ebrahim and Smith performed a systematic review and meta-analysis of 14 such trials of at least 6 months' duration, including 5 major trials examining efforts to prevent CHD events through changes in dietary fat for high-risk patients with no previous history of CHD.^ 11 ^ The dietary interventions were designed to improve serum lipid levels and reduce CHD events. Some of the trials also provided smoking cessation counseling or hypertension treatment. The summary effect on serum cholesterol was a reduction of 5.4 mg/dL (0.14 mmol/L), with a standard error of 0.38 mg/dl, (0.01mmol/L). Overall, the interventions did not have a significant effect on total mortality (odds ratio [OR], 0.97; 95% CI, 0.92-1.02), CHD mortality (OR, 0.96; 95% CI, 0.88-1.04), or nonfatal myocardial infarctions (OR, 1.0; 95% CI, 0.92-1.07).

The combined estimates, however, obscure some of the heterogeneity among individual trial results. The Oslo trial, in particular, tested a diet that reduced saturated fats and increased polyunsaturated fats.^ 12 ^ The investigators found large reductions in total and LDL cholesterol, increases in high density lipoprotein (HDL) cholesterol, and decreased CHD events among patients assigned to the intervention. The patients in this trial, however, had very high cholesterol levels (average total cholesterol at entry, 327 mg/dl) and consumed diets very different from those consumed in the United States today. Hence, the results of the Oslo trial may not generalize well to US populations. The Multiple Risk Factor Intervention Trial (MRFIT) study in the United States did not find important reductions in CHD events, despite intensive dietary counseling consisting of 10 weekly group sessions followed by individualized counseling at least every 4 months thereafter.^ 13 ^

##### Dietary fat intake and CHD risk factors in children

The benefits of reduced dietary fat intake during childhood are uncertain. Some observational evidence suggests that high childhood serum lipid levels are associated with higher levels in adulthood, but the relationship is imperfect.^ 14 ^ The effect of reducing dietary fat intake during childhood has been examined in a large RCT involving children ages 8 to 10 years at enrollment with LDL levels between about 115 mg/dl and 165 mg/dl. Intervention patients received a diet providing 28% of energy from total fat. Follow-up lasted a mean of 7.4 years.^ 15 ^ The 3-year intervention included 18 individual and group sessions during the first year and 4 to 6 individual or group sessions in years 2 and 3, with monthly telephone contacts between sessions. Patients receiving the intervention were able to reduce total fat intake by 2% to 4% and saturated fat intake by 1% to 2%. Patients had no adverse changes in mean height, ferritin levels, body mass index (BMI), or selected psychometric indices, but they also demonstrated little or no long-term change in serum cholesterol levels: differences in LDL cholesterol were 3% to 4% at 1 year but only 1% to 2% at the final follow-up visit.

#### Dietary Fat and Stroke

Gillman et al. examined the relationship between dietary fat intake and the risk of stroke in men using data from the Framingham Heart Study.^ 16 ^ They found that increasing intake of dietary total and saturated fat was associated with lower risk of ischemic stroke (RR, 0.85 [95% CI, 0.78-0.94] for each 3% increase in total fat intake; RR, 0.91 [95% CI 0.85, 0.98] for each 1% increase in saturated fat). Adjustment for potential confounders did not affect the results. Insufficient data are available to examine the relationship among women.

#### Dietary Fat and Cancer

The relationship between dietary fat and cancer has been difficult to elucidate. Numerous observational studies have examined the intake of dietary fats, including total fat and the saturated and unsaturated subfractions, and different forms of cancer.^ 17 ^ Most analyses have focused on the relationship between dietary fat and cancers of the prostate, breast, or colon. We examine these relationships in some detail here, but a full review of the topic is beyond the scope of this report.

##### Dietary fat and prostate cancer

Kolonel et al recently reviewed the relationship between dietary fat and prostate cancer.^ 18 ^ They examined English language studies from MEDLINE (search dates not reported) on the relationship between dietary fat (or fat-containing foods) and incidence or mortality from prostate cancer. Ecologic and case-control studies generally supported a relationship between dietary total or saturated fat and prostate cancer; cohort studies have had conflicting results.

##### Dietary fat and breast cancer

Hunter et al. performed a meta-analysis of 7 prospective cohort studies (including more than 337,000 women) that examined the relationship between dietary fat and breast cancer.^ 19 ^ They found no significant association between dietary fat consumption and breast cancer (RR for highest versus lowest quartile, 1.05; 95% CI, 0.94-1.16). The lack of association persisted even when the subgroup of women with very low intake (less than 20% of calories from total fat) were compared with women in the highest quartile of intake.

##### Dietary fat and colon cancer

Some studies suggest that diets high in total fat increase the risk of colorectal cancer: relative risks for cohort studies have ranged from 1.3 to 2.2.^ 20 ^ Animal fats seem to be most closely associated with risk. Other reviews have not identified a relationship between dietary fat and colorectal cancer once the investigators controlled for total caloric consumption.^ 21 ^

### Effects of Diets High in Cholesterol

Dietary cholesterol intake appears to have at best modest effect on serum cholesterol levels once fat intake has been controlled for. No evidence exists to determine if reducing dietary cholesterol specifically reduces CHD events.^22,23^

### Effects of Diets High in Fruits and Vegetables, Including Vegetarian Diets

#### Vegetarian Diets

To examine the relationship between a vegetarian diet and multiple health outcomes, Key et al. identified 5 large prospective cohort studies that drew their study populations from groups known to have a high proportion of vegetarians, defined as persons who reported not eating fish or meat.^ 24 ^ These 5 studies examined health outcomes for more than 76,000 persons ages 16 to 89 years over a mean of 10.6 years, including 27,000 vegetarians. Using a random effects model meta-analysis to combine results from the 5 studies, they found that total mortality did not clearly differ between vegetarians and nonvegetarians (RR for death among vegetarians, 0.95; 95% CI, 0.82-1.11). CHD mortality, however, was significantly lower among vegetarians (RR, 0.76; 95% CI, 0.62-0.94). The relative risk reduction was larger at younger ages and among those following a vegetarian diet for more than 5 years. Risk reductions persisted after adjustment for potential confounders of age, smoking status, alcohol use, education level, exercise level, and body mass index. Summary risk ratios for death rates from colorectal, lung, breast, or prostate cancer did not differ, although the total numbers of events were small enough that excluding a modest protective effect with certainty was not possible. No effect was seen on stroke mortality.

#### Effects of Fruits and Vegetables on CHD and Stroke

Numerous observational studies have examined the effect of diets high in fruit and vegetables on CHD and stroke. Persons who report consuming high levels of fruits and vegetables appear to have a lower risk of heart disease and stroke than those who consume few of these nutrients. The evidence from studies using the strongest design (cohort studies), however, have found mixed results for CHD.

In a systematic review of observational studies published through 1995, Ness and Powles examined the relationship between fruit and vegetable consumption and CHD or stroke.^ 25 ^ They included studies that measured dietary intake directly and that examined the association between fruit and vegetable consumption (or a nutritional surrogate) and CHD or stroke incidence.

Almost half (8 of 19) of the cohort or case-control studies examining the relationship between fruit and vegetable consumption and CHD found a protective effect; most studies (6 of 9) examining stroke also found fruit and vegetable consumption protective. The authors did not combine effect estimates because of the heterogeneity of study designs and effect sizes. Inaccuracy and imprecision in measuring fruit and vegetable consumption may have hampered estimating the true effect of fruits and vegetables on cardiovascular events. In addition, separating the effect of fruits and vegetables from the impact of concurrent increases in dietary fiber and reductions in saturated fat and perhaps total calories is difficult.^ 25 ^

Law and Morris performed a similar systematic review of cohort studies published through 1996 that reported at least 50 CHD events;^ 26 ^ 11 studies met their eligibility criteria. They re-analyzed the data from these studies and expressed the results as the relative risk of CHD for persons consuming fruits and vegetables at the 90^th^ percentile compared with those the 10^th^ percentile (about a 4-fold difference in consumption). They also examined several other markers of fruit and vegetable consumption such as potassium intake, fruit or vegetable fiber intake, or vitamin intake levels. The correlation among results was good regardless of how intake was measured. The median effect after adjustment for potential confounders was about a 15% lower risk of CHD events.

More recent cohort studies have found mixed results. Pietinen et al. studied 21,000 men 50 to 69 years of age enrolled in the Alpha Tocopherol, Beta-carotene Cancer Prevention Study.^ 27 ^ Participants with high fruit and vegetable consumption (fourth and fifth quintiles) had relative risks for coronary death 15% to 40% lower than those controls whose consumption fell into the first or second quintiles of consumption over the 6-year study.

Mann et al. studied more than 10,000 British men and women ages 16 to 79 years who had no previous CHD over a mean of 13 years to examine the effect of various dietary elements on CHD death rates and total mortality.^ 28 ^ Dietary patterns were measured using a semi-quantitative food frequency questionnaire administered at baseline. They found no protective effect against CHD death or total mortality among persons consuming large amounts of fruits, green vegetables, carrots, or dietary fiber. Increased consumption of dietary fat and cholesterol were both associated with increased risk of CHD death but not total mortality.

Key et al. examined the effect of different dietary elements within a cohort of 10,000 health-conscious persons in the United Kingdom recruited from health food stores, vegetarian societies, and magazines.^ 29 ^ Dietary assessment involved a brief questionnaire at baseline; a subset of participants underwent a follow-up questionnaire to determine changes in dietary patterns. Outcomes (mean follow-up, 17 years) were tracked through the British National Health System. Mean age of the participants was 46 years; 43% were self-described vegetarians. Persons who reported consuming fresh fruit daily had 20% to 25% lower rates of CHD death and 30% to 40% lower rates of stroke death than those consuming these foods less often than daily. Total mortality was 20% to 25% lower as well. Raw salad consumption was associated with lower risk of CHD death but not stroke death. Eating whole grain bread was associated with a 10% to 15% lower total mortality rate but did not have a significant effect on CHD death or stroke death. Reporting a vegetarian diet was not a significant predictor of decreased CHD mortality.

Joshipura et al. examined the relationship between fruit and vegetable intake and the risk of coronary heart disease using data from the Nurses' Health Study and the Health Professionals Follow-up Study.^ 30 ^ They found, after adjustment for standard cardiovascular risk factors, that subjects in the highest quintile of intake of fruits and vegetables (9 to 10 servings per day) had a relative risk of 0.80 (95% CI, 0.69-0.93) compared to those in the lowest quintile (2 to 3 servings per day). Each difference of 1 serving per day of fruit or vegetable was associated with a relative risk of 0.96 (95% CI, 0.94-0.99). The risk reduction was greater specifically for consumption of leafy green vegetable (RR, 0.77; 95% CI, 0.64-0.93).

#### Effects of Fruits and Vegetables on Blood Pressure

##### Observational evidence

Ascherio et al. examined the relationship between fruit and vegetable consumption and blood pressure in the Nurses' Health Study and found that fruit and vegetable consumption was associated with lower systolic and diastolic pressures.^ 31 ^

##### Dietary intervention trials

A recent large randomized trial (Dietary Approaches to Stop Hypertension [DASH]) examined the effect of a diet high in fruits and vegetables on blood pressure among volunteer subjects over 13 weeks at 4 centers in the United States. By design, a majority of the 412 participants (57%) was African-American; 57% were women; and the mean age was 48 years.^ 32 ^ Patients were given specially prepared meals during the trial; this factor may limit the generalizability of this study with respect changing behavior, but it allowed the investigators to estimate ideal efficacy.

Eligible patients had a baseline systolic blood pressure between 120 and 159 mm Hg and a diastolic blood pressure between 80 and 95 mmHg. Subjects were randomized to a diet high in fresh fruit and vegetables with typical dietary fat (35% total fat), a combination diet high in fresh fruits and vegetables plus low in dietary total and saturated fat (25% total fat), or a control diet for 13 weeks.

Compared to the blood pressures for controls, blood pressure was reduced most among those consuming the combination diet (a 5 mm Hg overall reduction in systolic pressure, 11 mm Hg reduction in hypertensive persons); smaller reductions were achieved for the increased fruit and vegetable/usual fat diet (3 mm Hg overall, 7 mm Hg among hypertensives).^ 32 ^ Two older trials that randomized patients to a vegetarian diet low in saturated fats found similar reductions in systolic blood pressure.^33,34^

#### Effects of Fruits and Vegetables on Lipid levels

Most interventions designed to affect serum lipid levels have focused on reducing the amount of dietary total or saturated fat or increasing fiber consumption. Reducing dietary fat may entail increasing fruit and vegetable consumption, and they have in some cases successfully changed lipid levels. Zino et al. examined the specific effect of increasing fruit and vegetable consumption on lipid levels in an 8-week randomized trial in New Zealand.^ 35 ^ Intervention subjects were asked to increase fruit and vegetable consumption from 3 or fewer servings per day to 8 servings per day but not to change consumption of nuts, oils, or butter. They found that participants were able to increase fruit and vegetable consumption 3-fold but that lipid levels did not change. The effect on the proportion of dietary fat intake was small (reduction from 35% to 32%).^ 35 ^

#### Effects of Fruits and Vegetables on Cancer

A large body of observational evidence suggests that persons who consume higher levels of fruits and vegetables are at lower risk for some forms of cancer, particularly gastrointestinal, lung, and endometrial cancers. Much of this evidence comes from either ecologic studies, which are subject to confounding, or from case-control studies, which may be subject to recall bias. Data from cohort studies, a design thought to be less susceptible to bias, are less suggestive of clear benefit for most types of cancer.^ 36 ^ Two recent cohort studies found little effect of increased fruit and vegetable consumption on the incidence of lung or colorectal cancer.^30,37^

Smith-Warner et al. recently pooled data from 8 large cohort studies that had at least 200 incident cases of breast cancer.^ 38 ^ Persons in the highest quartile of consumption of fruits and vegetables had risks for breast cancer that were only slightly lower than those risks among persons in the lowest quartile (RR, 0.93; 95% CI, 0.86-1.00). These results stand in contrast to those of another systematic review of observational data that identified 14 case-control and 3 cohort studies and found a significant risk reduction associated with higher vegetable consumption (RR, 0.75; 95% CI, 0.66-0.85).^ 39 ^

### Effects of Legumes (Beans, Peas, and Nuts) on CHD

Bazzano and colleagues examined the relationship between consumption of legumes (beans, nuts, and peas) and the risk of CHD, using data from the National Health and Nutrition Examination Survey (NHANES) Epidemiologic Follow-up Study.^ 40 ^ They measured legume consumption using a 3-month food frequency questionnaire and obtained data on CHD events from medical record review and death certificates. Persons consuming higher amounts of legumes had lower rates of CHD events. Compared to those consuming legumes less than once per week, those who consumed 4 or more servings of legumes per week had a relative risk for CHD of 0.78 (95% CI, 0.68-0.90). Adjustment for potential confounders did not affect the magnitude of the estimate importantly (adjusted RR, 0.80; 95% CI, 0.69-0.91).

### Effects of Diets High in Whole Grains and Fiber

Intake of dietary fiber, including whole grains, has been associated with a wide range of positive health outcomes, including lower mortality from CHD and cancer, lower rates of diabetes and obesity, and better gastrointestinal function.^ 41 ^ In some cases, separating the effects of fiber and whole grains from other dietary constituents (e.g., fruits and vegetables, dietary fat) is difficult.

#### Whole Grains and All-cause Mortality

Jacobs et al. used data from the Iowa Women's Health Study to examine the relationship between whole grain consumption and all-cause mortality.^ 42 ^ In this study, women were matched on total grain fiber intake but had varied levels of whole versus refined grains. Persons who consumed predominantly whole grains had a lower risk of mortality compared with those consuming refined grains (adjusted RR, 0.83; 95% CI, 0.73- 0.94). These data suggest that the type of grain fiber may be important to consider when examining diet-health relationships and that whole grains are more protective than refined grains.

#### Whole Grains and CHD

Several studies have examined the relationship between dietary intake of whole grains and risk of CHD. Jacobs and colleagues examined this relationship in the Iowa Women's Health Study, a prospective cohort study, and found that women who reported higher intake of whole grains had lower rates of fatal CHD events than those rarely consuming whole grains (adjusted RR 0.71 for consumption of 1.2 servings per day compared with those consuming 0.2 servings per day).^ 42 ^ More recently, Liu et al. used data from the Nurses' Health Study to examine the effect of whole grains on first CHD events (fatal and nonfatal).^ 43 ^ Whole grain consumption was inversely related to CHD incidence (adjusted RR, 0.75; 95% CI, 0.59-0.95 for highest level of consumption [2.7 servings per day] versus the lowest level [0.13 serving per day]).

#### Whole Grains and Stroke

Liu et al. also examined the relationship between whole grain consumption and risk of ischemic stroke in the Nurses' cohort.^ 43 ^ Higher consumption was protective against stroke as well (adjusted RR, 0.72; 95% CI, 0.53-1.00) for the second lowest quintile [0.43 servings per day] versus the lowest quintile [0.13 servings per day] of consumption).

#### Fiber and CHD

Many observational studies have found lower rates of CHD in those persons who consume large amounts of dietary fiber compared with those who consume little fiber.^41,44^ However, a large trial examining the effect of fiber on CHD events among middle-aged men who had recently had a myocardial infarction found no protective effect from advice to eat more fiber, despite fiber intakes that were twice that of control subjects.^ 45 ^ The relative risk for total mortality among those randomized to fiber was 1.23 (95% CI, 0.95-1.60).

#### Fiber and Lipid Levels

Soluble fiber intake of 3 grams (g) per day (roughly 3 servings of 28 g of oatmeal per day) has been shown to reduce serum cholesterol levels by 2% to 4%, based on data from recent systematic reviews and meta-analyses.^46,47^

#### Fiber and Blood Pressure

The independent relationship between a high fiber diet and reductions in blood pressure has been difficult to study because high fiber diets often contain large amounts of fruit, are high in potassium, and have low levels of sodium. All these factors may also positively influence blood pressure. He and Whelton reviewed studies of the relationship between dietary fiber and blood pressure,^ 48 ^ although they did not describe search methods or eligibility criteria. Persons consuming diets high in fiber were at lower risk for developing hypertension than those consuming lower levels of fiber. Relative risks were 0.76 for women and 0.64 for men when those with the highest consumption (greater than 25 g per day) were compared with those with the lowest (less than 10 to 12 g per day). They also identified 7 randomized trials of fiber supplementation published from 1986 to1992 that had blood pressure reduction as the primary endpoint.^ 48 ^ Fiber supplements (average supplement, 14 g per day) were associated with a 1.6 mm Hg reduction in systolic blood pressure (95% CI, 0.4-2.7) and a 2.0 mm Hg reduction in diastolic blood pressure (95% CI, 1.1-2.9).

#### Fiber and Cancer

A wide range of studies has explored the relationship between dietary fiber intake and cancer. Some studies have detected an inverse association between fiber intake and cancer incidence. This finding has not been consistent, however, especially when higher-quality data from cohort studies are considered alone.^ 41 ^

For breast cancer, a meta-analysis of 12 case-control studies identified a modest decrease in breast cancer (RR, 0.85) with increased dietary fiber.^ 49 ^ Newer studies (both case-control and cohort) have not found such an association.^ 41 ^

Numerous observational studies have examined the relationship between dietary fiber and colorectal cancer; recent reviews have attempted to summarize the data.^41,50^ In general, case-control studies and ecological data support a strong association between dietary fiber and colorectal cancer (odds ratios of 0.50 to 0.65), but cohort studies generally have had mixed results and overall have found only modest decreases in risk (10% to 20%).^ 50 ^ Two recent randomized trials of a high-fiber or fiber-supplemented diet for patients with previous colorectal adenomas did not find any change in the incidence of future adenomas with increased fiber.^51,52^

Data are not sufficient to determine the relationship between fiber intake and the incidence of cancer at other sites. In summary, current evidence is unclear with respect to the relationship between dietary fiber and cancer.

### Effects of Diets High in Fish or Fish Oils on CHD

Marckmann and Gronbaek performed a systematic review of prospective cohort studies examining the relationship between fish consumption and the risk of coronary heart disease death.^ 53 ^ Across 11 studies (a total of 116,764 persons), fish consumption was associated with a decreased risk of CHD death in high-risk but not low-risk populations.

The Diet and Reinfarction Trial (DART) examined the effect of different dietary recommendations on reinfarction and mortality among 2,033 men who had recently had a myocardial infarction.^ 45 ^ Those assigned to eat more fish (or to take a fish oil supplement if they could not tolerate the fish) had a 29% reduction in total mortality over 2 years (95% CI, 7%- 46%). In an older study of a post-infarction population, Singh and colleagues found similar results.^ 54 ^

The GISSI-Prevenzione trial (Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto miocardico) examined the effect of fish oil supplements on the incidence of CHD events in patients who had recently had a nonfatal myocardial infarction.^ 55 ^ Mean lipid levels at entry were 210 mg/dl for total cholesterol, 137 mg/dl for LDL cholesterol, and 41 mg/dl for HDL cholesterol. The risk of the combined endpoint of death, nonfatal myocardial infarction, or stroke was reduced by 10% over a mean follow-up of 3.5 years (95% CI, 1%-18%); the absolute risk reduction was 1.3%, meaning that about 77 people would need to take fish oil supplements for 3.5 years to prevent 1 CHD event. Total mortality was reduced (RRR, 14%; 95% CI, 3%-24%), as were cardiovascular deaths (RRR, 17%; 95% CI, 3%-29%) but not nonfatal myocardial infarction. Numbers needed to treat for 3.5 years were 77 and 91, respectively. No change in lipid levels was noted.

No trial has examined the effect of a diet high in fish among lower-risk patients with no previous history of CHD.

### Effects of Dietary Sodium on Blood Pressure

#### Observational Studies

Numerous ecologic and observational cohort studies have shown that dietary sodium intake and blood pressure are related. In general, the relationship between increasing levels of dietary sodium intake and blood pressure is linear.^ 56 ^ The relationship is confounded somewhat by the effect of other dietary elements, such as dietary potassium, that may be correlated with sodium intake.

#### Interventions

Numerous trials in persons with or without previously diagnosed hypertension have addressed the effect of dietary sodium restriction on blood pressure. Two recent systematic reviews and meta-analyses have summarized this evidence.^57,58^

Midgley and colleagues systematically reviewed the literature from 1966 to 1994.^ 57 ^ Reviewers identified 56 studies that randomized patients to sodium restriction or a control group, measured sodium excretion, and presented results for changes in both systolic and diastolic blood pressure. Patients with hypertension assigned to salt restriction averaged a 95 mmol/day reduction in sodium excretion. After adjustment for confounders, each 100 mmol reduction in daily sodium excretion was associated with a 3.7 mm Hg drop in systolic and a 0.9 mm Hg drop in diastolic blood pressure. For patients without hypertension, the mean decrease in sodium excretion was 125 mmol/day but the mean reduction in blood pressure per 100 mmol/day reduction in sodium excretion was only 1.0 mm Hg for systolic and 0.1 mm Hg for diastolic pressures. Decreases were larger for older patients with hypertension and smaller for free-living normotensive patients. The authors of the review concluded that sodium restriction was potentially useful for persons with hypertension but not for patients with normal blood pressure.

The Cutler team performed a similar systematic review in 1997, also covering literature published from 1966 to 1994.^ 58 ^ They used slightly different entry criteria: studies had to be randomized trials, be free of obvious confounding, use reasonable sodium intake goals, report changes in sodium excretion, and present results for change in either systolic or diastolic blood pressure. Across 32 trials (2,635 subjects), they found slightly larger estimates of effect than had Midgley et al.^ 57 ^ Among hypertensive persons, reductions in systolic and diastolic pressures per 100 mmol reduction in salt excretion were 5.8 and 2.5 mm Hg, respectively. Corresponding figures for normotensive persons were 2.3 and 1.4 mm Hg. They concluded that dietary sodium reduction was valuable, as even the smaller reductions in blood pressure could prevent many events if implemented by the entire population.^ 58 ^

The DASH trial examined the effect of different levels of sodium intake in patients eating a controlled diet.^ 32 ^ Patients were randomized to 1 of 3 levels of sodium intake: control (150 mmol [3.5 grams] of sodium), a 100-mmol sodium diet, or a 60-mmol sodium diet. They followed their initial sodium content for 30 days and then crossed over to the other 2 levels in consecutive 30-day periods. Patients' food was prepared and distributed at the study site; participants ate some meals at the study site but took others away to be consumed at home or work. The outcome of interest was blood pressure, measured at the study site. Sodium restriction reduced blood pressure for both the high fruit, vegetable, and fiber diet group and the control diet group. Participants on the control diet had a 6.7 mm Hg reduction in systolic pressure from high to low sodium, whereas those on the high fruit and vegetable diet had a 3.0 mm Hg drop.

The combined effect of eating a diet high in fresh fruits, vegetables, and fiber and minimizing salt intake reduced blood pressure more than either intervention alone. Low sodium intake had a greater effect in persons with hypertension, African-Americans, and women than it did in patients without hypertension, whites, or men.^ 32 ^

#### Trials of Hypertension Prevention

The Hypertension Prevention Trial, conducted in the mid-1980s, enrolled adults ages 25 to 49 with diastolic blood pressure between 78 and 89 mm Hg and no previous cardiovascular disease.^ 59 ^ Participants were assigned to dietary counseling about sodium restriction (n = 196) or usual care (no counseling, n = 196). Counseling occurred weekly for 10 weeks, then every 2 weeks for a month, then every other month for three years. Blood pressure was assessed at 6 months and at 1-, 2-, and 3-year follow-up by personnel unaware of treatment status.

Urinary sodium excretion was reduced for intervention patients (net reduction: 3.3 mmol per 8 hours at 6-month follow-up and 5.0 mmol per 8 hours at 3-year follow-up). These outcomes suggested that counseling was effective in changing sodium consumption, but blood pressure did not differ between intervention and control groups at either the 6-month or the 3- year follow-up.

In the early 1990s, another hypertension prevention trial was conducted among a similar population of patients.^ 60 ^ Eligibility criteria included diastolic blood pressure between 83 and 89 mm Hg and systolic blood pressure below 140 mm Hg. The goal of dietary counseling was to reduce sodium intake to 80 mmol/day (less than 2 g of sodium). Intervention patients received intensive counseling at 10 weekly group sessions followed by 4 monthly sessions, then 1 to 2 contacts per month for the duration of the trial. Participants kept logs of diet and activity and monitored urinary sodium excretion frequently. Control patients received usual care. Sodium excretion (mean 180 mmol/day at baseline) was reduced by 50 mmol/day for intervention patients and 10mmol/day for controls. Systolic blood pressure was reduced by a net 2.9 mm Hg at 6 months (P < 0.001) and 1.2 mm Hg at 3 years (P = 0.02). Development of hypertension, defined as systolic blood pressure greater than 140 mm Hg or diastolic blood pressure over 90 mm Hg or a new prescription for hypertension medication, was lower for intervention patients (RR = 0.82; P = 0.05).

Thus, intensive dietary counseling to reduce sodium intake among patients with high-normal blood pressure can apparently effectively reduce dietary sodium as measured by urinary sodium excretion. However, it has little effect on mean blood pressure and only a small effect on number of abnormal blood pressure readings or initiation of antihypertensive medication.

The adverse effects of a low sodium diet have not been well studied. Data from systematic reviews of multiple trials have not identified important harms from sodium reduction other than its effect on food palatability, which has not been well investigated.

### Effects of Dietary Potassium on Blood Pressure

#### Observational Studies

Several observational studies have examined the effect on blood pressure of diets high in potassium. They have generally found an inverse relationship between potassium intake and blood pressure. Separating this effect from the impact of other related components of the diet, including fiber, sodium, and the amount of fruits and vegetables, however, has been difficult.^ 61 ^

#### Interventions

Whelton et al. performed a systematic review of the effect of oral potassium supplementation on blood pressure, they identified 33 randomized trials published before July 1995 that involved a total of 2,609 subjects.^ 62 ^ Using a random effects model, they found that supplementation led to mean decreases of 3.1 mm Hg (95% CI, 1.9-4.3) in systolic blood pressure and 2.0 mm Hg in diastolic blood pressure (95% CI, 0.5-3.4). Thus, supplementation with potassium does seem to improve blood pressure and lends support to observational evidence that diets high in potassium-rich foods also improve blood pressure.

### Effects of Dietary Calcium

#### Effect of Dietary Calcium on Osteoporotic Fractures

##### Observational data

Population-based cohort and cross-sectional studies suggest that low calcium intake among young women leads to lower peak bone mass, a risk factor for postmenopausal osteoporosis. Data on the effect of calcium intake among middle-aged women are less clear. Feskanich et al. found that higher intake of dietary calcium was not associated with a lower risk of hip fracture in the Nurses' Health Study cohort of women ages 34 to 59 years.^ 63 ^

Whelton et al. performed a systematic review of 33 observational and interventional studies appearing between 1966 and 1994.^ 62 ^ Their analysis focused on premenopausal adult women and adult men between the ages of 18 and 50 years. The authors examined the strength of the correlation between dietary calcium intake and bone mass and calculated a summary correlation coefficient (r = 0.13; 95% CI, 0.09-0.16) and a partial correlation coefficient (partial r = 0.08; 95% CI, 0.05-0.12) that were statistically significant. They also concluded that a difference of 1,000 mg per day of calcium intake (in the form of supplements) would prevent the additional loss of 1% of bone at all bone sites examined except the ulna.

Cumming examined the effect of calcium intake on osteoporotic fractures in postmenopausal women.^ 64 ^ They performed a meta-analysis of 16 observational studies of dietary calcium that examined incidence of hip fracture. Pooling data from these 16 studies, the authors found an odds ratio for fracture of 0.88 (95% CI, 0.80-0.97) for 1,000 mg or less of higher intake of calcium. They concluded that modestly increased calcium intake among postmenopausal women appears to be associated with a small reduction in risk of fracture.

##### Intervention studies

Multiple randomized trials have examined the effect of increased calcium on bone mass or fracture risk. Heaney performed a systematic review of all studies relating calcium intake to bone health from 1977 to 1999 and identified 39 RCTs of the effect of calcium supplementation (33 with calcium supplements alone and 6 that used dietary sources alone or in addition to calcium).^ 65 ^ Of the 39 trials, 37 showed a positive effect on bone mass; 5 showed reduced fractures (all among the elderly). The concurrent use of vitamin D in the intervention studies makes it difficult to estimate the effect of increased calcium alone.

##### Adverse effects

The potential adverse effects of recommending high calcium intake include (rarely) milk alkali syndrome and increased occurrence of kidney stones in a susceptible host. When dairy products are the source of calcium, other potential adverse effects include exacerbation of lactose intolerance or an increase in dietary fat intake if low-fat dairy products are not used. In men, prostate cancer risk may be increased with higher intake of dairy products, an effect that may be mediated through reduced circulating 1,25 vitamin D levels.^ 66 ^ Available data are insufficient to estimate the risk of these complications.

### Other Dietary Elements

Other USPSTF reviews will deal with other potentially important dietary elements such as dietary iron and folate. Other vitamins are examined in forthcoming work on vitamin supplements, and infant nutrition will be covered by the review of counseling about breastfeeding.

### Special Populations

#### Pregnant Women

Nutritional status is especially important during pregnancy. Low birth weight and neonatal mortality are more common in pregnant women with very poor nutritional status^67,68^ and in those who fail to gain adequate weight during pregnancy.^69,70^ Factors other than nutrient intake per se, however, may account for these outcomes. Prenatal programs providing nutritional support for pregnant women have been associated with improved perinatal outcomes.

Pregnancy brings increased requirements for energy and specific nutrients, such as protein, calcium, folic acid, and iron.^70-72^ Folate supplementation, which prevents neural tube defects, is being considered in the specific USPSTF review for that subject. Oral iron supplements may be beneficial in preventing iron deficiency anemia in pregnancy. They are often prescribed routinely as part of prenatal health care, along with vitamin supplementation. The evidence for iron supplementation will be covered in the separate review on screening for iron deficiency.

#### Older Adults

The elderly also have special nutritional issues. Undernutrition, common among the elderly, is associated with adverse health outcomes. Because clinical recognition of protein-calorie malnutrition, especially when manifested by clinically subtle findings, is often delayed among older adults, attempts have been made to screen older adults routinely (see Key Question No. 2, below). The effectiveness of screening and counseling persons at risk has not been well documented, but a systematic review about the use of nutritional supplements to treat undernutrition is considered in Key Question No. 7 (below).

### Summary of the Evidence Regarding the Relationship Between Diet and Health Outcomes

Based on our review of the evidence relating various dietary elements with important health outcomes, we found reasonably good evidence that diets low in saturated and trans-unsaturated fats, and high in fruits, vegetables, fiber, and fish, are associated with better health outcomes. Diets high in calcium for women, and diets low in sodium for persons with hypertension or at high risk for developing it, are also associated with better surrogate health measures (bone density and blood pressure, respectively) that are correlated with improved health.

## Key Question No. 2: Valid, Feasible Tools for Assessment of Dietary Risk and Patterns

We identified 18 articles related to dietary assessments designed to determine level of risk, to guide counseling, or both. We also identified assessment questions that can inform counseling by assessing mediators to dietary change, such as stage of readiness to change^73-90^ (see Table 1).

Dietary assessment tools fall into 3 broad categories. First are age-specific general assessment tools, where attention is directed at issues relating to infants and toddlers, older children, adults, and the elderly. For children and adults, the particular concerns may involve assessing dietary behaviors most strongly identified with risk for chronic disease; for the elderly, unintentional weight loss associated with chronic illness, social isolation, or other factors linked with the aging process are of particular concern. The second category of assessments involves those that identify factors that foster or mediate dietary behavioral interventions. The third category includes assessment instruments to identify the presence of hunger and food insecurity.

### Assessment of Eating Patterns and Nutritional Factors in Selected Age Groups

#### Infant and Toddler Growth and Development

Comprehensive nutritional assessment includes multiple anthropometric and biochemical parameters in addition to estimations of dietary intake patterns. Most significant nutritional problems of infants and toddlers are manifested by a failure to follow predicted growth curves based on height for age and weight for stature. Therefore, growth charts are used to assess nutritional status and general health and well-being of infants, children, and adolescents. In May 2000, revised growth charts for the United States were released, representing the first major revision since the 1977 growth charts from the National Center for Health Statistics.^ 91 ^ These revisions corrected many previous concerns with the existing charts, centered on the fact that the prior infant charts were developed from data based on a single longitudinal study of primarily formula-fed, white, middle-class infants from a limited geographic region.

Findings of small stature or low weight for height require further evaluation to assess organic problems versus inadequate dietary intake. Excess weight for height is most likely related to either excess calorie intake or inadequate energy expenditure. A review of feeding practices or a 3-day record of all dietary intake can help identify major dietary problems leading to inadequate or excessive intake, but no brief, validated assessment tool is currently available for this purpose.

The revised US growth charts include, for the first time, BMI-for-age charts, and all charts for children and adolescents now extend to 20 years of age. These updated instruments may improve detection and monitoring of pediatric obesity (which is expected to be covered in a separate USPSTF report). Dietary assessment for overweight children above the age of 2 years should be conducted using tools available to assess dietary behavior associated with chronic disease outcomes.

A few brief diet and health screeners have been developed and evaluated as the first part of a 2-stage screening process to detect iron deficiency anemia in infants and toddlers. These measures are very sensitive (95%), but specificity is quite low (15% to 30%).^92-94^

#### Children

Assessing dietary intake of children becomes more difficult as they age. Parents have less control over intake and are less able to provide a complete and accurate picture of their children's food intake. In a review of dietary assessment instruments, Rockett and Colditz concluded that for children ages 9 years and older, food frequency questionnaires administered directly to children can provide a reasonably accurate picture of their usual patterns.^ 95 ^ Correlations with criterion measures on a number of instruments range from about 0.46 to about 0.79, except for sodium intake for which the correlation coefficient was much lower (0.21). Although food frequency assessments are generally the most efficient way to estimate usual dietary intake, the majority of the instruments reviewed were quite lengthy and designed more for epidemiologic research than for rapid clinical assessment.

For children below the age of 9, dietary assessment relies on joint input from parents and children and can be supplemented by written or tape-recorded methods.^96,97^ We identified no brief, validated diet screeners for this age group.

#### Adults

A recent review of practical nutrition assessment in primary care settings by Calfas et al. included brief instruments assessing primarily fat (various types) and, to a lesser extent, fruit and vegetable intake as well as other nutrients.^ 98 ^ Table 1 provides key descriptive information about various validated instruments and others identified from the literature. Most of these instruments can be self-administered, are easily scored, have fewer than 40 items, and take 10 minutes or less to administer. In contrast, dietary assessment tools designed for epidemiologic research generally require multiple 24-hour recalls, 7 days of food records, or food-frequency instruments with 60 to 100 items requiring 45 minutes or longer to administer.

Owing to the limited number of items in the shorter assessments, only selected nutrients found in a limited selection of foods can be assessed. These brief measures are usually compared against criterion measures using multiple 24-hour food recalls, records, or longer food-frequency instruments. Correlations with the criterion variable range from 0.37 to 0.60, with higher correlations for single nutrients such as calcium (0.79).^ 98 ^

In a recent study not included in the Calfas team's review, Little et al. validated 9 brief diet screener instruments commonly used in the United Kingdom against a 7-day weighted dietary record.^ 99 ^ Having found reasonable correlations in a range similar to that for the instruments in Table 1, they concluded that brief assessment instruments perform well enough for clinical work. However, underreporting of absolute calorie intake was common, particularly among obese patients (60% of those with BMI >30).

#### Nutritional Assessment in the Elderly

Poor nutrition in the elderly is common: more than 25% of independent-living elderly and more than 80% of home-bound elderly have moderate to high risk of malnutrition and poor nutrition. This problem has been associated with increased mortality, more visits to physicians and hospital admissions, higher morbidity, higher costs, and longer lengths of hospital stay.^ 100 ^ Risk factors for poor nutrition in older adults include low income, social isolation, loneliness, concurrent illness, compromised functional status, and polypharmacy.^ 101 ^ The challenge to primary care physicians is to identify elderly patients who would benefit from dietary intervention without subjecting all elderly persons to a battery of costly and time-consuming anthropometric, dietary, and laboratory tests.^ 102 ^ However, few providers (10%) routinely assess patients for undernutrition.^ 103 ^

Several brief screening instruments have been developed to assess nutritional status in the elderly. Although many are designed for long-term-care patients,^ 104 ^ some have been validated in community-living elderly and are intended for use by the primary care provider. Three extensively used and tested instruments are described here.

The Nutrition Risk Index (NRI) was derived initially from questions used in the first National Health and Nutrition Examination Survey (NHANES I). ^ 105 ^ Validity has been tested by the ability of the NRI to predict use of health services and correlations with a variety of anthropometric, laboratory, and clinical markers of nutritional status.

The DETERMINE instrument was developed as part of the Nutrition Screening Initiative - a 5-year campaign begun in 1990 to promote nutrition screening and better nutritional care among the elderly in the United States in response to the 1988 US Surgeon General's Workshop on Health Promotion and Aging.^ 106 ^ This instrument has been validated against measures of depressive symptoms and functional disability.^ 104 ^

Probably the most extensively validated instrument is the Mini Nutritional Assessment (MNA).^ 102 ^ Validation criteria include nutritional status determined by physicians using standard anthropometric, clinical, and dietary measures mortality, and hospital cost.

These instruments all consist of 18 or fewer yes/no checklist items and involve a weighted score. Nutrition factors common to all 3 instruments include unintended weight loss, problems with chewing and swallowing, polypharmacy, and concurrent illness. The DETERMINE checklist and the MNA also include food access, social isolation, mobility, poverty, and intake of fruits, vegetables, and protein sources. The MNA includes questions to assess psychological problems, dementia, independent living status, and a self-assessment of nutrition problems and relative health status.^101,102,105^

### Mediators of Dietary Change

In addition to assessing usual dietary behavior, providers are also encouraged to assess psychosocial factors that may mediate the effects of a counseling intervention. Such instruments have been developed primarily as evaluation measures in nutrition education intervention research.^ 107 ^ A mediator frequently used to guide counseling for a variety of health-related behaviors is Stage of Readiness to Change.^ 108 ^ This measure is used to determine the degree to which an individual is ready to begin counseling and how far he or she has advanced in the behavior change process. Several relatively brief and validated instruments assess stage of change for dietary fat intake; they can be implemented in the clinical setting.^109-112^

Table 2 lists additional mediating factors. These mediators have all been associated with success or lack of success in counseling interventions to promote dietary change.^ 113 ^ Whitlock et al., in a report to the USPSTF, discuss mediators of behavioral change in greater detail.^ 1 ^

Table 2. Potential mediators of dietary change

Mediators

- Knowledge of healthful food options
- Social support (availability of family or friends to encourage and assist with lifestyle change)
- Barriers to change (stress-related eating, limited resources to buy nutritious foods)
- Motivators of change (a desire to lose weight, reduce risk of chronic disease, feel better)
- Environmental influences on food choice (accessibility of both healthful and unhealthful food choices in the home or workplace)

### Food Insecurity and Hunger

Food insecurity and hunger is often overlooked as a nutrition concern. Food insecurity exists "whenever the availability of nutritionally adequate and safe foods or the ability to acquire acceptable foods in socially acceptable ways is limited or uncertain" (p.1560).^ 114 ^ In 1995, the Current Population Survey (CPS) of the US Census Bureau documented that approximately 12% of US households are "food insecure"; of these, 28% showed evidence of moderate hunger and 7% indicated severe hunger.^115,116^ Extensive work had been done to develop and validate an 18-item assessment instrument for food insecurity in a nationally representative sample of nearly 45,000 households as part of the Food Security Measurement Project.^ 115 ^

A subset of 6 questions has shown acceptable accuracy and is more feasible for use in primary care than the original (longer) version.^ 76 ^ Sample questions from this assessment include: "In the last 12 months, did you ever eat less that you felt you should because there wasn't enough money to buy food?" and "In the last 12 months, were you ever hungry but didn't eat because you couldn't afford enough food?" Patients identified as food insecure are likely to need referral to social services or other forms of assistance before they would be ready to attempt dietary changes to reduce chronic disease risk.

## Key Question No. 3: Adverse Effects of Dietary Assessment

We did not identify any studies that document adverse effects of dietary assessment alone. Under Key Question 5, we discuss possible adverse effects of dietary counseling interventions.

## Key Question No. 4: Efficacy of Primary Care Counseling and Dietary Behavior Change Interventions

### Impact of Dietary Counseling

#### Overview

From 325 abstracts of articles, we identified 74 articles examining the effect of counseling on dietary behavior (Figure 2). We excluded 41 articles (see Table 3) from our analysis because of methodological and reporting problems, such as lack of a true control group, lack of pre- and post-intervention measures, or retention rates below 50%. We retained 33 articles - representing 29 unduplicated studies - that met our eligibility criteria. Of these 29 studies, 12 examined more than 1 nutrient or food group: dietary fat, 25 studies; fruit and vegetable intake, 11; and dietary fiber, 7. Based on randomized design, high retention rates, and use of appropriate outcome measures, we considered the included studies to be of good quality or fair quality (in the case of 1 study that had a higher and unequal loss to follow-up^ 117 ^).

Table 3. Articles excluded for review of counseling interventions, by author and reason for exclusion

Author, Year | Reason for Exclusion
Aubin et al., 1998^ 184 ^ | No control group
Bakx et al., 1997^ 185 ^ | 17 year follow-up of a one-time intervention in 1977
Barratt et al., 1994^ 186 ^ | Nonclinical intervention (worksite)
Brannon et al., 1997^ 187 ^ | No control group
Burr et al., 1989^ 45 ^ | Post-myocardial infarction subjects
Caggiula et al., 1996^ 188 ^ | No diet outcomes
Calfas et al., 2000^ 98 ^ | No true control group; comparable diet outcomes not presented
Crouch et al., 1986^ 189 ^ | No diet outcomes
DeBusk et al., 1994^ 190 ^ | Post-myocardial infarction subjects
de Lorgeril et al., 1994^ 191 ^ | No baseline measures taken of control group; post-myocardial infarction subjects
Dyson et al., 1997^ 192 ^ | No control group
Ershoff et al., 1983^ 193 ^ | No diet outcomes
Family Heart Study Group, 1994^ 194 ^ | No diet outcomes
Fletcher, 1987^ 195 ^ | Post-myocardial infarction subjects
Ford and Sciamanna, 1997^ 144 ^ | Not an intervention (editorial)
Foreyt et al., 1979^ 196 ^ | No control group; no diet outcomes
George et al., 1993^ 197 ^ | No diet outcomes
Gosselin et al., 1996^ 198 ^ | No diet outcomes
Heller et al., 1989^ 199 ^ | No diet outcomes
Henkin, et al. 2000^ 200 ^ | No diet outcomes
Howard-Pitney et al., 1997^ 201 ^ | Nonclinical intervention
Kuehl et al., 1993^ 202 ^ | No control group
Luepker et al., 1978^ 203 ^ | No diet outcomes
Lytle et al., 1996^ 204 ^ | Nonclinical intervention
Miettinen et al., 1985^ 205 ^ | No diet outcomes
MRFIT Investigators, 1982^ 206 ^ | No diet outcomes
Naglak et al., 1998^ 207 ^ | No control group
Neil et al., 1995^ 208 ^ | No diet outcomes
Neyses et al., 1985^ 209 ^ | Cannot calculate difference in delta; baseline and follow-up data not reported and nonsignificant changes
Nikolaus et al., 1991^ 210 ^ | Three week inpatient metabolic ward study
Ornish 1998^ 211 ^ | Control group information not available
OXCHECK Study Group 1994^ 212 ^ OXCHECK Study Group 1995^ 213 ^ | No control group
Pritchard et al., 1999^ 214 ^ | No diet outcomes, no reference for diet outcomes
Ridgeway et al., 1999^ 215 ^ | No diet outcomes
Shannon et al., 1994^ 153 ^ | Two very different intervention groups; 2 control groups ("at risk" and "not at risk")
Smith et al., 1976^ 216 ^ | No diet outcomes
Tershakovec et al., 1998^ 217 ^ | Two very different intervention groups; 2 control groups ("at risk" & "not at risk")
Tomson et al., 1995^ 218 ^ | No diet outcomes
Waber et al., 1981^ 219 ^ | No diet outcomes
Winkleby et al., 1997^ 220 ^ | Nonclinical intervention

#### Tables Reporting Study Design, Intervention Characteristics, Outcomes, Effect Sizes, and Other Information

##### Tables 4-6 on study design and outcomes

Three tables (found at the end of this chapter) present detailed information on the 29 studies that examine the impact of dietary counseling in the primary care setting. Specifically, Table 4 presents information on counseling to reduce dietary fat; Table 5, counseling to increase intake of fruits or vegetables; and Table 6, counseling to increase intake of fiber.

Table 4. Studies of counseling to reduce dietary fat

Author Year | Sample Population | Level of Risk | Max Follow-up | Baseline Patient Numbers | Retention Rate | Setting | Intervention and Control Group Counseling Provider and Resources | Intensity | External Validity | Outcome* | Baseline Values | Duration of Follow-up | Final Follow-up Values | Change from Baseline to Final Follow-up | Net Difference in Change ^†^ or Difference at Final Follow-up | P-value | Calculated Relative Risk Reduction ^‡^ | Calculated Difference in Deltas | Effect Size ^\|\|^
Beresford et al., 1992^ 130 ^ | Adult men and women in North Carolina, USA; 35% black | Avg/Low | 3 mo | Intv: 120 Cont: 122 | 79% | Primary care providers | Intv: RN on-site provided 5 min intro to self-help materials with phone F/U 10 d later Cont: no intervention | Low | High | Grams of total fat | Intv: 66g Cont: 67g | 3 mo | NR | NR | 3.8 g | NR | NA | NA | Small
Beresford et al., 1997^ 131 ^ | Adult men and women in family practice clinics, USA | Avg/Low | 12 mo | Intv: 1,010 Cont: 1,111 | 86% | Primary care providers | Intv: trained MD-delivered 3 min intro to self-help booklet; reminder letter from MD Cont: NR | Low | High | % calories as total fat | Intv: 37.6% Cont: 37.5% | 12 mo | NR | Intv: −1.5% Cont: −0.3% | 1.2% | P < 0.01 | 0.04 | NA | Small
Campbell et al., 1998^ 124 ^ | Adult men and women w/ diagnosis of CVD in general practice Scotland | High | 12 mo | Intv: 673 Cont: 670 | 88% | Primary care providers | Intv: health visitor - run or RN-run clinics (fit into regular daily routine of caring for all patients on practice list) x 1yr: ROS, review medications, assess behavior, negotiate behavior change; pts recommended to attend every 2-6 months Cont: NR | High | High | % subjects eating a low-fat diet per DINE score <30 | Intv: 49.0% Cont: 48.6% | 12 mo | Intv: 56.5% Cont: 48.6% | Intv: 7.5% Cont: 0.0% | 7.5% | P = 0.009 | 0.15 | −15.3% | Medium
Campbell et al., 1994^ 123 ^ Tailored msg vs. control | Adult men and women of family practices: 2 urban and 2 rural in North Carolina, USA | Avg/Low | 4 mo | Intv: NR Cont: NR | 82% | Mailings and computer-generated messages | Intv: Self-administered surveys in office delivered by staff; tailored messages mailed home Cont: self-administered surveys only; no messages | Low | Medium | Grams of saturated fat | Intv: 18.7 g Cont: 16.3g | 4 mo | Intv: 13.9 g Cont: 15.8 g | Intv: −4.8 g Cont: −0.5 g | 4.3 g | P = 0.036 | 0.29 | −22.6% | Medium
Campbell et al., 1994^ 123 ^ Tailored msg vs. control | Adult men and women of family practices: 2 urban and 2 rural in North Carolina, USA | Avg/Low | 4 mo | Intv: NR Cont: NR | 82% | Mailings and computer-generated messages | Intv: Self-administered surveys in office delivered by staff; tailored messages mailed home Cont: self-administered surveys only; no messages | Low | Medium | Grams of total fat | Intv: 45.6 g Cont: 41.1g | 4 mo | Intv: 35.3 g Cont: 39.8 g | Intv: −10.3 g Cont: −1.3 g | 9 g | P = 0.033 | 0.25 | −19.4% | Medium
Nontailored msg vs. control | Adult men and women of family practices: 2 urban and 2 rural in North Carolina, USA | Avg/Low | 4 mo | Intv: NR Cont: NR | 82% | Mailings and computer-generated messages | Intv: Self-administered surveys in office delivered by staff; nontailored messages mailed home Cont: self-administered surveys only; no messages | Low | High | Grams of saturated fat | Intv: 16.1 g Cont: 16.3g | 4 mo | Intv: 14.4 g Cont: 15.8 g | Intv: −1.7 g Cont: −0.5 g | 1.2 g | P = 0.110 | 0.10 | −7.5% | Small
Nontailored msg vs. control | Adult men and women of family practices: 2 urban and 2 rural in North Carolina, USA | Avg/Low | 4 mo | Intv: NR Cont: NR | 82% | Mailings and computer-generated messages | Intv: Self-administered surveys in office delivered by staff; nontailored messages mailed home Cont: self-administered surveys only; no messages | Low | High | Grams of total fat | Intv: 40.4 g Cont: 41.1g | 4 mo | Intv: 36.8 g Cont: 39.8 g | Intv: −3.6 g Cont: −1.3 g | 2.3 g | P = 0 .157 | 0.09 | −5.8% | Small
Coates et al., 1999^ 118 ^ | Post-menopausal women in research clinics of Women's Health Trial: 28% black, 16% Hispanic | Moderate | 18 mo | Intv: 1324 Cont: 883 | 75-85% | Research clinic | Intv: RD-delivered group sessions wkly for 6wks, biweekly for 6 wks, monthly for 9 mo Cont: given Dietary Guidelines for Americans; no counseling | High | Low | % calories as saturated fat | Intv: 13.2% Cont:12.9% | 18 mo | NR | Intv: −4.4% Cont: −0.9% | 3.5% | NR | 0.34 | NA | Large
Coates et al., 1999^ 118 ^ | Post-menopausal women in research clinics of Women's Health Trial: 28% black, 16% Hispanic | Moderate | 18 mo | Intv: 1324 Cont: 883 | 75-85% | Research clinic | Intv: RD-delivered group sessions wkly for 6wks, biweekly for 6 wks, monthly for 9 mo Cont: given Dietary Guidelines for Americans; no counseling | High | Low | % calories as total fat | Intv: 39.7% Cont: 39.0% | 18 mo | NR | Intv: −14.2% Cont: −2.5% | 11.6 % | NR | 0.36 | NA | Large
Cupples and McKnight 1994^ 133 ^ | Adult men and women with angina x 6 mo at home or in a health care center or surgery center Belfast, Northern Ireland | High | 24 mo | Intv: 342 Cont: 346 | Intv; 93% Cont: 87% | Primary care clinic referral | Intv: Trained health visitor delivered diet assessment and health education every 4 months at home or health center or surgery center Cont: no intervention | Medium | Medium | % of subjects with improved intake of saturated fat | NR | 24 mo | NR | Intv: 10.4% Cont: 8.3% | 2.1% | P = 0.013 | NA | NA | Small
Delichatsios, Friedman et al., 2001^ 125 ^ | Adult men and women in a large multisite, multispecialty group practice -- Harvard Vanguard Medical Associates in Massa-chusetts, USA; 72% women, 45% white, 45% black | Avg/Low | 6 mo | NR | 50% | Mailings and computer-generated messages | Intv: weekly diet-related educational feedback, advice, and behavioral counseling for 5-7 minutes by a totally automated, telephone-linked computer-based voice communication system Cont: weekly physical activity-related educational feedback, advice, and behavioral counseling for 5-7 minutes by a totally automated, telephone-linked computer-based voice communication system | Medium | Medium | % calories as saturated fat | Intv: 10.1% Cont: 10.3% | 6 mo | Intv: 8.8% Cont: 10.5% | Intv: −1.3% Cont: +0.2% | 1.5% | P < 0.05 | 0.13 | 14.8% | Medium
Delichatsios, Hunt et al., 2001^ 134 ^ | Adult men and women patients from 6 group HMO practices in the primary care research network of Harvard Pilgrim HealthCare, Massa-chusetts, USA | Avg/Low | 3 mo | Intv: 230 Cont: 274 | Intv: 85% Cont: 92% | Mailings and computer-generated messages | Intv: mailed personalized dietary recommendations and 2 educational booklets; endorsement by trained (1 hour) MD or NP; 2 motivational phone counseling sessions by trained MPH student telephone counselors. RD consultation if needed. Cont: NR | Medium | Medium | % calories as saturated fat | Intv: 10.6% Cont: 10.3% | 3 mo | Intv: 9% Cont: 9.7% | Intv: −1.6% Cont: −0.6% | 1% | NR | 0.15 | 9.3% | Small
Heller et al., 1994^ 119 ^ Self or MD intervention vs. control | Siblings and offspring of subjects w/ hx/o MI, New South Wales, Australia | Moderate | 6 mo | Self Intv: 109 MDIntv: 120 Cont: 113 | 69% | Mailings and computer-generated messages | Self Intv: 4 mail-outs of self-help nutritional advice for 2-4 wks | Medium | Medium | Grams of total fat | NR | 6 mo | NR | Intv: −29.3 g Cont:+10.2g | 39.5 g | P < 0.001 | NA | NA | Large
Heller et al., 1994^ 119 ^ Self or MD intervention vs. control | Siblings and offspring of subjects w/ hx/o MI, New South Wales, Australia | Moderate | 6 mo | Self Intv: 109 MDIntv: 120 Cont: 113 | 69% | Mailings and computer-generated messages | MD Intv: Mailed advice to visit subjects' own general practitioner; letter and form for MD or | Low | Medium | Grams of total fat | NR | 6 mo | NR | Intv: +1.4 g Cont: +10.2 g | 8.8 g | NS | NA | NA | Small
Heller et al., 1994^ 119 ^ Self or MD intervention vs. control | Siblings and offspring of subjects w/ hx/o MI, New South Wales, Australia | Moderate | 6 mo | Self Intv: 109 MDIntv: 120 Cont: 113 | 69% | Mailings and computer-generated messages | Cont: no intervention | Low | Medium | Grams of total fat | NR | 6 mo | NR | Intv: +1.4 g Cont: +10.2 g | 8.8 g | NS | NA | NA | Small
Henderson et al., 1990;^ 141 ^ Insull et al., 1990;^ 142 ^ Kristal et al., 1992;^ 143 ^ White et al, 1992^ 144 ^ | Adult women 45-69 yrs at increased risk of breast cancer participating in Women's Health Trial in Ohio, Texas, Washington, USA | Moderate | 30-37 mo | Intv: 448 Cont: 457 | 86% | Research clinic: 3 clinical research centers | Intv: RD delivered 8 weekly group counseling meetings, followed by 4 biweekly meetings, then 20 monthly meetings Cont: no intervention | High | Low | % calories as saturated fat | Intv: 13.8% Cont: 13.6% | 24mo | Intv: 7.2% Cont: 12.3% | Intv: −6.6% Cont: −1.3% | 5.3 % | P < 0.001 | 0.49 | −38.3% | Large
Henderson et al., 1990;^ 141 ^ Insull et al., 1990;^ 142 ^ Kristal et al., 1992;^ 143 ^ White et al, 1992^ 144 ^ | Adult women 45-69 yrs at increased risk of breast cancer participating in Women's Health Trial in Ohio, Texas, Washington, USA | Moderate | 30-37 mo | Intv: 448 Cont: 457 | 86% | Research clinic: 3 clinical research centers | Intv: RD delivered 8 weekly group counseling meetings, followed by 4 biweekly meetings, then 20 monthly meetings Cont: no intervention | High | Low | % calories as total fat | Intv: 39.1% Cont: 38.9% | 24mo | Intv: 22.6% Cont: 36.8% | Intv: −16.5% Cont: −2.1% | 14.4 % | P < 0.0001 | 0.42 | −36.8% | Large
Henderson et al., 1990;^ 141 ^ Insull et al., 1990;^ 142 ^ Kristal et al., 1992;^ 143 ^ White et al, 1992^ 144 ^ | Adult women 45-69 yrs at increased risk of breast cancer participating in Women's Health Trial in Ohio, Texas, Washington, USA | Moderate | 30-37 mo | Intv: 448 Cont: 457 | 86% | Research clinic: 3 clinical research centers | Intv: RD delivered 8 weekly group counseling meetings, followed by 4 biweekly meetings, then 20 monthly meetings Cont: no intervention | High | Low | % calories as total fat | Intv: 39.9% Cont: 38.5% | 30 - 37 mo | Intv: 26.5% Cont: 32.4% | Intv: −13.4% Cont: −6.1% | 7.3% | P = 0.001 | 0.35 | −17.7% | Medium
Hjermann et al., 1981^ 12 ^ | Adult men at increased risk for CHD in a hospital medical outpatient clinic Oslo, Norway | Moderate -High | 5 yr | Intv: 604 Cont: 628 | 96% | Primary care clinic referral | Intv: MD delivered on-site 10-15 min of info re: CHD risk factors and RD delivered on-site diet assessment and advice; MD F/U Cont: short annual clinical re-examination | Medium | Low | % calories as saturated fat | NR | 4 yrs | Intv: 3.3% Cont: 7.1% | NR | 3.8% | P < 0.01 | NA | NA | Medium
Hjermann et al., 1981^ 12 ^ | Adult men at increased risk for CHD in a hospital medical outpatient clinic Oslo, Norway | Moderate -High | 5 yr | Intv: 604 Cont: 628 | 96% | Primary care clinic referral | Intv: MD delivered on-site 10-15 min of info re: CHD risk factors and RD delivered on-site diet assessment and advice; MD F/U Cont: short annual clinical re-examination | Medium | Low | % calories as total fat | NR | 4 yrs | Intv: 11.2% Cont: 17.0% | NR | 5.8% | P < 0.01 | NA | NA | Medium
Hunt et al., 1976^ 135 ^ | Low income pregnant women of Mexican descent in a prenatal clinic Los Angeles County, California, USA | Avg/Low | 35^th^ week | Intv: 171 Cont: 173 | 81% | Primary care clinic referral | Intv: Spanish-speaking RD delivered nutrition ed classes Cont: usual care | Low | Medium | % calories as total fat | Intv: 35.1% Cont: 34.1% | 35^th^ week of preg-nancy | Intv: 33.5% Cont: 34.9% | Intv: −1.6% Cont: +0.8 | 2.4% | NS | 0.05 | −2.0% | Small
Keyserling et al., 1997^ 126 ^ | Adult men and women, low income w/hypercholesterolemia in community and rural health centers North Carolina, USA | Moderate | 24 mo | Intv: 184 Cont: 188 | 95% | Primary care providers | Intv: On-site MD (trained for intv in 1.5 hr) delivered diet assess and 3 sessions of 5-10 min cnslg; followed up by referral to on-site (if available) or off-site RD if persistent hypercholesterolemia Cont: usual care | Medium | High | Dietary risk assessment score (scale: 0 to 98) | Intv: 22.0 Cont: 22.0 | 12 mo | NR | Intv: −5.3 Cont: −2.0 | 3.3% | P < 0.001 | 0.24 | NA | Medium
Knutsen and Knutsen, 1991^ 127 ^ | Adult men at increased risk for CVD and their families Tromso, Norway | Moderate | 6 yr | M: 1373 F: 1143 C: 2838 | M: 77% F: 82% C: 39% | Primary care clinic referral | Intv: MD and RD each made 1 home visit for CHD risk factor diet assessment and counseling Cont: NR | Medium | Low | % of subjects using butter for cooking | NR | 6 yrs | Intv: M: 20% F: 20% C: 25% Cont: M: 36% F: 36% C: 35% | NR | M: 16% F: 16% C: 10% | NR | NA | NA | Medium
Kristal et al., 2000^ 132 ^ | Adult men and women enrollees of Group Health Cooperative of Puget Sound HMO, Washington, USA | Avg/Low | 12 mo | Intv: 729 Cont: 730 | 86.5% | Mailings and computer-generated messages | Intv: self-help materials, dietary analysis with behavioral feedback, and semi-monthly newsletters mailed home; trained health educator delivered one motivational phone call Cont: usual care - no intervention | Medium | Medium | Fat score: 1 to 4 fat 1 = low fat 4 = high fat | Intv: 2.29 Cont: 2.30 | 12 mo | Intv: 2.20 Cont: 2.3 | Intv: −0.09 Cont: 0 | 0.09% | P < 0.001 | 0.04 | 4% | Small
Lee-Han et al., 1988^ 120 ^ | Adult women > 30 yrs with breast dysplasia enrolled in Breast Dysplasia Intervention Trial in Toronto, Canada | High | 12 mo | Intv: 37 Cont: 33 | 81% | Research clinic | Intv: RD provided advice and education about reducing dietary fat Cont: general advice about maintaining a healthy diet according to Canada's Food Guide; not counseled to change diet composition | Medium | Low | % calories as saturated fat | Intv: 14.1% Cont: 13.9% | 12 mo | Intv: 9.5% Cont: 14.0% | Intv: −4.6% Cont: +0.1% | 4.7% | NR | 0.33 | −33.2% | Large
Lee-Han et al., 1988^ 120 ^ | Adult women > 30 yrs with breast dysplasia enrolled in Breast Dysplasia Intervention Trial in Toronto, Canada | High | 12 mo | Intv: 37 Cont: 33 | 81% | Research clinic | Intv: RD provided advice and education about reducing dietary fat Cont: general advice about maintaining a healthy diet according to Canada's Food Guide; not counseled to change diet composition | Medium | Low | % calories as total fat | Intv: 36.4% Cont: 35.7% | 12 mo | Intv: 25.8% Cont: 35.8% | Intv: −10.5% Cont: +0.2% | 11.7% | P < 0.001 | 0.29 | −29.5% | Large
Lindholm et al., 1995^ 128 ^ | Adult men and women at increased risk for CHD in 32 county health centers Lund, Sweden | Moderate | 18 mo | Intv: 339 Cont: 342 | Intv: 92% Cont: 95% | Primary care clinic referral | Intv: usual health care advice from MD (see Cont) plus trained MD or RN delivered 6 group health care advice sessions which discussed 6 separate videos about 6 risk factors for heart disease Cont: usual health care advice from MD to reduce dietary fat, reduce weight if necessary, to stop smoking; pamphlet to reinforce instructions | High | Medium | Grams of total fat | NR | 18 mo | NR | NR | 14.6 g | P < 0.001 | NA | NA | Medium
Masley et al., 2001^ 140 ^ | Adult men and women with a diagnosis of CAD from 4 community outpatient clinics from Group Health Cooperative in Washington, USA | High | 12 mo | Intv: 49 Cont: 48 | 81% | Research clinic | Intv: RN taught 14 90-minute group classes: weekly for 1 month then monthly; also given nutrition textbook, cooking demos, and encouraged spousal support Cont: usual care from their providers and given written materials including a handout to follow NCEP's Step II-III diet | High | Low | Grams of saturated fat | Intv: 16.2 g Cont: 14.5 g | 12 mo | Intv: 13.8 g Cont: 14.8 g | Intv: −3.2 g Cont: −0.01g | 3.2 g | P = 0.1049 | 0.22 | 19.7% | Small
Masley et al., 2001^ 140 ^ | Adult men and women with a diagnosis of CAD from 4 community outpatient clinics from Group Health Cooperative in Washington, USA | High | 12 mo | Intv: 49 Cont: 48 | 81% | Research clinic | | High | Low | Grams of total fat | Intv: 49.6 g Cont: 45.4 g | 12 mo | Intv: 45.5 g Cont: 45 g | Intv: −6.6 g Cont: −1.7 g | 4.9 g | P = 0.4045 | 0.15 | 9.6%
Mojonnier et al., 1980^ 136 ^ | Adult men and women with hyperlipi-demia in study centers, USA | Moderate | 9 mo | Intv: NR Cont: | 70% | Research clinic | Intv: RD and nutrition aids delivered 4 different multidimensional interventions including assessment, self-teaching or group-teaching or individual teaching, or multi-method Cont: follow-up at 6 or 9 months for repeat measurements; no intervention | Medium | Low | % calories as saturated fat | Intv: 13.9% Cont: 13.3% | 6 and 9 mo F/U combined | Intv: 10.5% Cont: 12.8% | NR | 2.4% | P < 0.001 | NA | −20.7% | Small
Mojonnier et al., 1980^ 136 ^ | Adult men and women with hyperlipi-demia in study centers, USA | Moderate | 9 mo | Intv: NR Cont: | 70% | Research clinic | | Medium | Low | % calories as total fat | Intv: 37.8% Cont: 36.3% | 6 and 9 mo F/U combined | Intv: 33.9% Cont: 36.6% | NR | 2.7% | P < 0.01 | NA | −9.5% | Small
Neaton et al., 1981^ 13 ^ (The MRFIT Study) | Adult men at increased risk for CHD: MRFIT Multicenter Study, USA | Moderate --High | 3 yrs | Intv: 5,825 Cont: 5,766 | 91% | Research clinic | Intv: 10 initial intensive sessions followed by counseling sessions approx. q 4 mo; provider NR Cont: 3 screenings plus annual risk factor measurement and medical exam | High | Low | % calories as saturated fat | Intv: 14.0% Cont:14.0 % | 3 yrs | Intv: 10.0% Cont: 13.5% | Intv: −3.9% Cont: −0.4% | 3.5% | NR | 0.28 | −25% | Small
Neaton et al., 1981^ 13 ^ (The MRFIT Study) | Adult men at increased risk for CHD: MRFIT Multicenter Study, USA | Moderate --High | 3 yrs | Intv: 5,825 Cont: 5,766 | 91% | Research clinic | Intv: 10 initial intensive sessions followed by counseling sessions approx. q 4 mo; provider NR Cont: 3 screenings plus annual risk factor measurement and medical exam | High | Low | % calories as total fat | Intv: 38.2% Cont: 38.3% | 3 yrs | Intv: 33.8% Cont: 38.0% | Intv: −4.4% Cont: −0.3% | 4.1% | NR | 0.11 | −10.7% | Small
Ockene et al., 1996^ 139 ^ and Ockene et al., 1999^ 137 ^ | Adult men and women with hyperlipi-demia in HMOs USA | Moderate | 12 mo | Intv: NR Cont: NR | 80% | Primary care providers | Intv: MDs (trained for 3 hr) delivered nutrition counseling and staff provided office support Cont: usual care | Medium | High | % calories as saturated fat | NR | 12 mo | NR | Intv: −1.1% Cont: 0% | 1.1% | P = 0.01 | NA | NA | Small
Ockene et al., 1996^ 139 ^ and Ockene et al., 1999^ 137 ^ | Adult men and women with hyperlipi-demia in HMOs USA | Moderate | 12 mo | Intv: NR Cont: NR | 80% | Primary care providers | Intv: MDs (trained for 3 hr) delivered nutrition counseling and staff provided office support Cont: usual care | Medium | High | % calories as total fat | NR | 12 mo | NR | Intv: −2.3% Cont: −0.7% | 1.6% | P = 0.11 | NA | NA | Small
Ornish et al., 1990^ 121 ^ | Adult men and women with coronary atherosclerosis at study center California, USA | High | 12 mo | Intv: 28 Cont: 20 | Intv: 79% Cont: 95% | Research clinic | Intv: Clinical psychologist and RD provide initial 1-wk residential program followed by twice-a-wk (4 hr each) group sessions for 1 yr Cont: no intervention; usual care | High | Low | % calories as total fat | Intv: 31.5% Cont: 30.1% | 12 mo | Intv: 6.8% Cont: 29.5% | Intv: −24.7% Cont: −0.6% | 23.2% | P < .0001 | 0.23 | −76.4% | Large
Roderick et al., 1997^ 138 ^ | Adult men and women with hyper-cholesterolemia in general practice from 4 regions, United Kingdom | Avg/Low | 12 mo | Intv: 473 Cont: 483 | Intv: 86% Cont: 74% | Primary care providers | Intv: RNs on-site (trained for intv by RD) delivered dietary assessment, advice and F/U Cont: standard health education materials | Medium | High | % calories as saturated fat | Intv: 13.7% Cont: 14.0% | 12 mo | NR | Intv: −1.5% Cont: −0.6% | 0.9% | NR | 0.11 | NA | Small
Roderick et al., 1997^ 138 ^ | Adult men and women with hyper-cholesterolemia in general practice from 4 regions, United Kingdom | Avg/Low | 12 mo | Intv: 473 Cont: 483 | Intv: 86% Cont: 74% | Primary care providers | Intv: RNs on-site (trained for intv by RD) delivered dietary assessment, advice and F/U Cont: standard health education materials | Medium | High | % calories as total fat | Intv: 34.3% Cont: 34.2% | 12 mo | NR | Intv: −2.4% Cont --0.9% | 1.4% | NR | 0.07 | NA | Small
Simkin-Silverman et al., 1997^ 122 ^ | Premenopausal women at research centers Penn-sylvania, USA | Average | 6 mo | Intv: 267 Cont: 253 | 97% | Research clinic | Intv: Trained RD and behavioral interventionists led wkly group meetings x 10 wks then biweekly x 10 wks Cont: no intervention | High | Low | % calories as saturated fat | Intv: 12.3% Cont: 11.8% | 6 mo | NR | Intv: −4.3% Cont: −0.4% | 3.9% | P < 0.001 | 0.36 | NA | Large
Simkin-Silverman et al., 1997^ 122 ^ | Premenopausal women at research centers Penn-sylvania, USA | Average | 6 mo | Intv: 267 Cont: 253 | 97% | Research clinic | Intv: Trained RD and behavioral interventionists led wkly group meetings x 10 wks then biweekly x 10 wks Cont: no intervention | High | Low | % calories as total fat | Intv: 36.1% Cont: 35.5% | 6 mo | NR | Intv: −11.1% Cont: −1.0% | 10.1% | P < 0.001 | 0.31 | NA | Large
Steptoe et al., 1999^ 129 ^ | Adult men and women at increased risk for CHD in 20 general practices in London, England | Moderate | 12 mo | Intv: 316 Cont: 567 | 59% | Primary care providers | Intv: RN trained (4 days) in behavioral counseling delivered 2 to 3 individual counseling sessions-20 minutes each and 1 or 2 phone follow-ups Cont: NR | Medium | High | DINE Fat score | Intv: 30.5 Cont: 28.2 | 12 mo | Intv: 23.4 Cont: 23.8 | Intv: −7.1 Cont: −4.4 | 2.7 | P < 0.05 | 0.10 | 7.7% | Medium

*Outcomes in this table are reported in the following order of preference depending on the data available from each study: (a) percentage of kcals from saturated or total fat; (b) grams of saturated or total fat; and (c) other methods of measuring change in diet as presented by the authors of specific studies.

^†^(Baseline minus follow-up value for the intervention group) minus (baseline minus follow-up value for the control group). Note that the calculation for Difference at Final Follow-up is not given.

^‡^Absolute change in the intervention group from baseline to follow-up divided by the baseline value of control group.

Calculated percentage of calories from fat (either total or saturated) as (grams fat times 9 kcal divided by total kcal) x 100

^||^Effect size categories are assisgned based on either net difference in change or difference at final follow-up.

Table 5. Studies of counseling to increase intake of fruit or vegetables: study descriptions

Author Year | Sample Population | Level of Risk | Max Follow-up | Baseline Patient Numbers | Retention Rate | Setting | Intervention and Control Group Counseling Provider and Resources | Intensity | External Validity | Outcome | Baseline Values | Duration of Follow-up | Final Follow-up Values | Change from baseline to Final Follow-up | Net difference in change* or Difference at final follow-up | P- value | Calculated Relative Risk Reduction ^†^ | Calculated Difference in Deltas | Effect Size
Campbell et al., 1994^ 123 ^ Tailored msg vs. control | Adult men and women of family practices: 2 urban and 2 rural in North Carolina, USA | Avg/Low | 4 mo | Intv: NR Cont: NR | 82% | Mailings and computer-generated messages | Intv: Self-administered surveys in office delivered by staff; messages mailed home Cont: self-administered surveys only; no messages | Low | Medium | Servings of fruit and vegetables per day | Intv: 3.6Cont: 3.6 | 4 mo | Intv: 3.3 Cont: 3.3 | Intv: −0.3 Cont: −0.3 | 0 servings | P = 0. 817 | 0.08 | 0% | Small
Nontailored msg vs. control | Adult men and women of family practices: 2 urban and 2 rural in North Carolina, USA | Avg/Low | 4 mo | Intv: NR Cont: NR | 82% | Mailings and computer-generated messages | Intv: Self-administered surveys in office delivered by staff; non-tailored messages mailed home Cont: self-administered surveys only; no messages | Low | High | Servings of fruit and vegetables per day | Intv: 3.6 Cont: 3.6 | 4 mo | Intv: 3.3 Cont: 3.3 | Intv: −0.3 Cont: −0.3 | 0 servings | P = 0. 968 | 0.08 | 0% | Small
Coates et al., 1999^ 118 ^ | Post-menopausal in research clinics of Women's Health Trial28% black, 16% Hispanic | Moderate | 18 mo | Intv: 1324 Cont: 883 | 75%-85% | Outside referral | Intv: RD-delivered group sessions weekly x 6wks, biweekly x 6 weeks, monthly x 9 months Cont: given Dietary Guidelines for Americans; no counseling | High | Low | Servings of fruit per day | Intv: 1.53 Cont: 1.52 | 18 mo | NR | Intv: +0.54 Cont: +0.02 | 0.53 servings | NR | 0.36 | NA | Medium
Coates et al., 1999^ 118 ^ | Post-menopausal in research clinics of Women's Health Trial28% black, 16% Hispanic | Moderate | 18 mo | Intv: 1324 Cont: 883 | 75%-85% | Outside referral | Intv: RD-delivered group sessions weekly x 6wks, biweekly x 6 weeks, monthly x 9 months Cont: given Dietary Guidelines for Americans; no counseling | High | Low | Servings of vegetables per day | Intv: 1.62 Cont: 1.65 | 18 mo | NR | Intv: +0.35Cont: +0.08 | 0.27 servings | NR | 0.21 | NA | Medium
Cupples and McKnight 1994^ 133 ^ | Adult men and women with angina x 6mo at home or in a health care or surgery center Belfast, Northern Ireland | High | 24 mo | Intv: 342 Cont: 346 | Intv; 93% Cont: 87% | Primary care clinic referral | Intv: Trained health visitor delivered assessment and health education q 4 months at home or health center or surgery center Cont: assessment only | Medium | Medium | % of subjects with "improved" vegetable intake | NR | 24 mo | NR | Intv: 43.8% Cont: 37.7% | 6.1% | P = 0.002 | NA | NA | Small
Delichatsios, Friedman et al., 2001^ 125 ^ | Adult men and women in a large multisite, multi-specialty group practice -- Harvard Vanguard Medical Associates in Massa-chusetts, USA; 72% women, 45% white, 45% black | Avg/Low | 6 mo | NR | NR | Mailings and computer-generated messages: home | Intv: weekly diet-related educational feedback, advice, and behavioral counseling for 5-7 minutes by a totally automated, telephone-linked computer-based voice communication system Cont: weekly physical activity-related educational feedback, advice, and behavioral counseling for 5-7 minutes by a totally automated, telephone-linked computer-based voice communication system | Medium | Medium | Servings of fruit per day | Intv: 2.8 Cont: 2.4 | 6 mo | Intv: 3.2 Cont: 2.0 | Intv: +0.4 Cont: −0.4 | 0.8 servings | P < 0.05 | 0.17 | 31% | Medium
Delichatsios, Friedman et al., 2001^ 125 ^ | Adult men and women in a large multisite, multi-specialty group practice -- Harvard Vanguard Medical Associates in Massa-chusetts, USA; 72% women, 45% white, 45% black | Avg/Low | 6 mo | NR | NR | Mailings and computer-generated messages: home | | Medium | Medium | Servings of vegetables per day | Intv: 3.8 Cont: 3.5 | 6 mo | Intv: 4.5 Cont: 3.6 | Intv: +0.7 Cont: +0.1 | 0.6 servings | NR | 0.20 | 15.6% | Medium
Delichatsios, Hunt et al., 2001^ 134 ^ | Adult men and women patients from 6 group HMO practices in the primary care research network of Harvard Pilgrim HealthCare, Massa-chusetts, USA | Avg/Low | 3 mo | Intv: 230 Cont: 274 | Intv: 85% Cont: 92% | Mailings and computer -generated messages | Intv: mailed personalized dietary recom-mendations and 2 educational booklets; endorsement by 1 hour-trained MD or NP; 2 motivational phone counseling sessions by trained MPH student telephone counselors. RD consultation if needed. Cont: NR | Medium | Medium | Servings of fruit and vegetables per day | Intv: 2.9 Cont: 3.3 | 3 mo | Intv: 4 Cont: 3.7 | Intv: +1.1 Cont: +0.4 | 0.7 servings | NR | 0.33 | 25.8% | Medium
Knutsen and Knutsen, 1991^ 127 ^ | Adult men at increased risk for CVD and their familiesTromso, Norway | Moderate | 6 yr | M: 1373F: 1143C: 2838 | M:77% W:82% C: 39% | Primary care clinic referral | Intv: MD or RD each made 1 of made 2 home visits for CHD risk factor counseling and diet assessment and counseling Cont: NR | Medium | High | % of subjects eating > 4 fruits per week | NR | 6 yrs | Intv: M: 28% F: 48% C: 43% Cont: M: 24% F: 44% C: 39% | NR | M: 4% F: 4% C: 4% | NR | NA | NA | Small
Knutsen and Knutsen, 1991^ 127 ^ | Adult men at increased risk for CVD and their familiesTromso, Norway | Moderate | 6 yr | M: 1373F: 1143C: 2838 | M:77% W:82% C: 39% | Primary care clinic referral | Intv: MD or RD each made 1 of made 2 home visits for CHD risk factor counseling and diet assessment and counseling Cont: NR | Medium | High | % of subjects eating vegetables with dinner | NR | 6 yrs | Intv: M: 60% F: 72% C: 51% Cont: M: 60% F: 64% C: 53% | NR | M: 0% F: 8% C: 2% | NR | NA | NA | Small
Kristal et al., 2000^ 132 ^ | Adult men and women enrollees of Group Health Cooperative of Puget Sound HMO, Washington, USA | Avg/Low | 12 mo | Intv: 729 Cont: 730 | 86.5% | Mailings and computer-generated messages | Intv: self-help materials, dietary analysis with behavioral feedback, and semi-monthly newsletters mailed home; trained health educator delivered motivational phone call Cont: usual care - no intervention | Medium | Medium | Servings of fruit and vegetables per day | Intv: 3.62 Cont: 3.47 | 12 mo | Intv: 4.09 Cont: 3.61 | Intv: +0.47 Cont: +0.14 | 0.33 servings | P < 0.001 | 0.13 | 9% | Medium
Lutz et al., 1999^ 147 ^ Tailored msg w/ goal vs. control | Adult men and women | Avg/Low | 6 mo | Intv:177 Cont: 180 | 81% | Mailings and computer-generated messages | Intv: self-administered assessment mailed home; tailored messages were mailed home Cont: no newsletter | Low | Medium | Mean servings of fruits and vegetables per day | Intv: 3.5 Cont: 3.5 | 6 mo | Intv: 4.4 Cont: 3.6 | Intv: +0.9 Cont: +0.1 | 0.8 servings | P < 0.002 | 0.26 | 22.8% | Medium
Tailored msg w/out goal vs. control | Adult men and women | Avg/Low | 6 mo | Intv: 176 Cont: 180 | 81% | Mailings and computer-generated messages | Intv: self-administered assessment mailed home; tailored messages were mailed home Cont: no newsletter | Low | Medium | Mean servings of fruits and vegetables per day | Intv: 3.3 Cont: 3.5 | 6 mo | Intv: 4.1 Cont: 3.6 | Intv: +0.8 Cont: +0.1 | 0.7 servings | P < 0.002 | 0.23 | 21.3% | Medium
Lutz et al., 1999^ 147 ^ Nontailored msg vs. control | Adult men and women | Avg/Low | 6 mo | Intv: 177 Cont: 180 | 81% | Mailings and computer-generated messages | Intv: self-administered assessment mailed home; non-tailored messages were mailed home Cont: no newsletter | Low | Medium | Mean servings of fruits and vegetables per day | Intv: 3.4 Cont: 3.5 | 6 mo | Intv: 4.1 Cont: 3.6 | Intv: +0.7 Cont: +0.1 | 0.6 servings | P < 0.002 | 0.20 | 17.7% | Medium
Maskarinec et al., 1999^ 145 ^ | Healthy adult women over age 35 consuming less than 5 servings of fruit and vegetables daily in a study centerHawaii, USA | Avg/Low | 6 mo | Intv: 13 Cont: 16 | 88% | Outside referral | Intv: RD delivered monthly counseling sessions (1^st^ 2 individual, next 3 group) with phone follow-up as needed to increase fruits and vegetables Cont: RD delivered general healthy eating counseling based on the USDA Dietary Guidelines | High | Low | Servings of fruit and vegetables per day | Intv: 3.3 Cont: 3.2 | 6 mo | Intv: 7.4 Cont: 4.1 | Intv: 4.1 Cont: 0.9 | 3.2 servings | P = 0.0001 | 1.00 | 96% | Large
Masley et al., 2001^ 140 ^ | Adult men and women with a diagnosis of CAD from 4 community outpatient clinics from Group Health cooperative in Washington, USA | High | 12 mo | Intv: 49 Cont: 48 | 81% | Outside referral | Intv: RN taught 14 90-minute group classes: weekly for 1 months then monthly; also given nutrition textbook, cooking demos, and encouraged spousal support Cont: usual care from their providers and given written materials including a handout to follow NCEP's Step II-III diet | High | Low | Servings of fruit and vegetables per day | Intv: 3.08 Cont: 3.30 | 12 mo | Intv: 4.89 Cont: 2.88 | Intv: +1.73 Cont: −0.41 | 2.14 ser vings | P = 0.0002 | 0.65 | 69% | Large
Siero et al., 2000^ 146 ^ Group education vs. control | Low income adult men and women at increased risk for CVD in primary care practices and at home, The Netherlands | Moderate | 16 wks | Intv: NR Cont: NR | NR | Primary care clinic referral | Intv: 3 group sessions 2 hr each; provider NR Cont: received printed leaflet with the Dutch nutritional guidelines | High | Medium | Fruits and vegetables g/day | Intv: 424 g Cont: 416 g | 16 wks | Intv: 465 g Cont: 395 g | Intv: +41 g Cont: -21 g | 20 g | NR | 0.10 | 14.7% | Small
Group education and tailored msg vs. control | Low income adult men and women at increased risk for CVD in primary care practices and at home, The Netherlands | Moderate | 16 wks | Intv: NR Cont: NR | NR | Primary care clinic referral | Intv: messages were mailed home; group sessions 2 hr each led by group instructor not otherwise specified Cont: received printed leaflet with the Dutch nutritional guidelines | High | Medium | Fruits and vegetables g/day | Intv: 426 g Cont: 416 g | 16 wks | Intv: 494 g Cont: 395 g | Intv: +68g Cont: −21 g | +99 g | NR | 0.16 | 21% | Medium

* Baseline minus follow-up value for the intervention group minus baseline minus follow-up value for the control group

^†^ Absolute change in the intervention group from baseline to follow-up divided by the baseline value of the control group

Table 6. Studies of counseling to increase intake of fiber

Author, Year | Sample Population | Level of Risk | Max Follow-up | Baseline Patient Numbers | Retention Rate | Setting | Intervention and Control Group Counseling Provider and Resources | Intensity | External Validity | Outcome | Baseline Values | Duration of Follow-up | Final Follow-up Values | Change from Baseline to Final Follow-up | Net Difference in Change * or Difference at final follow-up | P-value | Calculated Relative Risk Reduction† | Calculated Difference in Deltas | Effect Size
Baron et al., 1990^ 148 ^ | Adult men and women in a group general practice, Abingdon, UK | Avg/Low | 12 mo | Intv: 187 Cont: 181 | 91% | Primary care providers | Intv: RN delivered 30 min group or individual diet advice and 2 F/Us Cont: RN follow up visit at 1 and 3 months; no dietary advice | Medium | High | Grams of fiber per day | Intv: M: 20.4 g F: 18.9 g Cont: M: 19.3 g F: 16.4 g | 12 mo | Intv: M: 22.8 g F: 21.4 g Cont: M: 20.1 g F: 15.4 g | NR | M: 2.7 g F: 6.0 g | NS | NA | M: +7.7% F: +7.1% | Medium
Beresford et al., 1992^ 130 ^ | Adult men and women in primary care 35% black North Carolina, USA | Avg/Low | 3mo | Intv: 120 Cont: 122 | 79% | Primary care providers | Intv: RN on site provides 5 min intro to self-help materials with phone F/U 10 d later Cont: baseline interview only | Low | High | Grams of fiber per day (adjusted) | Intv: 14 g Cont: 15 g | 3 mo | NR | NR | 0.6 g | NR | NA | NA | Small
Beresford et al., 1997^ 131 ^ | Adult men and women in family practice clinics, USA | Avg/Low | 12 mo | Intv: 1010 Cont: 1111 | 86% | Primary care providers | Intv: MD-delivered 3-min intro to self-help booklet + reminder letter from MD Cont: NR | Low | High | Grams of fiber per 1000 kcal | Intv: 10 g per 1000 kcal Cont: 10 g per 1000kcal | 12 mo | NR | Intv: +0.5 g per 1000 kcal Cont: +0.2 g per 1000 kcal | 0.3 g | NS | 0.1 | NA | Small
Delichatsios, Friedman et al., 2001^ 125 ^ | Adult men and women in a large multisite, multi-specialty group practice -- Harvard Vanguard Medical Associates in Massa-chusetts, USA; 72% women, 45% white, 45% black | Avg/Low | 6 mo | NR | NR | Mailings and computer-generated messages | Intv: weekly diet-related educational feedback, advice, and behavioral counseling for 5-7 minutes by a totally automated, telephone-linked computer-based voice communication system Cont: weekly physical activity-related educational feedback, advice, and behavioral counseling for 5-7 minutes by a totally automated, telephone-linked computer-based voice communication system | Medium | Medium | Grams of fiber per day | Intv: 21 g Cont: 20 g | 6 mo | Intv: 22 g Cont: 18 g | Intv: +1 g Cont: -2 g | 3 g | P < 0.05 | 0.05 | 14.8% | Medium
Delichatsios, Hunt et al., 2001^ 134 ^ | Adult men and women patients from 6 group HMO practices in the primary care research network of Harvard Pilgrim HealthCare, Massa-chusetts, USA | Avg/Low | 3 mo | Intv: 230 Cont: 274 | Intv: 85% Cont: 92% | Mailings and computer-generated messages | Intv: mailed personalized dietary recommendations and 2 educational booklets; endorsement by 1 hour-trained MD or NP; 2 motivational phone counseling sessions by trained MPH student telephone counselors. RD consultation if needed. Cont: NR | Medium | Medium | Grams of fiber per day | Intv: 7.3 g Cont: 8.2 g | 3 mo | Intv: 9.3 g Cont: 9.0 g | Intv: +2 g Cont: +0.8 g | 1.2 g | NR | 0.24 | 17.6% | Medium
Hjermann et al., 1981^ 12 ^ | Adult men at increased risk for CHD in a hospital medical outpatient clinic Oslo, Norway | Moderate to high | 5 yr | Intv: 604 Cont: 628 | 96% | Primary care clinic referral | Intv: MD-delivered on-site 10-15 min of info re: CHD risk factors and RD delivered on-site diet assessment and advice; MD F/U Cont: diet record only and annual short clinical re-examination | Medium | Low | Grams of fiber per day | NR | 4 yrs | Intv: +6 g Cont: +4.4 g | NR | 1.6 g | P < 0.05 | NA | NA | Medium
Lindholm et al., 1995^ 128 ^ | Adult men and women at increased risk for CHD in 32 county health centers Lund, Sweden | Moderate | 18 mo | Intv: 339 Cont: 342 | Intv: 92% Cont: 95% | Primary care clinic referral | Intv: MD- or RD-delivered group health care advice sessions Cont: usual health care advice from MD to reduce dietary fat, reduce weight if necessary, to stop smoking; pamphlet to reinforce instructions | High | Medium | Grams of fiber per day | NR | 18 mo | NR | NR | 0.9 g | P < 0.001 | NA | NA | Small

* Baseline minus follow-up value for the intervention group minus baseline minus follow-up value for the control group

^†^ Absolute change in the intervention group from baseline to follow-up divided by the baseline value of the control group

Each table has pairs of pages, such that any given study's information will be found on 2 adjoining pages. The first page presents information about the numbers and characteristics of the study population (including risk status), setting (and external validity of the study), the size and retention rates of the study, descriptions of the activities directed at the intervention and control groups, and the level of intensity of the intervention. The second page then presents information on outcomes, net changes between baseline and final follow-up measures for both intervention and control groups, differences between the intervention and control groups in net changes, and various statistical or effect size determinations.

Each separate row in a table represents a single study; if the study has multiple citations, they are provided in the first column. When studies have multiple arms, those are shown separated in the table by dotted lines; when studies simply have multiple outcome measures, such as outcomes related to total fat and saturated fat (in Table 4), those are given separately within the rows.

The study's setting, the means of performing the counseling, and the intensity and content of the intervention were considered especially significant variables in terms of understanding the feasibility of these types of interventions for primary care practice. Thus, we classified study settings (column labeled "Setting") in 1 of 4 ways:

1. primary care providers (counseling done by physician, physician assistant, nurse practitioner, or registered nurse [RN] in the course of his or her usual duties within the primary care setting);
2. primary care clinic referral (referral within a primary care practice, such as a registered dietitian [RD] or RN employed by the clinic or practice);
3. research clinic; or
4. mailings or computer-generated messages and intervention materials.

In addition, we noted other elements of interventions, including the intensity of the intervention (low, medium, or high) and whether the intervention components used had previously been shown to be associated with improved behavioral outcomes. We rated the study's external validity and feasibility for replication in routine primary care as high, medium, or low; in some studies, multiple intervention arms represented different levels of feasibility.

One column in the outcomes page of each table is entitled "Net Different in Change or Difference at Final Follow-up"; the net difference in change is calculated as the change from baseline to final follow-up for intervention groups minus the change for the control group and then presented in absolute terms. We also presented 2 calculated values in these tables. The "Relative Risk Reduction" is calculated as the absolute change in the intervention group from baseline to follow-up divided by the baseline value of the control group; although presented in arithmetic terms, it can be interpreted in percentage terms. The "Difference in Deltas" is calculated according to the following formula:

[(baseline intervention - follow-up intervention) / baseline intervention] -

[(baseline control - follow-up control) / baseline control] x 100.

Finally, using all information on study outcomes and changes from baseline to final measures for both intervention and control groups, we characterized the amount of dietary change in dietary behaviors, i.e., effect sizes, as small, medium, or large. The specific definitions for effect sizes are presented in the text below that deals in particular with the individual tables. Effect sizes for each study (including each arm or each separate outcome measure) appear in the last column of the table (on the second of the pair of pages).

##### Tables on interactions of variables and effect on dietary behaviors

Tables 7-12 deal in greater depth with results from reviewed studies concerning combined effects and relationships among, e.g., risk status of patients, intervention intensity, and number of components in the various interventions tested, setting and provider, and levels of effect size. Data are presented separately in some cases for fats, fruits and vegetables, and fiber.

### Effect of Counseling on Intake of Total and Saturated Fat

We identified 25 studies examining the effect of counseling on dietary total or saturated fat (Table 4). For outcomes stated in percentage of calories from total or saturated fat, we defined effect sizes as follows: large, >10% change in total fat or >3% change in saturated fat; medium, >5% to 10% change in total fat or >1.3% to 3% change in saturated fat; and small, 0% to 5% change in total fat or 0% to 1.3% change in saturated fat. For comparison purposes, a daily reduction of 7% in percent of calories from fat represents, in food terms, foregoing a medium serving of fast-food French fries or 4 pats of butter per day. For other outcomes, such as those reported in grams of total or saturated fat, specific dietary behaviors, or various food or dietary risk scores, the senior authors independently estimated the magnitude of relative change and assigned effect size categories; disagreements were resolved with consensus discussion.

Of the 25 studies in Table 4, 17 studies reported the effect of counseling on the percentage of calories derived from total dietary fat or provided data permitting us to calculate this value (12 directly reporting percentages, and 5 reporting grams); 11 studies provided data regarding the effect of counseling on percentage of calories from saturated fat. We considered 6 studies to have achieved large effects on change in dietary fat (in at least 1 element of the study).^118-122^ An additional 7 studies achieved medium effects (in at least 1 arm or outcome measure);^12,123-128^ 1 achieved a medium effect size on the DINE fat score.^ 129 ^ Finally, 13 studies (one with 2 published articles) achieved small effects on dietary fat (in at least one part of the study).^13,119,123,130-140^ Two studies had multiple study arms with different effect sizes.^119,123^ A collection of 4 studies presents data from the Women's Health Trial (WHT), which achieved large effects during a 24-month intervention period that were maintained at the medium level effect size for another year without further intervention. ^141-144^ Coates et al. examined a minority subset of the WHT.^ 118 ^

Eleven studies specifically examined the effect of counseling on the percentage of calories from saturated fats, and the net differences in these percentage reductions between baseline and final measurement in these studies ranged from 0.9% to 5.3%.^13,118,120,122,125,133,134,136,138,139,141-144^ Three other studies showed small or medium changes in other measures of saturated fats.^123,129,140^

### Effect of Counseling on Fruit and Vegetable Intake

We identified 11 studies that examined the effect of counseling on fruit and vegetable intake (Table 5);^118,123,125,127,132-134,140,145-147^ of these, 3 studies tested more than 1 type of intervention.^123,146,147^ Eight studies reported their results in terms of the change in the number of servings of fruits and vegetables consumed per day and the differences between the intervention and control groups in their changes between baseline and the end of the study.^118,123,125,132,134,140,145,147^ A serving of fruit and/or vegetables is one-half cup, the recommended intake is 5 servings a day, and the current US average is 2.5 to 3 servings per day. The mean increase in consumption seen with interventions ranged from 0 to 3.2 servings per day.

We defined effect sizes for studies reporting results in terms of increases in daily servings as follows: large, >1 serving; medium, 0.2 to 0.9 servings; and small, <0.2 servings. Across these 8 studies, 1 study achieved a small effect;^ 123 ^ 5 studies reported increases of medium size;^118,125,132,134,147^ and 2 had large effect sizes.^140,145^

The studies by Cupples and McKnight^ 133 ^ and Knutsen and Knutsen^ 127 ^ each used the percentage of subjects increasing their consumption of fruits or vegetables (or both) above a defined threshold as the main outcome variable. Both teams found little or no change in intake of fruits or vegetables (net increases of 0 to 8 percentage points in the proportion of subjects meeting the defined goals depending on the group being studied); we classified these as having only a small effect size.

Finally, Siero et al. presented grams of fruits and vegetables per day as their outcome measure in a 2-arm study.^ 146 ^ Group education alone achieved a 20 g increase in fruit and vegetable intake (small effect). By contrast, group education plus tailored messages resulted in a 99 g increase (medium effect); this is approximately equivalent to an increase of one-half serving per day.

### Effect of Counseling on Fiber Intake

Seven studies, lasting from 3 months to 4 years, examined the effect of counseling on fiber intake (Table 6).^12,125,128,130,131,134,148^ Of these 7 studies, 6 measured outcomes as grams of fiber per day;^12,125,128,130,134,148^ 1 used grams of fiber per 1,000 calories (kcal).^ 131 ^

For these studies, we defined effect sizes as follows: large, >6 g increase in consumption of fiber per day; medium, 1 g to 6 g increase in daily consumption; and small, <1 g change in consumption. Putting these changes in context, the currently recommended daily intake (RDI) for fiber is 20 to 30 g per day; the average intake in the United States is 15 g. An apple has about 2 g of fiber.

Four studies yielded increases in the amount of additional fiber consumed (range: 0.6 g to 3.0 g) classified as medium effect size,^12,125,134,148^ although Baron et al. reported differences in fiber intake between intervention and control groups of 2.7 g for men and 6.0 g for women at the 1-year follow-up point.^ 148 ^ Two studies had only small effect sizes.^128,130^ The single study with outcomes in terms of 1,000 kcal had only a small effect size (consensus decision by the senior authors).^ 131 ^

### Factors Affecting Response to Dietary Counseling

We examined several factors that may affect response to counseling and feasibility in a primary care setting. These factors include risk status of the patient, intensity of the intervention, and the setting and intervention provider. We also examined whether use of a number of specific counseling aids and components would influence the magnitude of effect. Tables 7 and 8 provide more details on these topics. The findings presented relate to all studies combined (fat, fruits and vegetables, fiber), because the number of studies in each group was too low for us to make valid comparisons for each specific dietary constituent.

#### Risk Status of Patients

Across all nutrient groups, studies of patients at average or low risk largely produced mainly small to medium effects on dietary behavior (Table 7). Studies of patients at moderate risk (1 or more identified risk factors, such as elevated cholesterol or hypertension) most frequently achieved small to medium levels of dietary change, but the amount of change tended to depend on the intensity of the intervention. Studies of high-risk patients (those with existing illnesses such as cancer or cardiovascular disease) were somewhat more likely to achieve large effects than studies of non-high-risk patients, but many studies in high-risk patients still produced only small or medium changes.

Table 7. Relationship between amount of change in dietary behavior and risk status of patients

Amount of Change in Dietary Behavior | Average/Low Risk | Moderate Risk | High Risk
Small Effect | Hunt et al., 1976^ 135 ^ Beresford et al., 1992^ 130 ^ Beresford et al., 1997^ 131 ^ Campbell et al., 1994^ 123 ^ (fruits and vegetables) Campbell et al 1994^ 123 ^ Delichatsios, Hunt et al., 2001^ 134 ^ (fat) Kristal et al., 2000 (fat)^ 132 ^ Roderick, 1997^ 138 ^ | Heller et al., 1994 (MD)^ 119 ^ Knutsen and Knutsen 1991^ 127 ^ (fruits and vegetables) Lindholm et al., 1995^ 128 ^ (fiber) Mojonnier et al., 1980^ 136 ^ Neaton et al., 1981^ 13 ^ Ockene et al., 1999^ 137 ^ | Cupples and McKnight, 1994^ 133 ^ Masley et al., 2001^ 140 ^ (fat) Neaton et al., 1981^ 13 ^
Medium Effect | Campbell et al., 1994^ 123 ^ (fat, tailored msg) Lutz, 1999^ 147 ^ Baron, 1990^ 148 ^ Delichatsios, Friedman et al., 2001^ 125 ^ Delichatsios, Hunt et al., 2001^ 134 ^ (fiber, fruits and vegetables) Kristal, 2000^ 132 ^ (fruits and vegetables) | Coates et al., 1999^ 118 ^ (fruits and vegetables) Hjermann et al., 1981^ 12 ^ (fat, fiber) Keyserling et al., 1997^ 126 ^ Knutsen and Knutsen, 1991^ 127 ^ (fat) Lindholm et al., 1995^ 128 ^ (fat) Siero et al., 2000^ 146 ^ Steptoe et al., 1999^ 129 ^ | Campbell et al., 1998^ 124 ^
Large Effect | Simkin-Silverman et al., 1997^ 122 ^ Maskarinec et al., 1999^ 145 ^ | Coates et al., 1999^ 118 ^ (fat) Heller et al., 1994^ 119 ^ (self) Henderson et al., 1990^ 141 ^ and Insull et al., 1990^ 142 ^ | Lee-Han et al., 1988^ 120 ^ Ornish et al., 1990^ 121 ^ Masley et al., 2001^ 140 ^ (fruits and vegetables)

#### Intensity of the Intervention

As shown in Tables 4-6, we classified the intensity of each counseling intervention as low, medium, or high; the factors dictating this classification included the number and length of counseling contacts, the magnitude and complexity of educational materials provided, and the use of supplemental intervention elements such as support group sessions or cooking classes. Table 8 documents the relationship between the amount of change in dietary behavior (i.e., effect size, as recorded in Tables 4-6) and intensity of interventions (shown as low, medium, or high).

Table 8. Relationship between the amount of change in dietary behavior and intensity of intervention

Amount of Change in Dietary Behavior | Low Intensity | Medium Intensity | High Intensity
Small Effect | Beresford et al., 1992^ 130 ^ Beresford et al., 1997^ 131 ^ (fiber) Campbell et al., 1994^ 123 ^ (nontailored msg: fat, fruits and vegetables) Heller et al., 1994^ 119 ^ (MD) Hunt et al., 1976^ 135 ^ | Cupples and McKnight, 1994^ 133 ^ (fat, fruits and vegetables) Delichatsios, Hunt et al., 2001^ 134 ^ (fat) Knutsen and Knutsen, 1991^ 127 ^ (fruits and vegetables) Kristal et al., 2000^ 132 ^ (fat) Mojonnier et al., 1980^ 136 ^ Ockene et al., 1999^ 137 ^ Roderick et al., 1997^ 138 ^ | Lindholm et al., 1995^ 128 ^ (fiber) Neaton et al., 1981^ 13 ^
Medium Effect | Campbell et al., 1994^ 123 ^ (tailored fat) Lutz, 1999 | Baron et al., 1990^ 148 ^ Delichatsios, Friedman et al., 2001^ 125 ^ Delichatsios, Hunt et al., 2001^ 134 ^ (fruits and vegetables, fiber) Hjermann et al., 1981^ 12 ^ (fat and fiber) Keyserling et al.,1997^ 126 ^ Knutsen and Knutsen, 1991^ 127 ^ (fat) Kristal et al., 2000^ 132 ^ (fruits and vegetables) Steptoe et al., 1999^ 129 ^ | Campbell et al., 1998^ 124 ^ Coates et al., 1999^ 118 ^ (fruits and vegetables) Lindholm et al., 1995^ 128 ^ (fat) Siero et al., 2000^ 146 ^
Large Effect | Beresford et al., 1997^ 131 ^ (fat) | Heller et al., 1994^ 119 ^ Lee-Han et al., 1988^ 120 ^ | Coates et al., 1999^ 118 ^ (fat) Henderson et al., 1990^ 141 ^ and Insull et al., 1990^ 142 ^ Masley et al., 2001^ 140 ^ (fruits and vegetables) Maskarinec et al., 1999^ 145 ^ Ornish et al., 1990^ 121 ^ Simkin-Silverman et al., 1997^ 122 ^

In our review, virtually all studies achieving large effect sizes fell into the high-intensity category. At the extreme is the study conducted by Ornish and colleagues.^ 121 ^ In their study, high-risk selected patients were referred to a multi-component lifestyle modification program delivered in a retreat-like setting. Studies that combine very intensive interventions with high-risk patients tended to show the largest impact.

The vast majority of medium-intensity studies achieved small to medium effects. Low-intensity counseling interventions, such as those typically used in primary care settings, also achieved only small to medium effects on dietary behavior

#### Combined Effect of Risk and Intensity

Tables 9a through 9c (respectively for fats, fruits and vegetables, and fiber) show the effect of intervention intensity and risk status of subjects on the amount of change in dietary behavior. In these tables, studies with small effect sizes are shown in Roman (regular) type, studies with medium effect sizes in italics, and studies with large effect sizes in bold.

Across all risk groups (average/low, moderate, and high), more intensive interventions were somewhat more likely to produce larger changes in behavior than were less intensive interventions. Studies conducted in high-risk patients were also more likely to be of higher intensity and, hence, more effective.

Table 9a. Combined effect of intensity of intervention and risk status of patients on the amount of change in dietary behavior: fat

Intensity | Average/Low Risk | Moderate Risk | High Risk
Low Intensity | Beresford et al., 1992^ 130 ^ Beresford et al., 1997^ 131 ^ Campbell et al., 1994^ 123 ^ (nontailored) Campbell et al., 1994 ^ 123 ^ (tailored) Hunt et al, 1976^ 135 ^ | Heller et al., 1994^ 119 ^ (MD)
Medium Intensity | Delichatsios, Hunt et al., 2001^ 134 ^ Kristal et al., 2000^ 132 ^ Roderick et al., 1997^ 138 ^ Delichatsios, Friedman et al., 2001^ 125 ^ | Heller et al., 1994^ 119 ^ (self) Hjermann et al., 1981 ^ 12 ^ Keyserling et al., 1997 ^ 126 ^ Knutsen and Knutsen, 1991 ^ 127 ^ Mojonnier et al., 1980^ 136 ^ Ockene et al., 1996^ 139 ^ Steptoe et al., 1999^ 129 ^ | Cupples and McKnight, 1994^ 133 ^ Lee-Han et al., 1988^ 120 ^
High Intensity | Simkin-Silverman et al., 1997^ 122 ^ | Coates, 1999 ^ 118 ^ Henderson et al, 1990 ^ 141 ^ and Insull, 1990 ^ 142 ^ Lindholm et al., 1995^ 128 ^ Neaton et al., 1981^ 13 ^ | Campbell et al., 1998 ^ 124 ^ Masley et al., 2001^ 140 ^ Ornish et al., 1990^ 121 ^ Neaton et al., 1981^ 13 ^

KeyBold = large effect: >10% change in total fat or > 3% change in saturated fatItalics = medium effect: 5-10% change in total fat or 1% - 3% decrease in saturated fat Regular Font = small effect: < 5 % change in total fat or <1% decrease in saturated fat

Table 9b. Combined effect of intensity of intervention and risk status on the amount of change in dietary behavior: fruits and vegetables

Intensity | Average/Low Risk | Moderate Risk | High Risk
Low Intensity | Campbell et al., 1994^ 123 ^ Lutz et al, 1999 ^ 147 ^
Medium Intensity | Delichatsios, Friedman et al., 2001 ^ 125 ^ Delichatsios, Hunt et al., 2001 ^ 134 ^ Kristal et al., 2000 ^ 132 ^ | Knutsen and Knutsen, 1991^ 127 ^ | Cupples and McKnight, 1994^ 133 ^
High Intensity | Maskarinec et al., 1999 ^ 145 ^ | Siero et al., 2000 ^ 146 ^ Coates et al., 1999 ^ 118 ^ | Masley et al., 2001^ 140 ^

KeyBold = large effect: >1 serving/day increaseItalics = medium effect: 0.5 - 1 serving/day increase Regular Font = small effect: <0.5 serving/day increase

Table 9c. Combined effect of intensity of intervention and risk status of patients on the amount of change in dietary behavior: fiber

Intensity | Average/Low Risk | Moderate Risk | High Risk
Low Intensity | Beresford et al., 1992^ 130 ^ Beresford et al., 1997^ 131 ^
Medium Intensity | Baron et al., 1990 ^ 148 ^ Delichatsios, Friedman et al., 2001^ 125 ^ Delichatsios, Hunt et al., 2001 ^ 134 ^ | Hjermann et al., 1981 ^ 12 ^ | Hjermann et al., 1981 ^ 12 ^
High Intensity | | Lindholm et al., 1995^ 128 ^

KeyBold = large effect (> 10g)Italics = medium effect (1-9g) Regular Font = small effect (< 1g)

#### Setting and Provider

As described above, we classified studies in terms of setting and provider and in terms of external validity. The latter classification - denoted, low, medium, or high - is based on representativeness of the providers and patient population and the feasibility of replicating the intervention in a primary care setting without the additional research infrastructure. Factors related to feasibility include training requirements of the providers as well as time and resource requirements of both patients and providers. (These data are recorded in columns labeled "Setting" and "External Validity" in Tables 4-6.)

Low-intensity interventions generally tended to be more feasible than higher-intensity efforts, and they tended to reflect counseling interventions that are implemented within the primary care setting today. However, some intervention strategies have achieved high levels of intensity while remaining feasible through the use of innovative, efficient strategies rather than relying on multiple clinic-based individual counseling sessions with the primary care provider. Examples include using office staff to deliver group-level interventions or follow-up telephone calls or mailings, computer-tailored newsletters or automated telephone systems to provide dietary feedback, goal setting, and reinforcement with very limited staff interaction time required.

In general, counseling provided by primary care providers had high external validity; primary care referral had medium external validity, as did mailed or computer-generated reminders. Research clinic settings had low external validity.

As shown in Tables 10a-10c and discussed in more detail below, studies conducted in primary care settings (by primary care providers or referrals) had small to medium effects, computer-generated messages and mailings had medium effects, and efforts in special research clinics tended to have large effects.

Table 10a. Studies documenting the relationship between the amount of change in dietary behavior and setting: fat

Amount of Change in Dietary Behavior | Primary Care Providers | Primary Care Clinic Referral | Research Clinic | Mailings and Computer-generated Messages
Small Effect | Beresford et al., 1992^ 130 ^ Beresford et al., 1997* ^ 131 ^ Ockene et al., 1996^ 139 ^ and 1999^ 137 ^ Roderick et al., 1997^ 138 ^ | Cupples and McKnight, 1994^ 133 ^ Hunt et al., 1976^ 135 ^ | Masley et al., 2001^ 140 ^ Mojonnier et al. 1980^ 136 ^ Neaton et al., 1981^ 13 ^ | Campbell et al., 1994 (nontailored)^ 123 ^ Delichatsios, Hunt et al., 2001^ 134 ^ Heller et al., 1994* ^ 119 ^ Kristal et al., 2000^ 132 ^
Medium Effect | Campbell et al., 1998^ 124 ^ Keyserling et al., 1997* ^ 126 ^ Steptoe et al., 1999^ 129 ^ | Hjermann et al., 1981^ 12 ^ Knutsen and Knutsen, 1991^ 127 ^ Lindholm et al., 1995^ 128 ^ | | Campbell et al., 1994 (tailored)^ 123 ^ Delichatsios, Friedman et al., 2001^ 125 ^
High Effect | | | Coates et al., 1999^ 118 ^ Henderson et al., 1990^ 141 ^ Kristal et al 1992^ 132 ^; White et al., 1992^ 144 ^ Insull et al., 1990^ 142 ^ Lee-Han et al., 1988^ 120 ^ Ornish et al., 1990^ 121 ^ Simkin-Silverman et al., 1997^ 122 ^ | Heller et al., 1994 (self)^ 119 ^

* Physician intervention only.

Table 10b. Studies documenting the relationship between the amount of change in dietary behavior and setting: fruits and vegetables

Amount of Change in Dietary Behavior | Primary Care Providers | Primary Care Clinic Referral | Research Clinic | Mailings and Computer-generated Messages
Small Effect | | Cupples and McKnight, 1994^ 133 ^ Knutsen and Knutsen, 1991^ 127 ^ | | Campbell et al., 1994 (nontailored)^ 123 ^
Medium Effect | | Siero et al., 2000^ 146 ^ | Coates et al., 1999^ 118 ^ | Delichatsios, Friedman et al., 2001^ 125 ^ Delichatsios, Hunt et al., 2001^ 134 ^ Kristal et al., 2000^ 132 ^ Lutz et al., 1999^ 147 ^
High Effect | | | Maskarinec et al., 1999^ 145 ^ Masley et al., 2001^ 140 ^

* Physician intervention only.

Table 10c. Studies documenting the relationship between the amount of change in dietary behavior and setting: fiber

Amount of Change in Dietary Behavior | Primary Care Providers | Primary Care Clinic Referral | Research Clinic | Mailings and Computer-generated Messages
Small Effect | Beresford et al., 1992^ 130 ^ Beresford et al., 1997* ^ 131 ^ | Lindholm et al., 1995^ 128 ^
Medium Effect | Baron et al., 1990^ 148 ^ | Hjermann et al., 1981^ 12 ^ | | Delichatsios, Friedman et al., 2001^ 125 ^ Delichatsios, Hunt et al., 2001^ 134 ^
High Effect

* Physician intervention only.

##### Primary care provider studies

We reviewed a total of 8 studies in which a primary care provider in the office setting delivered the diet counseling intervention (2 for fat and fiber, 5 for fat only, and 1 for fiber only) (Tables 10a-10c).^124,126,129-131,137-139,148^ Of these, 4 achieved small effects in dietary change and 4 achieved medium effects. All were considered to be of high feasibility and external validity.

Three evaluated interventions delivered primarily by physicians; 1 achieved medium-level effects,^ 126 ^ and 2, small effects.^131,137,139^ In the remaining 5 studies, the intervention involved distribution of print materials or counseling by a nurse employed by the primary care clinic. No study tested very brief advice by physicians against a control group receiving no such advice.

The studies that achieved medium-sized changes in dietary behavior used either medium-intensity^126,129,148^ or high-intensity^ 123 ^ interventions. Low-intensity interventions delivered to average-risk patients in primary care settings, although high in feasibility and external validity, produced only small changes in dietary fat consumption (1% to 2% reductions in total fat intake); changes in other dietary elements have not been studied.

##### Primary care clinic referral studies

An additional 6 studies in a primary care clinic used referral to a nutritionist, health educator, or other trained health professional (excluding nurses who were considered primary care providers when performing their usual duties) employed within that clinic.^12,127,128,133,135,146^ These studies produced small to medium effects on dietary behaviors. The studies in this category were all deemed to be of low to medium feasibility and external validity.

##### Research clinics

The largest effects on dietary behaviors were seen in studies using special research clinics, many of which also involved high-risk patients. All 10 of these studies (7 examining dietary fat; 2 fruits and vegetables; 1 for both fat and fruits and vegetables; none for fiber) were classified as having low feasibility or external validity for the typical primary care practice setting because of the intensive nature of the intervention and because they often used very selected study populations.^13,118,120-122,125,136,140-142,145^ Taking account of multiple dietary elements or study arms, 7 studies in research clinics achieved a large dietary behavioral effect, 1 a medium effect, and 3 a small effect.

##### Mailings and computer-generated messages

The health communications field is growing rapidly and has made use of various graphic and computer-based technologies to produce individually tailored counseling interventions that replace or supplement direct contact with providers. These interventions may be implemented alone or in conjunction with more conventional counseling strategies. We classified interventions in this category as largely having medium feasibility and external validity. As the technology evolves to provide "packaged" software tailoring programs, we anticipate that these interventions will become increasingly feasible for use within the primary care setting.

We identified 6 studies within this category, several of which tested multiple levels of computer tailoring.^119,123,125,132,134,147^ All but 1 of these studies resulted in medium to small effect sizes; the exception reported a large change in fat consumption among the siblings and offspring of individuals with a history of myocardial infarction but was rated as only fair quality because of unequal loss to follow up.^ 119 ^ More intensive tailoring seemed to result in greater dietary change, but the evidence was not conclusive.

#### Intervention Components

Several counseling intervention components have been shown to be associated with improved behavioral outcomes in other studies: a dietary assessment, family involvement, social support, group counseling, food interaction (such as taste testing or cooking), goal setting, and ethnic specificity. To characterize the investigations reported in this review at this level of detail, we abstracted data from each study to determine if the investigators used any of these 7 elements in their intervention; these data appear in Tables 11a, b, and c (fat, fruits and vegetables, fiber, respectively). The total number of components used ranged from 0 to 7, with a median of 2 components. Many authors did not describe their interventions in sufficient detail to assure that readers could determine the absence or presence of these study components.

Table 11a. Intervention components: fat

Author, Year | Dietary Assessment | Family | Social Support | Group | FoodInteraction | GoalSetting | EthnicSpecificity | Total Number of Effective Components
Beresford et al., 1992^ 130 ^ | No | No | No | No | No | No | No | 0
Beresford et al., 1997^ 131 ^ | No | No | No | No | No | No | No | 0
Campbell et al., 1998^ 124 ^ | Yes | No | No | No | No | Yes | No | 2
Campbell et al., 1994^ 123 ^ Tailored vs. control | Yes | No | No | No | No | No | No | 1
Nontailored vs. control | No | No | No | No | No | No | No | 0
Coates et al., 1999^ 118 ^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 7
Cupples and McKnight, 1994^ 133 ^ | No | No | No | No | No | No | No | 0
Delichatsios, Friedman et al., 2001^ 125 ^ | Yes | No | No | No | No | Yes | No | 2
Delichatsios, Hunt et al., 2001^ 134 ^ | Yes | No | No | No | No | Yes | No | 2
Heller et al., 1994^ 119 ^ | No | No | No | No | No | No | No | 0
Henderson et al., 1990^ 141 ^ Insull et al., 1990,^ 142 ^ Kristal et al., 1992^ 143 ^ | Yes | No | No | Yes | No | Yes | No | 3
Hjermann et al., 1981^ 12 ^ | Yes | Yes | No | Yes | No | No | No | 3
Hunt et al., 1976^ 135 ^ | No | No | No | Yes | No | No | Yes | 2
Keyserling et al., 1997^ 126 ^ | Yes | No | No | No | No | Yes | Yes | 3
Knutsen and Knutsen, 1991^ 127 ^ | Yes | Yes | No | No | No | No | No | 2
Kristal et al., 2000^ 132 ^ | Yes | No | No | No | No | Yes | No | 2
Lee-Han et al., 1988^ 120 ^ | No | No | No | No | No | No | No | 0
Lindholm et al., 1995^ 128 ^ | Yes | No | No | Yes | No | No | No | 2
Masley et al., 2001^ 140 ^ | Yes | Yes | No | Yes | Yes | No | No | 4
Mojonnier et al., 1980^ 136 ^ | No | No | No | Yes | No | No | No | 1
Neaton et al., 1981^ 13 ^ | Yes | No | No | No | No | No | No | 1
Ockene et al., 1996^ 139 ^ Ockene et al., 1999^ 137 ^ | Yes | No | No | No | No | Yes | No | 2
Ornish et al., 1990^ 121 ^ | No | No | Yes | Yes | No | No | No | 2
Roderick, 1997^ 138 ^ | Yes | No | No | No | No | Yes | No | 2
Simkin-Silverman et al., 1997^ 122 ^ | No | No | No | Yes | No | Yes | No | 2
Steptoe et al., 1999^ 129 ^ | Yes | No | No | No | No | Yes | No | 2

Table 11b. Intervention components: fruits and vegetables

Author, Year | Dietary Assessment | Family | Social Support | Group | Food Interaction | Goal Setting | Ethnic Specificity | Total Number of Effective Components
Campbell et al., 1994^ 123 ^ Tailored vs. control | Yes | No | No | No | No | No | No | 1
Campbell et al., 1994^ 123 ^ Nontailored vs. control | No | No | No | No | No | No | No | 0
Coates et al., 1999^ 118 ^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | 7
Cupples and McKnight 1994^ 133 ^ | No | No | No | No | No | No | No | 0
Delichatsios, Friedman, et al., 2001^ 125 ^ | Yes | No | No | No | No | Yes | No | 2
Delichatsios, Hunt et al., 2001^ 134 ^ | Yes | No | No | No | No | Yes | No | 2
Knutsen and Knutsen, 1991^ 127 ^ | Yes | Yes | No | No | No | No | No | 2
Kristal et al., 2000^ 132 ^ | Yes | No | No | No | No | Yes | No | 2
Lutz et al., 1999^ 147 ^ Tailored msg w/ goal vs. control | Yes | No | No | No | No | Yes | No | 2
Tailored msg w/out goal vs. control | Yes | No | No | No | No | No | No | 1
Nontailored msg vs. control | No | No | No | No | No | No | No | 0
Maskarinec et al., 1999^ 145 ^ | Yes | No | No | Yes | Yes | No | No | 3
Masley et al., 2001^ 140 ^ | Yes | Yes | No | Yes | Yes | No | No | 4
Siero et al., 2000^ 146 ^ Group education vs. control | No | No | No | Yes | No | No | No | 1
Group education and tailored msg vs. control | Yes | No | No | Yes | No | No | No | 2

Table 11c. Intervention components: fiber

Author, Year | Dietary Assessment | Family | Social Support | Group | Food Interaction | Goal Setting | Ethnic Specificity | Total Number of Effective Components
Baron et al., 1990^ 148 ^ | No | No | No | Yes | No | No | No | 1
Beresford et al., 1992^ 130 ^ | No | No | No | No | No | No | No | 0
Beresford et al., 1997^ 131 ^ | No | No | No | No | No | No | No | 0
Delichatsios, Friedman et al., 2001^ 125 ^ | Yes | No | No | No | No | Yes | No | 2
Delichatsios, Hunt et al., 2001^ 134 ^ | Yes | No | No | No | No | Yes | No | 2
Hjermann et al., 1981^ 12 ^ | Yes | Yes | No | Yes | No | No | No | 3
Lindholm et al., 1995^ 128 ^ | Yes | No | No | Yes | No | No | No | 2

As summarized in Table 12, studies employing 3 or more components were more likely to show a medium or large effect on dietary behaviors than studies using fewer than 3 components. Studies that did not report employing any of these specific components were more likely to have a small effect than studies using 1 or more components. The number of studies using each of the individual components was too low to permit us to determine with confidence whether the use of any given one component was associated with a greater change in dietary behavior.

Table 12. Relationship between the number of effective intervention elements and the change in dietary behavior

Amount of Change in Dietary Behavior | 0 Components | 1-2 Components | 3-7 Components
Small Effect | Beresford et al., 1992^ 130 ^ Beresford et al., 1997^ 131 ^ Campbell et al., 1994^ 123 ^ (nontailored fat plus fruits and vegetables) Cupples and McKnight, 1994^ 133 ^ Heller et al., 1994^ 119 ^ (MD) | Campbell et al., 1994^ 123 ^ (tailored fruits and vegetables) Delichatsios, Hunt et al., 2001^ 134 ^ (fat) Hunt et al., 1976^ 135 ^ Knutsen and Knutsen, 1991^ 127 ^ (fruits and vegetables) Kristal et al., 2000^ 132 ^ (fat) Lindholm et al., 1995^ 128 ^ (fiber) Mojonnier et al., 1980^ 136 ^ Neaton et al., 1981^ 13 ^ Ockene et al., 1999^ 137 ^ Roderick et al., 1997^ 138 ^ | Masley et al., 2001^ 140 ^ (fat)
Medium Effect | Lutz et al., 1999^ 147 ^ | Baron et al., 1990^ 148 ^ Campbell et al., 1994^ 123 ^ (tailored fat) Campbell et al., 1998^ 124 ^ Delichatsios, Friedman et al., 2001^ 125 ^ Delichatsios, Hunt et al., 2001^ 134 ^ (fruits and vegetables, fiber) Knutsen and Knutsen, 1991^ 127 ^ (fat) Kristal et al., 2000^ 132 ^ (fruits and vegetables) Lindholm et al., 1995^ 128 ^ (fat) Lutz et al., 1999^ 147 ^ Siero et al., 2000^ 146 ^ Steptoe et al., 1999^ 129 ^ | Coates et al., 1999^ 118 ^ (fruits and vegetables) Hjermann et al., 1981^ 12 ^ Keyserling et al., 1997^ 126 ^
Large Effect | Heller et al., 1994^ 119 ^ (self) Lee-Han et al., 1988^ 120 ^ | Ornish et al., 1990^ 121 ^ Simkin-Silverman et al., 1997^ 122 ^ | Coates et al., 1999^ 118 ^ (fat) Henderson et al., 1990^ 141 ^ and Insull et al., 1990^ 142 ^ Masley et al., 2001^ 140 ^ (fruits and vegetables) Maskarinec et al., 1999^ 145 ^

#### Sample Studies Illustrating Counseling Approaches

To understand more about how different approaches to counseling may affect dietary change, applying the 5-A framework is a useful step. The 5-A construct was initially developed to describe the essential elements of brief provider interventions related to tobacco cessation.^ 149 ^ Briefly, the 5-A framework includes Assess, Advise, Agree, Assist, and Arrange. Whitlock et al. describe it in more detail, provide an overview of counseling issues and approaches, and discuss the systems support necessary to implement behavioral counseling activities in the primary care setting.^ 1 ^

We found that too few studies reported adequate detail about the intervention to use the 5-As as a guide for this analysis of counseling, but it offers a useful framework for describing various counseling approaches. To provide more information on counseling approaches, therefore, we describe here 4 studies that represent different counseling approaches within each of our 4 settings categories (described earlier) that we deemed to be of higher external validity than other investigations and that achieved a medium to high effect.

##### Primary care provider studies

Illustrative of studies in this category is work by Keyserling et al.,^ 126 ^ who conducted a randomized trial in 21 community and rural health centers in the southeast. The main intervention was physician counseling, followed by a prompt for referral to a dietitian for patients not meeting their cholesterol-lowering goals after 6 months. Physicians advised patients with elevated cholesterol of the associated risks for cardiovascular disease. Patient diets were assessed using a 5- to 10-minute validated food frequency instrument. Providers were then trained to work with patients to agree on goals, provide counseling using low-literacy materials linked to the assessment (assist), and document the goals for follow-up at the next visit (arrange/assist). Before dietitian referral, the intervention resulted in a 3.3-point greater reduction in a dietary risk score for the intervention group than for control group (P < 0.001). When controlling for cholesterol-lowering medication use, reduction in total serum cholesterol was 5.5 mg/dl greater in the intervention group (95% CI, 0.3-10.7) than the control group. Ockene et al. tested a similar counseling intervention strategy by physicians in a group-model health maintenance organization supplemented with an office management system.^ 137 ^ This work produced a modest but statistically significant reduction in percentage of calories from saturated fat (1.1%), a reduction in weight of 2.3 kg, and a decrease of 3.8 mg/dl in LDL cholesterol. Dietary changes were not significant in the study arm that did not include an office management system.

##### Primary care clinic referrals

Siero and colleagues compared 3 2-hour group education classes only with an intervention arm including classes and a computer-tailored mailing.^ 146 ^ Designed to promote a "Mediterranean-style" diet, this study was conducted in a low socioeconomic status community in the Netherlands. The authors did not mention whether the group sessions included an assessment of dietary intake or mediating factors. Group leaders advised participants about both the knowledge and the skills needed to implement the Mediterranean diet and assisted them in making the behavior changes with specific guidelines for food purchasing and preparation. Subjects randomized to the 2-part intervention also received a computer-generated personal letter tailored to attitude, self-efficacy, social norm, and stage of change based on an extensive assessment of dietary habits and related psychosocial factors. The investigators did not mention either identifying and agreeing on a set of goals or arranging for follow-up in either group. Results of the study showed an increase of 62 g in the consumption of fruits and vegetables (approximately 0.4 to 0.5 serving) in the group- session-only arm; the tailored letters conferred no significant additional benefit (99 g total increase).

##### Research clinics

In the study by Coates and colleagues,^ 118 ^ dietitian-led group sessions were conducted weekly for 6 weeks, biweekly for another 6 weeks, and then monthly for 9 months. Study participants were ethnically diverse and were guided by group leaders to assess their dietary needs and then agree on specific changes to address the problems identified. Participants were advised by the group leaders regarding personal goals for grams of fat. The groups leaders then assisted participants with the lifestyle change process by teaching them about low-fat substitutions, implementing a self-monitoring strategy using a specially designed tool, guiding them through role plays and problem solving, and providing individualized attention as needed. Because the groups met on a regular basis, arranging follow-up was not necessary. This intervention resulted in a medium effect for fruits and vegetables (an increase of 0.53 servings of fruit and 0.27 servings of vegetables) and a large effect for fat (net reduction of 3.5% calories from saturated fat and 11.6% calories from total fat).

##### Mailings and computer-generated messages

This emerging technology in nutrition counseling has the potential to tailor messages individually while requiring little time on the part of health care providers. Campell et al. devised computer-tailored newsletters to be mailed to family practice patients.^ 123 ^ The study did fit into the 5-A framework. Diet was assessed using a self-administered food frequency instrument which provided the information needed to generate computer tailored nutrition messages mailed to participants. Although patients were not directly counseled by their physicians, the mailed materials helped to advise and assist them regarding recommended dietary change. The intervention did not arrange for any follow-up other than post-intervention measures. Relative to a control group, the tailored intervention resulted in a significant decrease in both total and saturated fat (9 g, P = 0.03 and 4.3 g, P = 0.036, respectively), whereas a nontailored newsletter did not show significant reduction in fat. Neither intervention arm achieved significant increases in fruit and vegetable intake.

### Summary of the Effectiveness of Dietary Counseling

The existing literature examining the effect of dietary counseling for patients in primary care is complex. Differences in the risk status, intensity of the intervention, setting, use of effective counseling components, dietary element(s) targeted, and outcome measures used all affect interpretation of data on the ability of counseling to change dietary behavior. We identified a large number of high-quality studies, many of which used patients and settings very similar to average US primary care clinics. We also identified several studies that take advantage of computerized or mailed information to supplement direct face-to-face counseling; these approaches are becoming more available with new advances in information technology dissemination.

Overall, dietary counseling produced modest reductions in the consumption of dietary total and saturated fat and modest increases in the consumption of fruits and vegetables. We did not identify sufficient evidence to make a conclusion about changes in other dietary elements. For studies conducted in primary care populations, interventions that were more intensive, conducted in patients at risk for chronic disease, or employed more of the effective "counseling elements" produce larger changes in dietary behavior. We did not identify enough studies to determine the individual effect of specific counseling techniques.

### Other Systematic Reviews Related to the Effectiveness of Dietary Interventions

Several other systematic reviews of dietary interventions have involved either a broader or narrower range of studies relevant to primary care practice^150-153^ In general, these reviews support our findings that a variety of counseling interventions result in meaningful dietary change in fat, saturated fat, fruits and vegetables, and fiber. As in this review, effect sizes vary widely and tend to be higher among those at higher risk for chronic disease. No clear consensus emerges from these reviews to suggest that certain intervention components are key to success.

### Interventions to Enhance Dietary Counseling Behaviors Among Physicians

Of the numerous studies regarding efforts to increase dietary counseling interventions by physicians and their office staff, only a few have included a rigorous pre-post design with comparison groups. Kottke et al. documented an increase in reported diet counseling for cardiovascular disease risk reduction after serving (unbeknownst to the conference attendees) meals that qualified as the "prudent diet" at a family practice conference.^ 154 ^ The proportion of physicians who reported that they considered the diet "very palatable" rose from 26% before the conference to 64% after they were told about the nature of the meals served. Several residency training programs were able to improve nutrition knowledge or increase dietary counseling behaviors (or both) through the use of a physician nutrition specialist (among other strategies).^155-157^ Finally, a randomized trial demonstrated that computerized reminders increased physician dietary assessment and counseling along with other cancer prevention behaviors.^ 158 ^

## Key Question No. 5: Adverse Effects and Associated Costs of Behavioral Interventions to Promote Healthy Diets

Concerns have been raised about the safety of reduced-fat diets for growing children.^159,160^ Case studies have reported poor growth as a result of low-fat diets,^161,162^ and experts have issued warnings of nutritional inadequacy for iron and calcium resulting from low-fat diets.^ 163 ^ In reviewing evidence for detrimental consequences of dietary fat restriction for children, Kaplan and Toshima evaluated studies on secular trends, migration, and vegetarian diets.^ 164 ^ They concluded that some evidence supports the contentions that dietary fat restriction may have minor effects on growth and that children who are placed on severe dietary restriction during growth periods may experience growth stunting. They cautioned, however, that the majority of the studies reviewed had serious methodological limitations.

The DISC Study (Dietary Intervention Study in Children) is perhaps the only systematic attempt to evaluate the impact of a fat-reduced diet during puberty on anthropometric, biochemical, and dietary measures of nutritional adequacy and safety.^ 15 ^ A recent publication from this study concluded that a cholesterol-lowering diet for children had no adverse effect on growth and development.^ 165 ^

Theoretically, assessing weight or dietary status or recommending dietary change to populations at high risk for eating disorders can pose some adverse effects. However, we are aware of no case reports or controlled studies regarding this issue.

## Key Question No. 6: System Influences that Facilitate or Impede Dietary Intervention

Many patients look to their physicians as the most likely source of nutritional guidance and perceive the level of expertise of physicians as equal to or just below that of a dietitian.^166,167^ Older national telephone surveys of practicing physicians and the adult public administered in 1983, 1986, and 1990 showed a steady increase in physician-provided diet counseling over time and a greater willingness to begin counseling at a lower serum cholesterol level.^168,169^ Most surveys suggest that physicians believe in the importance of diet counseling and perceive it to be within their role.^170,171^ However, counseling rates are still far from what is recommended by national guidelines.^172,173^

The epidemic of obesity in the United States is rising,^ 174 ^ and the USPSTF is expected to address screening for obesity in 2 future reviews. Hiddink et al. examined surveys over a 5-year period (1992 through 1997) and demonstrated a trend that can be characterized only as disturbing in this context, namely, a significant decrease in physician documentation and dietary counseling for obese patients.^ 175 ^ In the same surveys, perceived self-efficacy for counseling dropped and time as a barrier increased. Physicians may find weight reduction counseling less rewarding because obesity is such a widespread and intractable diet-related problem.

Barriers to dietary counseling by physicians are numerous. Some frequently reported barriers include perceived lack of preparation and confidence in their ability to help patients make lifestyle changes and a overall sense that their efforts are not successful.^170,171,175-177^ Other frequently documented obstacles include lack of time, perceived lack of patient interest and nonadherence by patients, and lack of adequate educational materials.^170,171,177-180^ Some weak associations between a physician's personal health habits and counseling behaviors seem to exist, and at least 1 study has shown that younger female physicians are more likely to be knowledgeable about diet and provide counseling than other physicians.^181,182^

In addition to the limited time available for preventive counseling, other system-level barriers exist. Many physicians cite the lack of nutrition training provided in medical school. Other describe challenges of reimbursement for physician or staff time spent on nutrition services,^ 179 ^ as well as unavailability of referral sources and lack of supportive office systems to facilitate nutrition intervention and monitoring.^ 182 ^

## Key Question No. 7: Nutritional Supplementation

Patients with poor nutritional status may benefit from nutritional supplementation. Potter et al. performed a systematic review of 32 studies of oral nutritional supplements.^ 183 ^ Persons randomized to receive supplements showed consistently improved changes in body weight compared with controls (weighted mean difference, 2.1%; 95% CI, 1.6%-2.5%). Treatment patients were also at lower risk for death (OR, 0.66; 95% CI, 0.48-0.91). Too few data were available to determine whether use of ordinary food in typical daily meals was superior or inferior to the generally more expensive prepared supplements.

## Issues Relating to Quality and Strength of Evidence in this Body of Literature

The evidence for the different key questions ranges from fair to good. Articles we reviewed had to meet relatively strict inclusion criteria (to optimize internal validity), and we restricted studies to those conducted in primary care populations (to optimize external validity). Randomized trials directly measuring the effect of differences in dietary intake on health outcomes are rare because of the long lag time between dietary "exposure" and disease. Those who wish to examine these questions must rely on observational data or evidence relating dietary interventions to change in chronic disease risk factors.

Quality issues related to internal validity that we could not control through inclusion criteria included the degree to which the intervention can be correctly characterized from the published description and problems associated with self-report bias. External validity is more difficult to characterize, given the considerable room for interpretation as to whether an intervention delivered after referral to another health care provider is "generalizable" to the population and conditions of general primary care practice. Although this point is not strictly a quality issue for any one study, the tendency for counseling interventions to test multiple intervention strategies simultaneously makes it difficult to identify evidence regarding the effect of any one strategy.