# Methods

## Analytic Framework and Key Questions

Staff of the RTI-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC), together with 3 members of the US Preventive Services Task Force (USPSTF) who are authors of this systematic evidence review (SER), developed an analytic framework to guide the work of producing this systematic evidence review (Figure 1). It depicts the relationship between diet and health, feasible dietary assessment strategies, evidence that dietary interventions delivered through primary care are effective in promoting long- and short-term behavior change, adverse effects associated with dietary assessment or intervention, and system influences on the delivery of diet assessment and counseling.

Figure 1. Counseling to Promote a Healthy Diet: Analytic Framework

To guide the work more precisely, we identified 7 key questions:

1. What is the relationship between dietary patterns and health outcomes?
2. What are valid, feasible tools for assessment of dietary risk?
3. What are the adverse effects of dietary assessment?
4. What is the efficacy of primary care counseling and dietary behavior change interventions?
5. What are the adverse effects and associated costs of dietary behavior intervention?
6. Which of the following system influences facilitate or impede dietary intervention: features of the health care team? features of the practice setting? features of the health care system?
7. Can dietary supplements improve nutrition in patients identified as undernourished?

## Literature Search and Analysis Strategy

To identify studies examining the question of the relationship between diet and health, we identified existing systematic reviews from MEDLINE, the Cochrane Database of Systematic Reviews, and the University of York Database of Reviews of Effectiveness (DARE) from 1990 to the present; we did not conduct formal searches of the primary literature. When systematic reviews were unavailable, we also included representative individual observational studies and randomized trials.

To find articles relevant to the questions about dietary assessment and the effectiveness of diet counseling in the primary care setting, we searched the MEDLINE database for citations to articles published between 1966 and 2001. The information on searches provided below and in Chapter III pertains to those key questions about dietary behavior interventions.

We employed the following Medical Subject Heading (MeSH) terms for the 3 main types of searches (diet, primary care, and counseling):

- Diet: "diet," "nutrition," "food frequency," "food habits," "dietary assessment," "diet records," "diet surveys," and "nutrition assessment";
- Primary care: "family practice," "primary health care," "primary care setting";
- Counseling: "counseling," "dietary counseling" (textword), "diet counseling" (textword), and "nutrition counseling (textword)."

We carried out additional searches to identify articles regarding brief dietary assessment methodology and existing systematic reviews about dietary counseling interventions. We reviewed bibliographies of pertinent articles and consulted with experts in the field to assure completeness.

### Inclusion and Exclusion Criteria

We limited all searches to "human" populations and "English language." For counseling interventions, we restricted searches to randomized controlled trials (RCTs).

For the diet counseling literature related to patient dietary outcomes, we included articles if they evaluated a nutrition intervention delivered to a primary care population either within a primary care setting or after referral. We included studies that assessed impact on dietary change among those at risk for chronic disease (e.g., elevated cholesterol). However, we excluded studies of individuals with a diagnosed illness that (a) might directly affect their dietary intake (e.g., cancer), (b) required a specialized diet (e.g., diabetes or renal disease), or (c) required entry into the study immediately following a life-threatening, disease-related event (e.g., during hospitalization for an acute myocardial infarction).

All included articles used a RCT design with baseline and follow-up measures of relevant dietary outcomes. We excluded studies that reported physiologic measures or biomarkers associated with dietary change (e.g., serum vitamin levels) but no direct measure of diet behavior. We also did not use studies in which the diet was externally controlled (provided by researchers or in a residential institution). To include a study we required that the retention rate be at least 50% and that studies be at least 3 months in duration.

We retained studies evaluating physician training programs to improve physician counseling practices if a control or comparison group was a part of the evaluation and if the counseling approach tested was relevant to the primary care setting.

### Literature Synthesis

Senior investigators reviewed titles and abstracts to identify which full manuscripts to review and made the final decisions about inclusion or exclusion. Assisted by nutrition doctoral students, they then reviewed individual articles and abstracted selected information onto evidence tables. Reviewers discussed any disagreements; the senior investigators made the final decisions.

We graded the quality of the articles, in terms of internal validity, as good or fair. We judged studies to be fair or good quality based on allocation concealment, blinding of outcomes assessment, and completeness of follow-up. Exclusion criteria eliminated articles that would be considered of poor quality.

We classified each study as having low, medium, or high external validity based on representativeness of the providers and patient population as well as feasibility of replicating the intervention in a primary care setting without additional research infrastructure. Two senior reviewers independently rated the intensity of the dietary intervention as low, medium, or high based on the number and length of counseling contacts, the magnitude and complexity of educational materials provided, and the use of supplemental intervention elements, such as support groups sessions or cooking classes. Low-intensity interventions generally involved 1 contact lasting less than 30 minutes. High-intensity interventions involved greater than 6 contacts, each lasting at least 30 minutes. Medium intensity was in between low and high.

Given the wide range of measurement and reporting strategies and the need to facilitate comparability across studies, we also classified the effect size achieved by each study. We developed specific cutpoints to define 3 effect size categories, denoted large, medium, or small, for dietary fat, fruit and vegetables, and fiber. For outcomes stated in percentage of calories from total or saturated fat, we defined effect sizes as follows: large, >10% change in total fat or >3% change in saturated fat; medium, >5% to 10% change in total fat or >1.3% to 3% change in saturated fat; and small, 0% to 5% change in total fat or 0% to 1.3% change in saturated fat. We classified fruit and vegetable intake effect sizes based on the following categories: large, > 1 serving change; medium, 0.2 to 0.9 serving change; and small < 0.2 serving change. For fiber, effect size definitions were as follows: large change, > 6 grams (g); medium change, 1 g to 6 g; and small change, < 1 g. When studies used outcomes such as amounts of intake (e.g., grams of fat), dietary risk scores, or changes in specific dietary behaviors, we classified effect size based on the relative change (net change divided by baseline values in controls) and by our own qualitative estimates; when the abstractors disagreed, they resolved the discrepancy by consensus discussion.

## Preparation of Systematic Evidence Review

The authors presented the work plan and interim portions of this SER at several USPSTF meetings in 2000 and 2001; at those times the Task Force liaisons and the entire Task Force could discuss and clarify the breadth of the work. In particular, Task Force members encouraged the research staff to expand their examination and review of literature pertaining to linkages between diet and health outcomes (i.e., Key Question No. 1) and provide much more detailed data and analysis on the components of dietary intervention strategies than had originally been planned. The senior author, who had primary responsibility for materials relating to issues of counseling and dietary practices, also participated in teleconferences of the USPSTF Counseling and Behavioral Intervention Work Group. The draft SER was circulated for outside peer review in early June 2001 and revised appropriately for this final version.