# Appendix A. Acknowledgements

## Appendix AAcknowledgements

This study was supported by Contract 290-97-0011 from the Agency of Healthcare Research and Quality (Task No. 3). We acknowledge at AHRQ the continuing support of Jacqueline Besteman, J.D., M.A., Director for the Evidence-based Practice Center program; and David Atkins, M.D., M.P.H., Director of the Clinical Prevention Program for the U.S. Preventive Services Task Force. The investigators deeply appreciate the contributions of Loraine Monroe or RTI, for superior secretarial assistance. In addition, we are indebted to staff from the University of North Carolina at Chapel Hill and the Cecil G. Sheps Center for Health Services Research: Carol Krasnov for diligent administrative assistance and coordination, and Timothy S. Carey, M.D., M.P.H., Director of the Sheps Center and Co-Director of the RTI-UNC Evidence-based Practice Center.

We also owe our thanks to the following external peer reviewers, who provided constructive feedback and insightful suggestions for improvement of this systematic evidence review: Walter Willet, M.D., Dr.P.H., Harvard School of Public Health, Boston, Massachusetts; Ronald Kahn, M.D., American Academy of Family Physicians, Little Rock, Arkansas; R. Wayne Elford, M.D., University of Calgary Medical Clinic, Alberta, Canada; Eric Gertner, M.D., Lehigh Valley Physician Group, Allentown, Pennsylvania; Heidi Michels Blank, Ph.D., M.S., Centers for Disease Control and Prevention, Atlanta, Georgia; Chris Gibbons, M.D., M.P.H., Centers for Medicare and Medicaid Services, Baltimore, Maryland; Peter C. van Dyck, M.D., M.P.H., Health Resources and Services Administration, Rockville, Maryland; Laura McNally, R.D., M.P.H., Health Resources and Services Administration, Rockville, Maryland; Joan M.G. Lyon, M.S., R.D., L.D., U.S. Army Medicine, Aberdeen Proving Ground, Maryland; and Paul M. Coates, Ph.D, National Institutes of Health, Bethesda, Maryland.