# References

1 World Health Organization. Global Hepatitis Report 2017: World Health Organization; 2017.
2 Kowdley KV, Wang CC, Welch S, . Prevalence of chronic hepatitis B among foreign-born persons living in the United States by country of origin. Hepatology (Baltimore, Md). 2012;56(2):422–33. PMID: 22105832. 10.1002/hep.24804
3 Dionne-Odom J, Tita AT, Silverman NS. #38: Hepatitis B in pregnancy screening, treatment, and prevention of vertical transmission. American journal of obstetrics and gynecology. 2016;214(1):6–14. PMID: 26454123. 10.1016/j.ajog.2015.09.100 26454123
4 Polaris Observatory C. Global prevalence, treatment, and prevention of hepatitis B virus infection in 2016: a modelling study. Lancet Gastroenterol Hepatol. 2018;26:26. PMID: 29599078. 10.1016/S2468-1253(18)30056-6
5 Roberts H, Kruszon-Moran D, Ly KN, . Prevalence of chronic hepatitis B virus (HBV) infection in U.S. households: National Health and Nutrition Examination Survey (NHANES), 1988-2012. Hepatology (Baltimore, Md). 2016;63(2):388–97. PMID: 26251317. 10.1002/hep.28109
6 Gish RG, Sollano JD, Jr., Lapasaran A, . Chronic hepatitis B virus in the Philippines. J Gastroenterol Hepatol. 2016;31(5):945–52. PMID: 26643262. 10.1111/jgh.13258 26643262
7 Schillie S, Vellozzi C, Reingold A, . Prevention of Hepatitis B Virus Infection in the United States: Recommendations of the Advisory Committee on Immunization Practices. MMWR 2018;67(RR-1):1–31. 10.15585/mmwr.rr6701a1
8 Salemi JL, Spooner KK, Mejia de Grubb MC, . National trends of hepatitis B and C during pregnancy across sociodemographic, behavioral, and clinical factors, United States, 1998-2011. Journal of medical virology. 2017;89(6):1025–32. PMID: 27805270. 10.1002/jmv.24725 27805270
9 Miller GK, Barker L, Taylor A, . Hepatitis B vaccination among U.S. women of reproductive age. Journal of Women’s Health. 2017;26(4):A29. PMID: None. 10.1089/jwh.2017.29011.abstracts
10 Ko SC, Fan L, Smith EA, . Estimated Annual Perinatal Hepatitis B Virus Infections in the United States, 2000-2009. Journal of the Pediatric Infectious Diseases Society. 2016;5(2):114–21. PMID: 26407247. 10.1093/jpids/piu115 26407247
11 Terrault NA, Lok ASF, McMahon BJ, . Update on prevention, diagnosis, and treatment of chronic hepatitis B: AASLD 2018 hepatitis B guidance. Hepatology (Baltimore, Md). 2018;67(4):1560–99. PMID: 29405329. 10.1002/hep.29800
12 Schwarz KB, Cloonan YK, Ling SC, . Children with Chronic Hepatitis B in the United States and Canada. J Pediatr. 2015;167(6):1287–94e2. PMID: 26364985. 10.1016/j.jpeds.2015.08.021 26364985
13 Ghany MG, Perrillo R, Li R, . Characteristics of adults in the hepatitis B research network in North America reflect their country of origin and hepatitis B virus genotype. Clin Gastroenterol Hepatol. 2015;13(1):183–92. PMID: 25010003. 10.1016/j.cgh.2014.06.028 25010003
14 National Academies of Sciences Engineering and Medicine. Eliminating the Public Health Problem of Hepatitis B and C in the United States: Phase One Report. Buckley GJ, Strom BL, editors. Washington (DC): National Academies Press (US); 2016.
15 del Canho R, Grosheide PM, Mazel JA, . Ten-year neonatal hepatitis B vaccination program, The Netherlands, 1982-1992: protective efficacy and long-term immunogenicity. Vaccine. 1997;15(15):1624–30. PMID: 9364693.9364693
16 Chen HL, Zha ML, Cai JY, . Maternal viral load and hepatitis B virus mother-to-child transmission risk: a systematic review and meta-analysis. Hepatology Research. 2018;23:23. PMID: 29473269. 10.1111/hepr.13072
17 Haber P, Moro PL, Ng C, . Safety of currently licensed hepatitis B surface antigen vaccines in the United States, Vaccine Adverse Event Reporting System (VAERS), 2005-2015. Vaccine. 2018;36(4):559–64. PMID: 29241647. 10.1016/j.vaccine.2017.11.079 29241647
18 Centers for Disease Control and Prevention. Sensitivity of the test for antibody to hepatitis B surface antigen-United States. MMWR Morbidity and mortality weekly report. 1993;42(36):707–10. PMID: 8361466.
19 World Health Organization. Hepatits B Surface Antigen Assays: Operational Characteristics (Phase I). http://www.who.int/diagnostics_laboratory/evaluations/en/hep_B_rep1.pdf: World Health Organization; 2001.
20 Schillie S, Walker T, Veselsky S, . Outcomes of infants born to women infected with hepatitis B. Pediatrics. 2015;135(5):e1141–e7. PMID: 25896839. 10.1542/peds.2014-3213 25896839
21 Centers for Disease Control and Prevention. Perinatal Hepatitis B Prevention Program. https://www.cdc.gov/vaccines/programs/perinatal-hepb/index.html. Accessed: 05/03/2018.
22 Abara WE, Qaseem A, Schillie S, . Hepatitis B Vaccination, Screening, and Linkage to Care: Best Practice Advice From the American College of Physicians and the Centers for Disease Control and Prevention. Annals of internal medicine. 2017;167(11):794–804. PMID: 29159414 10.7326/M17-1106 29159414
23 Bruce MG, Bruden D, Hurlburt D, . Antibody levels and protection after hepatitis B vaccine: results of a 30-year follow-up study and response to a booster dose. The Journal of infectious diseases. 2016;214(1):16–22. PMID: 26802139. 10.1093/infdis/jiv748 26802139
24 Centers for Disease Control and Prevention. Hepatitis B virus: a comprehensive strategy for eliminating transmission in the United States through universal childhood vaccination. Recommendations of the Immunization Practices Advisory Committee (ACIP). MMWR Recommendations and reports: Morbidity and mortality weekly report Recommendations and reports. 1991;40(Rr-13):1–25. PMID: 1835756.
25 Chen ZX, Zhuang X, Zhu XH, . Comparative Effectiveness of Prophylactic Strategies for Perinatal Transmission of Hepatitis B Virus: A Network Meta-analysis of Randomized Controlled Trials. Open Forum Infect Dis. 2017;4(4):ofx225. PMID: 29181424. 10.1093/ofid/ofx225 29181424
26 Venters C, Graham W, Cassidy W. Recombivax-HB: perspectives past, present and future. Expert Rev Vaccines. 2004;3(2):119–29.15056038
27 Assad S, Francis A. Over a decade of experience with a yeast recombinant hepatitis B vaccine. Vaccine. 1999;18(1-2):57–67. PMID: 10501235. 10.1016/S0264-410X(99)00179-6 10501235
28 Terrault NA, Bzowej NH, Chang KM, . AASLD guidelines for treatment of chronic hepatitis B. Hepatology (Baltimore, Md). 2016;63(1):261–83. PMID: 26566064. 10.1002/hep.28156
29 Culp LA, Caucci L, Fenlon NE, . Assessment of State Perinatal Hepatitis B Prevention Laws. American journal of preventive medicine. 2016;51(6):e179–e85. PMID: 27866601. 10.1016/j.amepre.2016.09.005 27866601
30 Kwong AJ, Chang MS, Tuomala RE, . Peripartum Care for Mothers Diagnosed with Hepatitis B During Pregnancy: A Survey of Provider Practices. Matern Child Health J. 2018. PMID: 29512054. 10.1007/s10995-018-2515-0
31 Kolasa MS, Tsai Y, Xu J, . Hepatitis B Surface Antigen Testing Among Pregnant Women, United States 2014. Pediatric Infectious Disease Journal. 2017;36(7):e175–e80. PMID: 28030527. 10.1097/INF.0000000000001516 28030527
32 Hill HA, Elam-Evans LD, Yankey D, . Vaccination coverage among children aged 19–35 months—United States, 2017. 2018;67(40):1123.
33 Hill HA, Elam-Evans LD, Yankey D, . Vaccination Coverage Among Children Aged 19-35 Months - United States, 2016. MMWR Morbidity and mortality weekly report. 2017;66(43):1171–7. PMID: 29095807. 10.15585/mmwr.mm6643a3 29095807
34 Delage G, Montplaisir S, Remy-Prince S, . Prevalence of hepatitis B virus infection in pregnant women in the Montreal area. CMAJ: Canadian Medical Association journal = journal de l’Association medicale canadienne. 1986;134(8):897–901. PMID: 3955483.
35 Jonas MM, Schiff ER, O’Sullivan MJ, . Failure of Centers for Disease Control criteria to identify hepatitis B infection in a large municipal obstetrical population. Ann Intern Med. 1987;107(3):335–7. PMID: 3039886.3039886
36 Kumar ML, Dawson NV, McCullough AJ, . Should all pregnant women be screened for hepatitis B? Ann Intern Med. 1987;107(3):273–7. PMID: 3619218.3619218
37 Summers PR, Biswas MK, Pastorek JG, 2nd, . The pregnant hepatitis B carrier: evidence favoring comprehensive antepartum screening. Obstetrics and gynecology. 1987;69(5):701–4. PMID: 3574797.3574797
38 Wetzel AM, Kirz DS. Routine hepatitis screening in adolescent pregnancies: is it cost effective? American journal of obstetrics and gynecology. 1987;156(1):166–9. PMID: 3099577.3099577
39 McQuillan GM, Townsend TR, Johannes CB, . Prevention of perinatal transmission of hepatitis B virus: the sensitivity, specificity, and predictive value of the recommended screening questions to detect high-risk women in an obstetric population. Am J Epidemiol. 1987;126(3):484–91. PMID: 3618580.3618580
40 U. S. Preventive Services Task Force. Screening for hepatitis B virus infection: recommendation statement 2004. http://www.ahrq.gov/clinic/uspstf/uspshepb.htm. Accessed: 06/01/2017.
41 U. S. Preventive Services Task Force. Screening for hepatitis B virus infection in pregnancy: U.S. Preventive Services Task Force reaffirmation recommendation statement. Ann Intern Med. 2009;150(12):869–73, W154. PMID: 19528565. 10.7326/0003-4819-150-12-200906160-00011 19528565
42 Krishnaraj R. Screening for hepatitis B virus infection: a brief evidence update for the U.S. Preventive Services Task Force. http://www.ahrq.gov/clinic/3rduspstf/hepbscr/hepbup.htm. Accessed: 06/01/2017.
43 Mele A, Tancredi F, Romano L, . Effectiveness of hepatitis B vaccination in babies born to hepatitis B surface antigen-positive mothers in Italy. J Infect Dis. 2001;184(7):905–8. PMID: 11509998. 10.1086/323396 11509998
44 Ni YH, Chang MH, Huang LM, . Hepatitis B virus infection in children and adolescents in a hyperendemic area: 15 years after mass hepatitis B vaccination. Ann Intern Med. 2001;135(9):796–800. PMID: 11694104.11694104
45 Chang MH, Chen CJ, Lai MS, . Universal hepatitis B vaccination in Taiwan and the incidence of hepatocellular carcinoma in children. Taiwan Childhood Hepatoma Study Group. N Engl J Med. 1997;336(26):1855–9. PMID: 9197213. 10.1056/NEJM199706263362602 9197213
46 Lin K, Vickery J. Screening for hepatitis B virus infection in pregnant women: evidence for the U.S. Preventive Services Task Force reaffirmation recommendation statement. Ann Intern Med. 2009;150(12):874–6. PMID: 19528566.19528566
47 Lee C, Gong Y, Brok J, . Effect of hepatitis B immunisation in newborn infants of mothers positive for hepatitis B surface antigen: systematic review and meta-analysis. BMJ. 2006;332(7537):328–36. PMID: 16443611.16443611
48 Hyun MH, Lee YS, Kim JH, . Systematic review with meta-analysis: the efficacy and safety of tenofovir to prevent mother-to-child transmission of hepatitis B virus. Aliment Pharmacol Ther. 2017;45(12):1493–505. PMID: 28436552. 10.1111/apt.14068 28436552
49 Brown RS, Jr., McMahon BJ, Lok AS, . Antiviral therapy in chronic hepatitis B viral infection during pregnancy: A systematic review and meta-analysis. Hepatology (Baltimore, Md). 2016;63(1):319–33. PMID: 26565396. 10.1002/hep.28302
50 Tavakolpour S, Darvishi M, Mirsafaei HS, . Nucleoside/nucleotide analogues in the treatment of chronic hepatitis B infection during pregnancy: a systematic review. Infect Dis (Lond). 2018;50(2):95–106. PMID: 29020844. 10.1080/23744235.2017.1384957 29020844
51 Jourdain G, Ngo-Giang-Huong N, Harrison L, . Tenofovir versus Placebo to Prevent Perinatal Transmission of Hepatitis B. N Engl J Med. 2018;378(10):911–23. PMID: 29514030. 10.1056/NEJMoa1708131 29514030
52 US Preventive Services Task Force. Guide to Clinical Preventive Services: Report of the U.S. Preventive Services Task Force. Baltimore (MD): Williams & Wilkins; 1996 [cited Workplan. Available from: https://www.ncbi.nlm.nih.gov/books/NBK15435/.
53 Kubo A, Shlager L, Marks AR, . Prevention of vertical transmission of hepatitis B: an observational study. Annals of internal medicine. 2014;160(12):828–35. PMID: 24862434. 10.7326/M13-2529 24862434
54 National Heart Lung and Blood Institute. Quality Assessment Tool for Before-After (Pre-Post) Studies with No Control Group. https://www.nhlbi.nih.gov/health-pro/guidelines/in-develop/cardiovascular-risk-reduction/tools/before-after. Accessed: 9/12/2017.
55 Wells G, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomized studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.htm. Accessed: 9/12/2017.
56 Smith EA, Jacques-Carroll L, Walker TY, . The national Perinatal Hepatitis B Prevention Program, 1994-2008. Pediatrics. 2012;129(4):609–16. PMID: 22451702. 10.1542/peds.2011-2866 22451702
57 Stevens CE, Beasley RP, Tsui J, . Vertical transmission of hepatitis B antigen in Taiwan. N Engl J Med. 1975;292(15):771–4. PMID: 1113797. 10.1056/NEJM197504102921503 1113797
58 Machaira M, Papaevangelou V, Vouloumanou EK, . Hepatitis B vaccine alone or with hepatitis B immunoglobulin in neonates of HBsAg+/HBeAg- mothers: a systematic review and meta-analysis. The Journal of antimicrobial chemotherapy. 2015;70(2):396–404. PMID: 25362571. 10.1093/jac/dku404 25362571
59 Eke AC, Eleje GU, Eke UA, . Hepatitis B immunoglobulin during pregnancy for prevention of mother-to-child transmission of hepatitis B virus. Cochrane Database of Systematic Reviews. 2017;2:CD008545. PMID: 28188612. 10.1002/14651858.CD008545.pub2 28188612
60 Rajbhandari R, Barton K, Juncadella AC, . Discontinuity of care for mothers with chronic hepatitis B diagnosed during pregnancy. Journal of Viral Hepatitis. 2016;23(7):561–8. PMID: 26940754. 10.1111/jvh.12524 26940754
61 Pierce RL, Smith S, Rowe-West B, . Hepatitis B maternal screening, infant vaccination, and infant prophylaxis practices in North Carolina. Archives of Pediatrics & Adolescent Medicine. 1999;153(6):619–23. PMID: 10357304.10357304
62 Centers for Disease Control and Prevention. Prevention of perinatal hepatitis B through enhanced case management-Connecticut, 1994-95, and the United States, 1994. MMWR - Morbidity & Mortality Weekly Report. 1996;45(27):584–7. PMID: 9132578.9132578
63 Weerasinghe I, Bannister N, Huang V, . The Role of the Patient-Centered Medical Home in Addressing Hepatitis B Perinatal Transmission: Charles B. Wang Community Health Center’s Hep B Moms Program. AAPI Nexus: Policy, Practice and Community. 2014;12(1-2):140–60. PMID: None.
64 National Academies of Sciences Engineering and Medicine. A National Strategy for the Elimination of Hepatitis B and C: Phase Two Report. Strom BL, Buckley GJ, editors. Washington (DC): National Academies Press (US); 2017.
65 U.S. Department of Health and Human Services. National Viral Hepatitis Action Plan 2017-2020. www.hhs.gov/hepatitis/: 2017.