# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Iris Mabry-Hernandez, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Brandy Peaker, MD, MPH, at the Centers for Disease Control and Prevention, and Rajen Koshy, PhD, and Nahida Chakhtoura, MD, MsGH, at the National Institutes of Health, for providing federal partner review of the draft report; Sarah Schillie, MD, MPH, MBA, Matthew S. Chang, MD, and Su Wang, MD, MPH, who provided expert review of the draft report; Peter Miksovsky, MD, who served as a clinical consultant during the review process; Jennifer S. Lin, MD, MCR, for mentoring and project oversight; Smyth Lai, MLS, who conducted literature searches; and Katherine Essick for editorial assistance at the Center for Health Research.