# Chapter 4 Discussion

## Summary of Evidence

Two fair-quality observational studies provide evidence on the effectiveness of case management for delivering prophylaxis to prevent perinatal transmission of HBV, and evidence that over time, reductions in perinatal transmission have been observed for woman and infants enrolled in case management. These improvements may be owing to a combination of factors, such as improvements in the evidence-based protocols that are implemented in the programs, and refinements in the case management process whereby tracking of infants and delivery of interventions have improved. Changes in recordkeeping, loss to followup, and population demographics could also influence the reported findings, given that these are observational data. National data from the PHBPP in the United States provided evidence that case management for prevention of perinatal transmission is associated with low infection rates that have declined over time. At the same time, higher rates of maternal HBV case identification and infant program completion (serologic testing 2 years after birth) were reported. More complete data from a regional health system that employs a coordinated case management program is consistent with the national data trend, with rising rates of testing for HBV infection for case-managed infants, and the lowest rates of perinatal transmission observed in the most recent years (2006 to 2010).

Prior to the development of HBV prophylaxis, it was estimated that up to 40 percent of infants born to HBV-positive mothers would become infected.^57^ An established body of evidence has demonstrated the effectiveness of prophylactic interventions, as recommended by CDC and ACIP, for reducing the risk of perinatal transmission. Foundational evidence from an earlier era and observational data from case management programs in the modern era together support the value of prenatal screening to identify infants for prophylactic interventions. Screening identifies women whose infants would benefit from case management, through timely delivery of recommended prophylaxis. Infants born to HBV-positive women in case management programs exhibit very low and declining rates of perinatal transmission over time.

As in previous reviews on this topic, no comparative studies were identified on the benefits or harms of screening. Screening pregnant women for HBV infection is standard care, but recommended universal HBV vaccination of all infants at birth also serves as a safeguard to prevent infection among infants whose mothers’ infections are not identified through prenatal screening. A downward trend in perinatal HBV transmission in the United States as case management completion increased highlights the value of screening women to determine HBV status during pregnancy in the setting of universal birth vaccination. Even if universal birth vaccination recommendations were fully implemented, screening and case management may confer additional benefit for coordinating the delivery of additional interventions recommended for infants born to HBV-positive women. The additional benefit of HBIG administration at birth for vaccinated infants born to HBV-positive women was supported in a recent network meta-analysis, although most included studies in this review were among women who were HBeAg+ or had a high viral load and several studies were evaluated to have high risk of bias. Further research is needed to strengthen the evidence base with regard to protocols for HBIG administration at birth and potentially in the prenatal period.^25,^ ^58,^ ^59^ Limited evidence suggests potential preventive benefits of antiviral treatment before birth for women with high HBV viral loads.^48,^ ^49^

Screening for HBV infection during pregnancy facilitates entry into case management in the United States. The rate of women entering the PHBPP based on screening during pregnancy (i.e., women not already known to have an HBV infection) has not been reported; however, data from a large urban hospital in Boston spanning the years 1995 to 2014 indicated that more than one third (37%) of pregnant women with chronic HBV infection were initially diagnosed at the first prenatal visit.^60^

Women with poor access to health care are at greater risk of not being screened until delivery or not at all, reducing the time available to plan the best prophylactic intervention. Efforts are needed to improve outreach and screening for HBV infection and other preconception health risks to vulnerable populations.^61^ In particular, higher rates of chronic HBV infection are found among foreign-born women from countries where HBV prevalence is higher and infection is common in childhood. Thus, the highest seroprevalence among women of childbearing age occurs among foreign-born Asian and Pacific Islander women.^56^ Prenatal care that can address language and health care access barriers for this population may further reduce rates of perinatal transmission in the United States.

Public health policy and health institution practices play an important role in improving prevention of perinatal HBV transmission. Earlier evidence suggests that state and hospital policies requiring HBV screening increased the likelihood of women’s HBV-positive status being recorded in medical charts. Further, enhanced case management by health care delivery systems, including routine reminders, flags in patient charts, and standing orders for birth HBV vaccination, were shown to improve the receipt of timely HBV vaccination and HBIG administration.^62^ Demonstrations of improved intervention rates in clinical settings serving subpopulations with higher chronic HBV infection rates are particularly encouraging.^63^ Rates of HBV screening in pregnancy are high in the United States; research to ensure that case management care reaches women who screen positive may require a focus on health system quality improvement interventions.

## Review Limitations and Future Research Needs

For this review, we sought overarching evidence on populationwide screening programs for reducing perinatal transmission of HBV. Only two studies were identified that met the inclusion criteria for a KQ. The included studies, however, are highly relevant for evaluating recommended interventions for preventing perinatal transmission of HBV in the United States. It was not possible to identify studies that could disentangle the effects of prenatal screening from effects of universal birth HBV vaccination, as these practices emerged around the same time, and their contributions to prevention of perinatal transmission of HBV are confounded.

This review supports the broad conclusion that screening can facilitate the receipt of prophylactic interventions and referral to effective case management programs. There is foundational evidence on individual intervention effectiveness (HBV vaccination, HBIG administration) and data from case management programs demonstrating very low rates of perinatal transmission of HBV. There were no serious harms of screening or case management identified in the included studies, but theoretical harms, such as false-positive results and inappropriate entry into case management, would likely be corrected with additional testing in the PBHPP throughout the course of pregnancy.

The availability of effective interventions and their adoption by national case management programs will continue to be guided by emerging evidence and established practice. Recent reviews and recommendations continue to support the notion that active and passive prophylaxis likely provide the greatest degree of protection from HBV infection.^3,^ ^25^ Systematic reviews focused on the use of antiviral medications during pregnancy for women with an acute HBV infection and a high viral load have also identified the need for further research to prevent perinatal transmission in these highest-risk cases. Efforts to further increase the proportion of infants identified for and completing case management, accompanied by implementation of recommended interventions, may further reduce rates of perinatal transmission of HBV. More recent data from the PBHPP would be informative for understanding current program performance and research needs. Finally, research and targeted resources are needed to ensure that case management is effectively implemented and reaches vulnerable populations most at risk for perinatal transmission of HBV. Improving access to prenatal care, screening, and integration of public health and clinical health services to facilitate case management are among the strategies outlined to help eliminate perinatal HBV infection in the United States,^64^ a goal of the 2017–2020 National Viral Hepatitis Action Plan.^65^

## Conclusions

This evidence update includes two observational studies of case management interventions conducted in the United States, bolstered by a larger body of evidence establishing the effectiveness of interventions to prevent perinatal HBV transmission. The comprehensive strategy for the elimination of perinatal HBV transmission in the United States includes the use of routine screening of all women for HBV infection in pregnancy, along with universal HBV vaccination of all infants and additional prophylactic measures to those born to HBV-positive mothers. Within the U.S. public health system, case management programs can ensure implementation of recommended protocols for prevention of perinatal transmission of HBV. Although direct evidence of the effects of screening on perinatal transmission is not available, screening in pregnancy is an important step toward appropriate delivery of prophylactic interventions. Screening in pregnancy identifies women eligible for case management, which is associated with a very low risk of perinatal transmission. Until the public health goal of eliminating HBV infections in the United States is achieved, screening in pregnancy to identify opportunities to prevent perinatal transmission will remain important.