# Chapter 3 Results

## Literature Search

Our literature search yielded 5,688 unique citations. From these citations, we accepted 499 articles for review based on titles and abstracts (Appendix A Figure 1). After reviewing the full-text articles and conducting critical appraisal, we included two fair-quality studies for KQ 3. Appendix B contains a list of all full-text articles and their reasons for exclusion. No studies were excluded based on study quality.

No eligible studies were identified that directly investigated the population benefits of universal HBV screening in pregnancy. Broad criteria were used to identify potentially relevant studies based on title and abstract screening; however, no studies that examined the rates of HBV transmission before and after the implementation of a perinatal screening program were found. Many of the studies reviewed that were excluded focused on the rates of decline in HBV infection due to the implementation of targeted or universal vaccination programs or, particularly in the older literature, examined the comparative effectiveness of individual strategies for the prevention of HBV transmission (e.g., HBIG administration vs. placebo, various HBV vaccination doses) and did not address a KQ. Among studies evaluating case management programs, many reported outcomes at a single time point without a historical or geographical comparator necessary to establish program effectiveness. Harms outcomes were not reported in any of the studies reviewed for inclusion.

## Results of Included Studies

### KQ 1 What Are the Observed Population Benefits of Universal HBV Screening Programs During Pregnancy?

No eligible studies were identified that directly examined the population benefits of universal HBV screening in pregnancy. We did not find any studies comparing screened with unscreened populations that met the eligibility criteria. The primary reasons for exclusion of these studies were the lack of a comparator (i.e., data across time or locations) and lack of perinatal HBV transmission outcomes.

### KQ 2 What Harms Have Been Observed in Programs of Universal HBV Screening During Pregnancy?

No eligible studies were identified that directly examined the harms of universal HBV screening programs in pregnancy.

### KQ 3 What Is the Effectiveness of Case Management Programs to Prevent Perinatal Transmission Among HBV-Positive Pregnant Women?

We identified two studies that met the inclusion criteria for KQ 3—a fair-quality observational study reporting a historical trend in infant outcomes with infant case management provided through the PHBPP, which is administered by the CDC,^56^ and a fair-quality observational study reporting the trend in perinatal transmission associated with infant case management provided in a coordinated care health system (Kaiser Permanente Northern California).^53^

In addition to rates of perinatal transmission (key outcome), the studies reported time trend data on the estimated proportion of HBV-positive women identified for case management and the time trends in the proportion of their infants who received HBV vaccination at birth, vaccination series completion by 12 months, and postvaccination testing for HBV immunity or infection.

#### National PHBPP Study Results

Data from the PHBPP for a cohort of infants born from 1994 to 2008 were reported, with perinatal transmission outcomes reported for infants born from 1999 to 2008.^56^ The annual number of births to HBV-positive women were estimated in the study using national data (NHANES) on seroprevalence rates among women of childbearing age. These data indicate that foreign-born women identified as Asian or Pacific Islander had the highest seroprevalence rates (9%), followed by non-Hispanic black women (0.5%).^56^ Outcomes were reported by the PHBPP 2 years after the birth year and perinatal transmission rates could be estimated only among those infants for whom HBV serologic testing was complete.

There was a statistically significant increasing trend over time (1994 to 2008) in the estimated number of births to HBV-positive women in the United States (from 19,208 to 25,600; p<0.001) (Table 1). The proportion of infants born to HBV-positive women who were identified by the PHBPP for case management also increased over time, starting at 42.1 percent in 1994 and increasing to 47.9 percent in 2008 (p=0.002). Of the identified infants, 98 percent were case managed, and the number of case-managed infants increased over time, from 7,415 in 1994 to 12,033 in 2008 (p<0.001).

Table 1 Results From the PHBPP on Infants Born to HBV-Positive Women in the United States^56^

Outcome | Calculation | Time | Range
PHBPP coverage | Percentage of infants born to HBV-positive women in the United States^*^ identified for PHBPP case management | 1994–2008 | Increase from 42.1% in 1994 to 47.9% in 2008 (p=0.002). As estimated number of births continued to rise, stable coverage of ~50%.; Number of case-managed infants increased from 7,415 to 12,033.
Postvaccination serologic testing completed^†^ | N with serologic testing/N case managed | 1994–2008 | Increase from 25.1% in 1994 to 55.7% in 2008 (p<0.001).; Number of case-managed infants receiving serologic testing increased from 1,860 to 6,697.
HBV positivity among infants completing case management | N HBV infected/N serologically tested | 1999–2008 | Decrease from 1.9% in 1999 to 0.8% in 2008 (p<0.001)

* The study authors used deidentified U.S. natality and HBV prevalence data to calculate trends in the estimated number of births to HBV-positive women. Data were reported for women of childbearing age by race/ethnicity, primarily obtained through the National Health and Examination Survey. The number of women identified through the PHBPP for case management was then divided by this estimated number of births to HBV-positive women and reported by year.

† Within 24 months of birth.

Abbreviations: HBV = hepatitis B virus; N = number of persons; PHBPP = Perinatal Hepatitis B Prevention Program.

Serologic testing for HBV is an indicator of completed case management because it is conducted after the completion of the three-dose vaccination series (based on CDC recommendations, testing was done by ages 9 to 18 months over the study period) and determines whether prophylaxis was successful. Of the case-managed infants in PHBPP, rates of serologic testing within 24 months of birth increased over the study period, more than doubling from 25.1 percent in 1994 to 55.7 percent in 2008 (p<0.001). A statistically significant downward trend in the perinatal transmission rate from 1999 to 2008 was also reported. In 1999, of the 3,826 infants tested, 71 were infected with HBV (1.9%), and in 2008, of the 6,697 infants tested, 56 were infected (0.8%), a statistically significant decreasing trend (p=0.001).

An increasing number of the estimated cases of HBV infection among pregnant women in the United States were case managed through the PHBPP over the study period. Rates of HBIG administration and HBV vaccination at birth (>90%) and completion of the three-dose vaccination series by ages 6 to 8 months (>70%) among those infants who were case managed held steady, with statistically nonsignificant tests for trend (p=0.126 and p=0.734, respectively). There was, however, a decline in the proportion of case-managed infants who received the full HBV vaccination series by age 12 months (p<0.001), with rates dropping below 80 percent in 2001 from a high of 86 percent in 1994.

This observational study contributes evidence that the infant case management program, as implemented from 1994 to 2008, achieved improvements in identifying women with HBV infection and enrolling their infants, and maintained high levels of preventive interventions.

Reporting on the proportion of PHBPP case-managed infants lost to followup was required starting in 2004. From 2004 to 2008, there was not a statistically significant trend over time in loss to followup (range, 13% to 26%; p=0.126), but the lowest rate was reported in 2008. Reported reasons for loss to followup did not differ, with one exception: “family refused” increased as a stated reason for noncompletion of case management. Overall, the most common reasons reported were “moved out of country” (24%) or “could not locate” (33%).

The reductions in perinatal HBV transmission reported in this observational study could have been influenced by secular changes outside of the PHBPP (e.g., universal HBV vaccination practices). Within PHBPP, rates of HBIG administration and HBV vaccination at birth remained steady and high across the time period, ranging from 90 to 97 percent from 1999 to 2008, and completion of all three HBV vaccination doses by age 12 months, ranging from 78 to 80 percent for the same time period. Postvaccination serologic testing increased over this period, allowing calculation of perinatal transmission rates for a greater proportion of infants in PHBPP. The reported perinatal transmission rate could also have been affected by changes in recordkeeping and tracking of infants in PHBPP, with the cases at greater risk potentially least likely to have completed the program. Observed improvements in serologic testing and reduced loss to followup, however, suggest that data may be more complete in recent years.

The loss to followup in the PHBPP study was nearly one quarter of women in 2004 and just slightly more than 1 in 10 women in the most recent year reported. The loss to followup in the PHBPP program highlights the challenges of studying and tracking the population at greatest risk of perinatal HBV transmission, since populations most at risk, such as immigrants, lower-income populations, and women with substance abuse disorders, are also more likely to face instability in housing, employment, and health care access. The available data suggest that followup in PHBPP improved over time, possibly increasing the presence of higher-risk infants in the study data over time, so the observed trend is more likely an underestimate of the benefit of case management. Overall, completion of PHBPP case management is associated with low and declining rates of perinatal transmission.

#### Health System Study Results

An observational study using data on births (n=4,446) to HBV-positive women who received clinical care in a coordinated, managed care health setting reported on the trend over time from 1997 to 2010 in perinatal transmission of HBV (Table 2).^53^ The health system commenced the Regional Perinatal Screening Hepatitis B program in 1988. Women in the health system are screened during prenatal care and, if found to be HBV positive, are entered into the health system’s case management system (“tracking program”) to support on-time delivery of immunoprophylactic interventions and followup testing. Of the 4,446 infants born to HBV-positive pregnant women identified from 1997 to 2010, most received HBIG administration and HBV vaccination within the recommended time frames (i.e., >97% received HBIG administration and HBV vaccination within 12 hours of birth). Eighty-five percent of infants (n=3,353) were tested for HBV infection, with the highest rates of testing reported in recent years (93% for 2006 to 2010, before age 12 months). The overall rate of perinatal transmission over the time period was very low at 0.75 cases per 100 tested infants (25/3,353). A decreasing trend was observed in perinatal infection from 1997 to 2010 (incident rate ratio, 0.90 [95% confidence interval, 0.82 to 1.00]). This trend could be attributed to changes in case management (e.g., viral load testing in later years), to differences in case ascertainment (i.e., retroactive serologic testing in earlier years, more infants tested in later years), or a combination of these factors, as well as other unmeasured factors. Overall, the study demonstrates high effectiveness of modern prophylactic interventions for insured pregnant women and infants case managed in a coordinated health system.

Table 2 Perinatal Transmission Among Infants Born to HBV-Positive Women Enrolled in KPNC Case Management, 1997–2010^53^

Outcome | Total 1997–2010 | 1997–2000 | 2001–2005 | 2006–2010 | Trend
Infants born to HBV-positive women at KPNC, N (range per year) | 4,446 (261 to 381) | 1,152 | 1,616 | 1,678 | NR
Postvaccination serologic testing for infection completed, N (%) | 3,353 (85) | 715 (70) | 1,235 (86) | 1,403 (93) | NR
Rate of HBV positivity among infants tested for HBV infection (HBsAg+)^*^ | 0.75 (0.48 to 1.10) | 1.12 (0.42 to 2.21) | 0.81 (0.39 to 1.49) | 0.50 (0.20 to 1.03) | Poisson IRR, 0.90 (95% CI, 0.82 to 1.00)

* Rate per 100 children tested; Poisson distribution-based 95% CI.

Abbreviations: CI = confidence interval; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; IRR = incident rate ratio; N = number of persons; KPNC = Kaiser Permanente Northern California.

Table 3 Snapshot of the Evidence

| Rationale and foundational evidence for previous USPSTF recommendations^40,^ ^41,^ ^52^ | New evidence findings | Limitations of new evidence | Consistency of new evidence with foundational evidence and current understanding
Benefits | Screening: Screening is highly accurate and identifies infants at risk of perinatal transmission. Universal screening is important because known risk factors only present in 35% to 65% of HBV-positive pregnant women.; Treatment: There are effective preventive measures (i.e., HBV vaccination within 12 hours of birth, HBIG administration) for preventing perinatal transmission and sequelae. | Screening: No new evidence.; Treatment (case management): Two observational studies of the effectiveness of case management programs for infants at risk for perinatal HBV transmission in the United States; one study of the national public health system program and one study in an integrated health system.; Case management in the integrated health system attained very high rates of on-time prophylaxis completion.; Very low perinatal transmission rates reported in most recent years (0.5% to 0.8%) that had been trending downward over time. | Observational studies that cannot control for the effects of trends over time in historical, population, or recordkeeping factors that could also influence estimates.; Program data are not complete and based on unverified reports by physicians, hospitals, and laboratories; loss to followup, missing data, and differences in data collection procedures may have had a greater effect on data estimates from earlier years. | The included observational studies suggest improving trends for perinatal transmission prevention among infants who have completed case management programs.; A high proportion of case-managed infants are documented as having HBIG administration and HBV vaccination at birth and three vaccine doses by 12 months.; Screening for HBV infection in pregnancy can identify infants at risk of perinatal transmission to identify them for case management.
Harms | Screening: Highly accurate test, low false-positive rate, no serious harms reported.; Treatment: None identified, universal vaccination of all infants recommended regardless of maternal HBV status; HBIG harms not reported. | Screening: No new studies of screening were identified.; Treatment: No harms of screening or case management were reported in the included study. | Program data do not capture potential harms of screening, other than reasons for loss to case management program followup. | No harms of screening or case management reported in foundational or included evidence.

Abbreviations: HBV = hepatitis B virus; N = number of persons; PHBPP = Perinatal Hepatitis B Prevention Program; HBIG = hepatitis B immune globulin; U.S. Preventive Services Task Force.

### KQ 4 What Harms Have Been Observed in Case Management Programs to Prevent Perinatal Transmission Among HBV-Positive Pregnant Women?

No eligible studies were identified that reported on harms of case management programs for pregnant women living with HBV infection.