# Chapter 2 Methods

## Scope and Purpose

Screening for HBV infection in pregnancy has been a standard of care for more than 30 years, with an “A” recommendation from the USPSTF from its 1996 inception.^40,^ ^41,^ ^52^ In the United States, the aim of screening for HBV infection in pregnancy is to identify women at risk of transmitting the infection to their infants to ensure the delivery of effective prophylactic interventions. In the United States, a federal CDC program, the PHBPP, funds, coordinates, and documents the delivery of effective interventions to prevent perinatal transmission through case management programs. Case management is also practiced in some private health care systems, where the care of women who screen positive for HBV is organized through patient tracking and evidence-based care protocols.^53^ The scope of this review was designed to focus on overarching effectiveness and potential harms of screening and the effectiveness and harms of case management to prevent perinatal transmission.

The USPSTF has based previous recommendations for this topic on the following factors, and previous evidence updates have not identified new or contrary evidence: 1) screening for HBV infection in pregnant women is feasible in primary care and has high test accuracy, and 2) there are effective interventions to prevent vertical transmission of HBV infection that are rarely harmful.

Given the lack of formal trials evaluating the effectiveness of screening for HBV infection in pregnancy, the included Key Questions (KQs) were scoped to allow for observed population changes in HBV outcomes within geographic and historical comparisons of screening practices.

Given the recognized effectiveness of individual interventions (i.e., HBV vaccination, HBIG administration) and the available guidance on protocols for prophylaxis from CDC and ACIP, the KQs related to treatment guiding this review were focused on the effectiveness of case management programs. The focus on case management is motivated by the fact that it is the recommended intervention in the United States for all HBV-positive pregnant women. Thus, the KQs were intended to identify evidence on the effects of screening and case management on perinatal transmission of HBV infection and any associated harms.

## Analytic Framework and KQs

In consultation with members of the USPSTF, we developed an analytic framework (Figure 1) and four KQs to guide the literature search, data abstraction, and data synthesis.

Figure 1 Analytic Framework

Figure is the analytic framework that depicts the four Key Questions to be addressed in the systematic review. The figure illustrates how screening for hepatitis B virus infection in pregnant women may result in improved health outcomes (KQ1) or potential harms (KQ2). Additionally, the figure illustrates how programs to prevent vertical transmission in pregnant women with hepatitis B may result in improved health outcomes (KQ3) or potential harms (KQ4).

### KQs

1. What are the observed population benefits of universal HBV screening programs during pregnancy?
2. What harms have been observed in programs of universal HBV screening during pregnancy?
3. What is the effectiveness of case management programs to prevent perinatal transmission among HBV-positive pregnant women?
4. What harms have been observed in case management programs to prevent perinatal transmission among HBV-positive pregnant women?

## Data Sources and Searches

We conducted a literature search of MEDLINE, PubMed Publisher-Supplied Records, the Cochrane Database of Systematic Reviews, the Cochrane Central Register of Controlled Trials, the Cumulative Index for Nursing and Allied Health Literature, Embase, and PsycInfo from January 1, 1986 to May 3, 2018. The search start date was selected to coincide with the availability of the recombinant vaccine for HBV in the United States. We worked with a research librarian to develop our search strategy, which was peer reviewed by a second research librarian (Appendix A). We supplemented these searches by reviewing reference lists of recent reviews and primary studies. The searches were limited to articles published in English. We managed literature search results using Endnote® version X7 (Thomson Reuters, New York, NY).

## Study Selection

We developed specific inclusion criteria to guide study selection (Appendix A Table 1). Two reviewers independently reviewed the titles and abstracts of all identified articles using DistillerSR (Evidence Partners, Ottawa, Canada). Two reviewers then independently evaluated the full text of all potentially relevant articles. We resolved differences in the abstract or full-text review by discussion. For all KQs, we included studies conducted in countries categorized as “high” or “very high” on the Human Development Index. Studies conducted in settings without universal birth HBV vaccination programs were excluded, since findings would not be applicable to the U.S. setting. For all KQs, we included randomized and nonrandomized controlled trials and large observational cohort studies, including ecologic studies and those with historical or geographical comparator controls. We excluded editorials, narrative reviews, and case studies.

For KQs 1 and 3, studies reporting on the perinatal transmission rates for screening and case management programs were considered for inclusion. For KQs 2 and 4, evidence on the potential harms of screening and case management programs, including potential psychological, psychosocial, or other negative consequences for pregnant women or their children, were considered for inclusion.

## Quality Assessment and Data Abstraction and Synthesis

Two reviewers independently assessed the methodological quality of each included study using predefined criteria based on the Newcastle-Ottawa scale and the National Heart, Lung, and Blood Institute’s Quality Assessment Tool for Before‐After (Pre‐Post) Studies With No Control Group (Appendix A Table 2);^54,^ ^55^ disagreements were resolved by discussion. We extracted important study design, setting, and participant characteristics (e.g., demographic characteristics, health conditions) and outcomes and synthesized the evidence from included studies in a narrative format.

## Expert Review and Public Comment

A draft Research Plan for this review was available for public comment from July 13, 2017 to August 9, 2017. Comments received during this period were reviewed, considered, and addressed as appropriate. The full draft report was shared with invited expert reviewers and federal partners. We compiled the comments received from these invited experts and addressed them in the report when appropriate. The draft version of this report was posted for public comment on the USPSTF Web site from January 8, 2019 to February 4, 2019. Comments received during this period were reviewed and considered, and minor changes were made to the contextual information in the report. No changes were made to the evidence or to our conclusions.

## USPSTF Involvement

This evidence update was funded by AHRQ under a contract to support the USPSTF. We consulted with USPSTF members during development of the Research Plan (i.e., KQs, analytic framework, and inclusion criteria). An AHRQ Medical Officer provided project oversight, reviewed the draft and final versions of the evidence update, and assisted with public comment on the Research Plan and draft report. The USPSTF and AHRQ had no role in the study selection, quality assessment, or writing of the evidence update.