# Chapter 1 Introduction

## Condition Background

### Condition Definition

Hepatitis B is a viral infection of the liver caused by the hepatitis B virus (HBV). The presence of the hepatitis B surface antigen (HBsAg+) indicates an acute (i.e., <6 months) or chronic HBV infection. Hepatitis B e-antigen (HBeAg+) positivity is associated with active viral replication, high HBV DNA viral load, and higher infectivity. In the absence of HBsAg, the existence of HBV core antibodies may indicate that a person was previously infected with HBV. The presence of HBV surface antibodies indicates that the person has achieved immunity to HBV following an infection or from vaccination. HBV is transmitted through contact with the blood or bodily fluids of an infected person. In countries with high HBV prevalence, perinatal transmission of infection from mother to neonate at the time of delivery is common.^1^ Consequently, adults living with HBV in the United States who were born in high-prevalence countries often contracted the infection in childhood.^2^ New cases of HBV infection among adults in the United States are primarily transmitted through sexual intercourse and intravenous drug use. For children born in the United States, the primary source of infection is vertical transmission from an infected mother either in utero or peripartum, with the greatest risk occurring when the newborn is exposed to vaginal blood or secretions at delivery.^3^

### Disease Prevalence and Burden of Disease

HBV remains an important global public health concern despite the existence of an effective vaccine and antiviral agents. Globally, in 2015, chronic HBV infection (measured by seroprevalence of HBsAg) was estimated to affect 3.5 percent of the population (approximately 257 million persons), including an estimated 65 million women of childbearing age. The highest prevalence rates reported by the World Health Organization (WHO) occur in the African (6.1%) and Western Pacific regions (6.2%), with recent modeling estimates finding higher prevalence for specific subregions.^4^ Based on population, the largest number of persons living with chronic HBV infection are in the Western Pacific region and the smallest number are in the Americas.^4^

Data from the National Health and Nutrition Examination Survey (NHANES) from 2007 to 2012 estimate that 10.8 million persons in the United States had ever been infected with HBV.^5^ It is estimated that 847,000 persons (0.3% of the population) were living with chronic infection in 2011 to 2012.^5^ However, NHANES may underestimate the prevalence of chronic infections due to undersampling in key subgroups (i.e., persons born in high-prevalence countries, living in institutions, or who are incarcerated).^2,^ ^6^ Estimates attempting to account for this underestimation suggest there may be more than 2 million persons living with chronic HBV infection in the United States.^2,^ ^6^ The highest rates of chronic HBV infection were identified in non-Hispanic Asian (3.1%) and non-Hispanic black (0.6%) populations.^5^ Foreign-born Americans have a 10-fold higher prevalence than persons born in the United States (1.1% vs. 0.1%). The prevalence in women is reported to be lower than in men (0.2% vs. 0.4%).^5^

Beginning in 1991, the United States implemented a public health strategy to control HBV including: screening all pregnant women for HBV infection, universal vaccination of all infants at birth, routine vaccination of previously unvaccinated children, and vaccination of adults at high risk for HBV infection.^7^ Over time, immunity has increased in the United States from 21.7 percent in 1999 to 2006 to 25.1 percent in 2007 to 2012. Rates of immunity are highest among younger persons, with 44.4 percent immunity in persons ages 6 to 19 years compared with 8.7 percent immunity in those age 50 years or older, based on NHANES data from 2007 to 2012. However, while rates of immunity in older persons have increased over time, the rates of immunity in children ages 6 to 19 years have significantly decreased from the previously recorded rate of 56.8 percent in the years 1999 to 2006.^5^

According to data from the Nationwide Inpatient Sample from 1998 to 2011, the prevalence of maternal HBV infection was 85.8 cases per 100,000 deliveries (0.09% of liveborn singleton deliveries in the United States).^8^ Rates of maternal HBV infection have shown an annual increase of 5.5 percent since 1998 and have increased among nearly every population subgroup, especially among women age 30 years and older. Older maternal age was significantly associated with a higher rate of HBV infection, with mothers age 30 years and older 2.3 times more likely than teenage mothers to be infected, likely due to the higher rates of vaccination among younger women of childbearing age. Non-Hispanic black and Asian women were estimated to have a 5- and 12-fold increased odds of HBV infection, respectively.^8^ According to data from the National Health Interview Survey from 2013 to 2015, the greatest risk indicators for HBV infection among women ages 18 to 44 years were lower education, higher poverty levels, and lack of insurance coverage.^9^ One factor contributing to the rise in rates is increasing immigration of foreign-born women from areas with a higher prevalence of HBV, particularly from Asian countries.^10^ The majority of cases of HBV infection in the United States are among persons who emigrated from endemic regions, were born to immigrant parents, or were exposed through close household contact with these HBV-positive persons.^11–13^ Some of the observed increase in HBV infection among pregnant women also may be attributed to increased case finding with the advent of screening for HBV infection in pregnant women.^8^

### Natural History

An estimated 70 percent of healthy adults with acute HBV infection are asymptomatic, and the remainder have symptoms of liver disease (e.g., abdominal pain, jaundice).^14^ Fewer than 1.5% of acute HBV infections are fatal.^7^ The progression to chronic HBV infection (infection beyond 6 months) varies dramatically depending on age at the time of initial infection. Chronic infections develop in 80 to 90 percent of infants (age <1 year) infected with HBV, in approximately 25 to 30 percent of acute infections before age 6 years, and in less than 1 to 12 percent of acutely infected older children or adults.^7,^ ^11^ The remaining individuals generally resolve their HBV infection without sequelae and develop immunity. Chronic HBV infection can result in serious long-term health complications such as chronic hepatitis, cirrhosis, and hepatocellular carcinoma. Up to 25 percent of persons who become chronically infected in childhood and 15 percent of persons infected in adulthood will die prematurely from cirrhosis or liver cancer.^7^

The primary well-established risk of harm associated with maternal HBV infection is perinatal transmission to the infant, occurring most commonly through the process of delivery (caesarean or vaginal delivery). Higher levels of maternal HBV DNA occurring with active viral replication are strongly predictive of perinatal transmission; among HBeAg- mothers, the perinatal transmission risk is approximately 30 percent, but among HBeAg+ mothers, the risk rises to 85 percent.^7^ However, viral replication is present in some HBeAg- women, and evidence suggests that viral load, rather than HBeAg marker status, may be most indicative of the risk of transmission.^15,^ ^16^

## Rationale for HBV Screening in Pregnancy and Interventions to Prevent Perinatal Transmission and Current Clinical Practice

Prevention of perinatal transmission of HBV infection hinges upon the timely administration of prophylaxis, particularly for infants whose mothers are HBV positive.^17^ HBV screening has very high accuracy (sensitivity and specificity >98%), as established in studies by the CDC, U.S. Food and Drug Administration, and WHO in the 1980s and 1990s, when the tests were first developed.^18,^ ^19^ Routine HBV screening in prenatal care is intended to ensure preventive interventions, including those recommended for all newborns regardless of HBV status (i.e., HBV vaccination). In the United States, screening facilitates entry into a national case-management program tasked with ensuring and documenting the delivery of evidence-based prophylaxis for HBV-exposed infants.

Beginning in 1990, the PHBPP, funded by the CDC, was developed to identify HBV-positive pregnant women and ensure that their infants receive timely, evidence-based postexposure prophylaxis.^10^ The Public Health Services Act, Section 317, mandates the Immunization Grants Program and the Prevention and Public Health Funds, which support the PHBPP in 64 jurisdictions: 50 states, six cities, five territories, and three freely-associated island nations.^20,^ ^21^ Grant recipients are required to submit yearly reports that include specific information on the number of infants born to HBV-positive women identified by the program, timing of prophylactic interventions, serologic testing, and loss to followup.^10^ The CDC Advisory Committee on Immunization Practices (ACIP) recommends that all HBV-positive pregnant women be referred to their jurisdiction’s PHBPP for case management to ensure their infants receive timely prophylaxis and followup.^7^

Since its licensure in 1981, the HBV vaccination remains the most effective measure to control and prevent HBV infection, perinatal transmission, and long-term sequelae.^22,^ ^23^ ACIP first recommended universal HBV vaccination for infants in 1991.^24^ Systematic reviews and clinical trials have consistently demonstrated high seroprotection rates among infants and healthy adults age 40 years or younger who have received the complete vaccine series.^22,^ ^25–27^ Prior to the development of the HBV vaccination, HBIG administered within 12 hours of delivery was shown to be effective for reducing perinatal transmission by providing passive immunity and temporary protection (i.e., 3 to 6 months) from HBV infection.^3^ The most recent recommendation (2018) is for all infants to receive their first dose of the HBV vaccination within 24 hours, and for infants born to HBV-positive mothers to receive infant vaccination and HBIG administration within 12 hours of birth.^7^

Since the introduction of standard guidelines for HBV postexposure prophylaxis in 1991, cases of chronic HBV infection in infants have declined by 75 percent; however, the CDC estimates that between 2000 and 2009 there were 800 to 1,000 infants (3.8% of babies born to HBV-positive mothers) infected each year in the United States.^10^ Most of these cases occurred among infants of HBeAg+ women with high viral loads, with some infections theorized to occur in utero.^5^

Since 2015, the American Association for the Study of Liver Diseases has recommended the use of antiviral therapy to reduce perinatal HBV transmission in women with a high viral load (>200,000 IU/mL).^11,^ ^28^ This recommendation was incorporated into the CDC/ACIP guidance in 2018.^7^

While screening for HBV infection in pregnant women has been universally recommended for decades, it is not fully implemented in prenatal care services. As of December 2013, 26 states required all pregnant women to be screened for HBV infection, with 19 of these states mandating that screening occur at the first prenatal visit or shortly thereafter.^29^ However, not all providers are aware of these legal requirements or the fact that HBV is a reportable infection.^30^ Based on medical claims records from 2013 to 2014, 88 percent of commercially-insured women received HBV testing during pregnancy, with 60 percent tested during the first trimester; however, rates were lower for women enrolled in Medicaid, with 84 percent tested, but only 39 percent during the first trimester.^31^ In addition, universal vaccination of all infants within the first 24 hours is recommended, but in 2016, only 71 percent of all infants born in the United States received their first HBV vaccination within 3 days of birth, likely owing to patient and health system variation in adherence to recommendations. Due to the incomplete vaccination coverage at birth, in 2016 ACIP removed previously permissive language that had allowed providers to consider delaying the birth dose, and in 2017, receipt of HBV vaccination at birth increased to 74%.^32^ In 2017, 91 percent of U.S.-born children were fully immunized (i.e., received all three doses) by age 3 years.^32,^ ^33^

## Rationale and Supporting Evidence for Previous USPSTF Recommendations

No randomized trials of screening effectiveness for reducing HBV vertical transmission or health outcomes have been identified in prior USPSTF reviews. The original 1996 “A” recommendation to screen all pregnant women for HBV infection was based on reports showing that screening tests for HBV infection have high accuracy, and evidence from controlled trials and observational studies suggesting that neonatal vaccination and HBIG are effective for preventing perinatal transmission. The rationale for universal screening was based on evidence that identifiable risk factors (e.g., multiple sexual partners, exposure to human blood, contact with an infected person, travel to high-prevalence region) were present in only 35 to 65 percent of HBV-positive pregnant women.^34–39^ In 2004 and again in 2009, the USPSTF reaffirmed its recommendation using brief evidence updates.^40,^ ^41^

Since the original 1996 recommendation statement, updated reaffirmation reviews for the USPSTF have found little additional evidence on the effectiveness or harms of screening for and treatment of HBV infection in pregnancy. No studies meeting inclusion criteria were identified, but limited observational evidence supporting the effectiveness of prophylaxis has been cited in reaffirmation reviews.^42–45^ In 2009, no new trials of prenatal screening or newborn prophylaxis for HBV infection were identified, and a cited Cochrane review on HBV vaccination only included studies published prior to 1996.^46,^ ^47^ No previous reviews or new studies addressing the harms (e.g., consequences of a false-positive test result) were identified. No new evidence was found for the benefits or harms of HBV screening in pregnant women in either evidence update.^42,^ ^46^

Recent reviews, including a network meta-analysis, support the preventive effectiveness of HBIG and HBV vaccination and, more recently, the prenatal use of antiviral medication.^25,^ ^48–50^ These reviews cite evidence limitations with regard to setting, sample size, and study protocols, and the need for further research. In particular, additional studies are needed on prenatal use of antiviral medication, which may further reduce perinatal transmission beyond the already low rates observed when HBV vaccination and HBIG are administered. A 2017 systematic review of comparative trials through August 2016 (n=599 pregnancies) demonstrated that tenofovir significantly reduced the risk of infant infection when combined with HBIG and HBV vaccination.^48^ In the trials, tenofovir was administered in the second or third trimester among HBV-positive women with high viral loads (HBV DNA ≥200,000 IU/mL).^48^ A 2016 systematic review of randomized and observational studies drew similar conclusions and reported no increased risk of adverse maternal or fetal outcomes (e.g., congenital malformation rate, prematurity rate, Apgar scores) associated with antiviral treatment.^49^ Case management programs are guided by regular updates on evidence-based practices from ACIP and CDC for prevention of perinatal transmission. Accordingly, new guidelines in January 2018 recommended testing for viral load and treatment with antiviral therapy in addition to established HBV vaccination and HBIG practices.^7^ Evidence in this area is still emerging. Most recently, a double-blind placebo-controlled trial (n=331) of tenofovir conducted in Thailand reported null findings for antiviral treatment coupled with HBIG and HBV vaccination, but the trial was underpowered given the low perinatal transmission rates (0 infections in the intervention group and 3 infections in the placebo group; p=0.12).^51^ The trial also did not identify a statistical difference in the rate of adverse events for women or infants.