# Appendix B Excluded Studies

Exclusion Criteria Code | Exclusion Criteria
1 | Relevance
2 | Design
3 | Not primary data
4 | Not high/moderate Human Development Index
5 | Setting does not include universal vaccination
6 | Population
7 | Hepatitis detected postpartum
8 | Not an included intervention
9 | Study of individual treatment components
10 | No universal screening
11 | Lack of relevant comparator
12 | No relevant outcomes or incomplete outcomes reporting
13 | Full text unavailable

Reference | Exclusion Code
The Cochrane Database of Systematic Reviews - Issue 11 of 2010. J Evid Based Med. 2010;3(4):226-7. | 3
Further preventing mother to child hepatitis B transmission. J Paediatr Child Health. 2017;53(2):201. | 3
CDC recommends a comprehensive strategy to eliminate HBV. Am Fam Physician. 1992;45(4):1912-4, 7. | 3
Many chronically infected HBsAg positive pregnant women are not being identified. Michigan Nurse. 2009;82(5):28. | 3
Universal prenatal screening for hepatitis B. Emerg Med. 1990;22(17):51-4. | 3
Prenatal screening for infectious diseases. ACOG Clin Rev. 2004;9(2):5-6. | 3
Reduction in hepatitis B transmission to infants. AIDS Hepatitis Digest. 2011;141:7-8. | 13
Test all pregnant women for hepatitis B? Patient Care. 1988;22(5):23-4. | 3
Abara WE, Cha S, Malik T, et al. Prenatal screening for and prevalence of hepatitis B surface antigen in pregnant women and prevention of transmission to infants born to infected mothers-Guam, 2014. J Pediatric Infect Dis Soc. 2018;7(4):290-5. | 12
Abara WE, Cha S, Malik T, et al. Hepatitis B surface antigen screening among pregnant women and care of infants of hepatitis B surface antigen-positive mothers - Guam, 2014. MMWR Morb Mortal Wkly Rep. 2017;66(19):506-8. | 12
Abass F, Thomas RD, Rajkumar A, et al. Controlling perinatally acquired hepatitis B. Indian J Pediatr. 2001;68(4):365. | 3
Adamo B, Stroffolini T, Sagliocca L, et al. Ad hoc survey of hepatitis B vaccination campaign in newborns of HBsAg positive mothers and in 12-year-old subjects in southern Italy. Vaccine. 1998;16(8):775-7. | 12
Addidle M. Impact of universal hepatitis B vaccination on antenatal hepatitis B prevalence in the Midlands region of the North Island, New Zealand. N Z Med J. 2011;124(1332):40-4. | 12
Agbim U, Jaffe A, Verna EC, et al. Evaluation of hepatitis B management among peripartum women in an urban setting. Gastroenterol. 2017;152(5):S1084. | 12
Al-Mandeel HM, Alansary M, Algawahmed F, et al. Seroprevalence of hepatitis B and C, and human immunodeficiency viruses in Saudi pregnant women and rates of vertical transmission. Kuwait Med J. 2015;47(3):221-4. | 11
al-Owais A, al-Suwaidi K, Amiri N, et al. Use of existing data for public health planning: a study of the prevalence of hepatitis B surface antigen and core antibody in Al Ain Medical District, United Arab Emirates. Bull World Health Organ. 2000;78(11):1324-9. | 12
Alavian SM. Immigration and knowledge, education, and practices regarding chronic hepatitis B in pregnancy. Ann Gastroenterol. 2018;31(3):384. | 3
Alavian SM, Ebrahimi E, Abedini M. Necessity for hepatitis B surface antigen screening in pregnant females in Iran. Iran Red Crescent Med J. 2016;18(9):e40844. | 3
Alswaidi FM, O’Brien SJ. Is there a need to include HIV, HBV and HCV viruses in the Saudi premarital screening program on the basis of their prevalence and transmission risk factors? J Epidemiol Community Health. 2010;64(11):989-97. | 1
Alter MJ. Epidemiology of hepatitis B in Europe and worldwide. J Hepatol. 2003; 39(Suppl 1):S64-9. | 3
American Academy of Pediatrics Committee on Infectious Diseases. Universal hepatitis B immunization. Pediatrics. 1992;89(4 Pt 2):795-800. | 3
Anderson SR, Righarts A, Maguire H. Surveillance of antenatal infections-HIV, hepatitis B, syphilis and rubella susceptibility in London. Commun Dis Public Health. 2004;7(4):251-7. | 12
Anonymous. Prevention of transmission of hepatitis B: responsibilities of healthcare providers. J Arkansas Med Soc. 1998;94(8):365-6. | 3
Anonymous. Prevention of perinatal transmission of hepatitis B virus: prenatal screening of all pregnant women for hepatitis B surface antigen. JAMA. 1988;260(2):165, 69-70. | 3
Anonymous. Two research projects seek to improve immunization practices. Bull Pan Am Health Organ. 1992;26(1):96-7. | 3
Anonymous. Universal antenatal screening for hepatitis B and immunisation of babies at risk. Commun Dis Rep CDR Wkly. 1998;8(32):281, 4. | 3
Anonymous. Should all pregnant women be screened for hepatitis B surface antigen? Med J Aust. 1989;150(6):346, 8. | 12
Anonymous. Prevalence of HBsAg in UK population. Br Med J Clin Res Ed. 1987;294(6563):57. | 12
Anonymous. From the Centers for Disease Control and Prevention. Maternal hepatitis B screening practices-California, Connecticut, Kansas, and United States, 1992-1993. JAMA. 1994;271(23):1819-20. | 12
Anonymous. Hepatitis B alert! J Okla State Med Assoc. 1996;89(8):297-9. | 3
Anonymous. Universal hepatitis B screening in pregnancy. Am Fam Physician. 1988;38(4):92, 4, 7. | 3
Anonymous. Perinatal transmission of hepatitis B in Kansas. Kans Med. 1993;94(1):20-1. | 2
Anonymous. Infant HBV immunisation. Commun Dis Rep CDR Wkly. 1992;2(30):133. | 11
Arima S, Michitaka K, Horiike N, et al. Change of acute hepatitis B transmission routes in Japan. J Gastroenterol. 2003;38(8):772-5. | 6
Aydin G. The investigation and follow up of HBsAg positive pregnant women and their babies. Hepatol Int. 2015;9(1):S29. | 11
Azzopardi Micallef D, Mamo N, Micallef Fava A, et al. Management of pregnancy complicated by hepatitis B and C in Malta. Int J Gynecol Obstet. 2012;119(S3):S700-1. | 3
Baird J, Hammond M, Barker M. Implementation of universal antenatal screening for HIV and hepatitis B-lessons for future work. J Public Health Med. 2003;25(2):171-3. | 12
Baker DA, Bienstock J, Metz G, et al. Serologic screening of pregnant women at high risk for transmitting hepatitis B to their newborn. Bull N Y Acad Med. 1986;62(3):282-6. | 12
Balogun MA, Ramsay ME, Fairley CK, et al. Acute hepatitis B infection in England and Wales: 1985-96. Epidemiol Infect. 1999;122(1):125-31. | 6
Banatvala JE, Chrystie IL, Palmer SJ, et al. Retrospective study of HIV, hepatitis B, and HTLV-I infection at a London antenatal clinic. Lancet. 1990;335(8693):859-60. | 12
Barbosa C, Smith EA, Hoerger TJ, et al. Cost-effectiveness analysis of the national Perinatal Hepatitis B Prevention Program. Pediatrics. 2014;133(2):243-53. | 2
Barr D, Hershow R, Furner S, et al. Assessing prenatal hepatitis B screening in Illinois with an inexpensive study design adaptable to other jurisdictions. Am J Public Health. 1999;89(1):19-24. | 11
Bascom S, Miller S, Greenblatt J. Assessment of perinatal hepatitis B and rubella prevention in New Hampshire delivery hospitals. Pediatrics. 2005;115(5):e594-9. | 11
Batayneh N, Bdour S, et al. Risk of perinatal transmission of hepatitis B virus in Jordan. Infect Dis Obstet Gynecol. 2002;10(3):127-32. | 12
Beck CR, MacGregor V, Makki S, et al. An audit of neonatal and infant hepatitis B immunisation and serological testing in two counties of England, 2007-12. J Infect Prev. 2014;15(5):182-8. | 11
Bergin H, Wood G, Walker S, et al. Successful implementation of new management guidelines and a specialized clinic for hepatitis B virus positive pregnant women. Aust N Z J Obstet Gynaecol. 2016;56(S1):21. | 11
Birnbaum JM, Bromberg K. Evaluation of prophylaxis against hepatitis B in a large municipal hospital. Am J Infect Control. 1992;20(4):172-6. | 12
Biroscak BJ, Fiore AE, Fasano N, et al. Impact of the thimerosal controversy on hepatitis B vaccine coverage of infants born to women of unknown hepatitis B surface antigen status in Michigan. Pediatrics. 2003;111(6 Pt 1):e645-9. | 12
Borchardt SM, Kocharian A, Hopfensperger D, et al. Prevention of perinatal transmission of hepatitis B virus: assessment among Wisconsin maternity hospitals. WMJ. 2016;115(2):74-9; quiz 80. | 12
Borgia G, Maraolo AE, Gentile I. Hepatitis B mother-to-child transmission and infants immunization: we have not come to the end of the story yet. Infect Dis (Lond). 2017;49(8):584-7. | 3
Børresen ML, Koch A, Biggar RJ, et al. Effectiveness of the targeted hepatitis B vaccination program in Greenland. Am J Public Health. 2012;102(2):277-84. | 11
Bortolotti F, Cadrobbi P, Armigliato M, et al. Prognosis of chronic hepatitis B transmitted from HBsAg positive mothers. Arch Dis Child. 1987;62(2):201-3. | 11
Boxall E. Universal immunization of babies against hepatitis B. AIDS Hepatitis Digest. 2005;108:2-3. | 3
Boxall EH. Antenatal screening for carriers of hepatitis B virus. BMJ. 1995;311(7014):1178-9. | 3
Boyles S. Is universal better than selective immunization in developing world? Vaccines (HBV). Hepatitis Wkly. 1998;7-8. | 3
Boyles S. Transmission (HBV). Centralized management key to preventing perinatal hepatitis. Health Letter CDC. 1997;13-4. | 13
Bracciale L, Fabbiani M, Sansoni A, et al. Impact of hepatitis B vaccination in children born to HBsAg-positive mothers: a 20-year retrospective study. Infection. 2009;37(4):340-3. | 12
Bracebridge S, Irwin D, Millership S. Prevention of perinatal hepatitis B transmission in a health authority area: an audit. Commun Dis Public Health. 2004;7(2):138-41. | 11
Brady M. Preventing the perinatal spread of hepatitis B. J Pediatr Health Care. 1989;3(1):49-51. | 3
Braillon A, Nguyen-Khac E. Pregnancy and hepatitis B in Europe. Liver Int. 2009;29(9):1447; author reply 1447-8. | 3
Brook MG, Lever AM, Kelly D, et al. Antenatal screening for hepatitis B is medically and economically effective in the prevention of vertical transmission: three years experience in a London hospital. Q J Med. 1989;71(264):313-7. | 11
Burgis JC, Kong D, Salibay C, et al. Perinatal transmission in infants of mothers with chronic hepatitis B in California. World J Gastroenterol. 2017;23(27):4942-9. | 11
Cabrié T. Women diagnosed with chronic hepatitis B. Aust Nurs Midwifery J. 2015;22(9):50. | 3
Cai HD, Liu M. The strategy of antivirus treatment in reproductive women infected with hepatitis B virus [Chinese]. Zhonghua Gan Zang Bing Za Zhi. 2008;16(2):159-60. | 3
Cairns JA, Shackley P. Assessing value for money in medical screening. J Med Screen. 1994;1(1):39-44. | 3
Caley M, Fowler T, Greatrex S, et al. Differences in hepatitis B infection rate between ethnic groups in antenatal women in Birmingham, United Kingdom, May 2004 to December 2008. Euro Surveill. 2012;17(30):26. | 12
Cambrea SC, Dumea E, Ilie MM, et al. Materno-foetal transmision of B viral hepatitis in Constanta. J Gastrointest Liver. 2012;21(4):60-1. | 11
Capar M, Kosić-Andrasević V, Popić G, et al. The need and value of routine screening of all pregnant women for hepatitis B surface antigen. Acta Med Croatica. 1995;49(4-5):161-4. | 12
Carey I, et al. Preventing mother to child transmission of HBV in an ethnically diverse South London population: an effective multidisciplinary clinical pathway. Hepatology. 2016;63(1):890A. | 11
Carlson NS. Current resources for evidence-based practice, May/June 2017. J Midwifery Womens Health. 2017;62(3):373-9. | 3
Centers for Disease Control (CDC). Screening for hepatitis B virus infection among refugees arriving in the United States, 1979-1991. MMWR Morb Mortal Wkly Rep. 1991;40(45):784-6. | 12
Centers for Disease Control. Hepatitis B screening and follow-up vaccination of infants of carrier mothers-Atlanta, 1988 and 1989. MMWR Morb Mortal Wkly Rep. 1990;39(24):405-7. | 12
Centers for Disease Control and Prevention (CDC). Postvaccination serologic testing results for infants aged ≤24 months exposed to hepatitis B virus at birth - United States, 2008-2011. MMWR Morb Mortal Wkly Rep. 2012;61(38):768-71. | 11
Centers for Disease Control. Prevention of perinatal transmission of hepatitis B virus: prenatal screening of all pregnant women for hepatitis B surface antigen. MMWR Morb Mortal Wkly Rep. 1988;37(22):341-6, 351. | 3
Centers for Disease Control and Prevention. Hepatitis B vaccination-United States, 1982-2002. MMWR Morb Mortal Wkly Rep. 2002;51(25):549-52, 63. | 12
Centers for Disease Control and Prevention. Assessing completeness of perinatal hepatitis B virus infection reporting through comparison of immunization program and surveillance data-United States. MMWR Morb Mortal Wkly Rep. 2011;60(13):410-3. | 12
Centers for Disease Control and Prevention. Program to prevent perinatal hepatitis B virus transmission in a health-maintenance organization-Northern California, 1990-1995. MMWR Morb Mortal Wkly Rep. 1997;46(17):378-80. | 12
Centers for Disease Control and Prevention. Postvaccination serologic testing results for infants aged <=24 months exposed to hepatitis B virus at birth: United States, 2008-2011. MMWR Morb Mortal Wkly Rep.. 2012;61:768-71. | 9
Centers for Disease Control and Prevention. Prevention of perinatal hepatitis B through enhanced case management-Connecticut, 1994-95, and the United States, 1994. MMWR Morb Mortal Wkly Rep. 1996;45(27):584-7. | 12
Chae HB, Kim JH, Kim JK, et al. Current status of liver diseases in Korea: hepatitis B. Korean J Hepatol. 2009;15(Suppl 6):S13-24. | 3
Chandrapalan S, Smyth C, Lau S, et al. Audit on antenatal care of patients with hepatitis B in a multi-professional clinic in a non-regional centre. United Eur Gastroenterol J. 2015;2(Suppl 1):A516. | 12
Chang MS, Tuomala R, Rutherford AE, et al. Postpartum care for mothers diagnosed with hepatitis B during pregnancy. Am J Obstet Gynecol. 2015;212(3):365.e1-7. | 12
Chang MS, Wharam JF, Zhang F, et al. Peripartum maternal hepatitis B care in a US nationwide data set. J Clin Gastroenterol. 2018 Aug 24. [Epub ahead of print] | 12
Chang YH, Choi GS, Jeong WJ, et al. Epidemiologic study of hepatitis B in pregnant Korean women. Korean J Intern Med. 1986;1(2):233-42. | 12
Chauvin P, Ekra D, Plotkin SA. The cost of not implementing routine neonates immunization programmes in HBsAg high prevalence countries. Vaccine. 2002;20(23-24):2848-50. | 12
Chen AL, et al. Strategies for the prevention of hepatitis B. The Washington Nurse. 1998;28(2):26-8. | 3
Chen DS, Hsu HM, Bennett CL, et al. A program for eradication of hepatitis B from Taiwan by a 10-year, four-dose vaccination program. Cancer Causes Control. 1996;7(3):305-11. | 11
Chen G, Block JM, Evans AA, et al. Gateway to Care campaign: a public health initiative to reduce the burden of hepatitis B in Haimen City, China. BMC Public Health. 2014;14:754. | 12
Chen HL, Chang MH, Ni YH, et al. Seroepidemiology of hepatitis B virus infection in children: ten years of mass vaccination in Taiwan. JAMA. 1996;276(11):906-8. | 1
Chen HL, Lin LH, Hu FC, et al. Breakthrough infection in children born to hepatitis B virus carrier mothers: a reappraisal of screening in pregnant women and universal immunization strategy. J Hepatol. 2011;54:S354. | 9
Cheng EH, Witharana S, Haque M. The impact of maternal chronic hepatitis B infection in obstetric outcomes. Hepatol Int. 2014;8(Suppl 1):S147-8. | 11
Cheng E, Go G, Fereday E, et al. Hepatitis B vertical transmission risk assessment and follow up in the gastroenterology clinic: an Australian tertiary centre experience. Hepatol Int. 2013;7:S271. | 12
Chernesky MA, Blajchman, et al. Analysis of a pregnancy-screening and neonatal-immunization program for hepatitis B in Hamilton, Ontario, Canada, 1977-1988. J Med Virol. 1991;35(1):50-4. | 7
Chien YC, Jan, et al. Nationwide hepatitis B vaccination program in Taiwan: effectiveness in the 20 years after it was launched. Epidemiol Rev. 2006;28(1):126-35. | 9
Choe BH. A disappearing vertical infection: will hepatitis B be a forgotten disease in children? Korean J Intern Med. 2014;29(3):296-300. | 3
Chongsuvivatwong V, Patamasucon P, Chandeying V, et al. Hepatitis B insurance for the newborn. Lancet. 1989;2(8665):749-50. | 12
Christopher PJ. Should all pregnant women be screened for hepatitis B surface antigen? Med J Aust. 1989;150(11):668. | 3
Chrystie I, Sumner D, Palmer S, et al. Screening of pregnant women for evidence of current hepatitis B infection: selective or universal? Health Trends. 1992;24(1):13-5. | 12
Chuang CH. Hepatitis B control program in Taiwan. Acta Paediatr Jpn. 1989;31(6):645-8. | 8
Clark C. Hepatitis B (prevention). HMO tracking system helps prevent infection in newborns. Health Letter CDC. 1997;1-2. | 13
Clarke V, Alfaham M, Evans M, et al. Missed opportunities for preventing perinatal hepatitis B infection. Arch Dis Child Fetal Neonatal Ed. 2000;82(3):F259-60. | 11
Cowan SA. Denmark scales up hepatitis B screening and vaccination for risk groups. Euro Surveill. 2005;10(11):E051103.4. | 3
Cowan SA, Bagdonaite J, Qureshi K. Universal hepatitis B screening of pregnant women in Denmark ascertains substantial additional infections: results from the first five months. Euro Surveill. 2006;11(6):E060608.3. | 12
Crovari P. Epidemiology of viral hepatitis B in Italy. Vaccine. 1995;13(Suppl 1):S26-30. | 3
Cruz AC, Frentzen BH, Behnke M. Hepatitis B: a case for prenatal screening of all patients Am J Obstet Gynecol. 1987;156(5):1180-3. | 11
Cui F, Li L, Hadler SC, et al. Factors associated with effectiveness of the first dose of hepatitis B vaccine in China: 1992-2005. Vaccine. 2010;28(37):5973-8. | 8
Cui F, Luo H, Wang F, et al. Evaluation of policies and practices to prevent mother to child transmission of hepatitis B virus in China: results from China GAVI project final evaluation. Vaccine. 2013;31(Suppl 9):J36-42. | 12
Cui F, Shen L, Li L, et al. Prevention of chronic hepatitis B after 3 decades of escalating vaccination policy, China. Emerg Infect Dis. 2017:23(5):765-72. | 1
Fernandes CN, Alves Mde M, de Souza ML, et al. Prevalence of hepatitis B and C seropositivity in pregnant women [Portuguese]. Rev Esc Enferm USP. 2014;48(1):89-96. | 12
Da Villa G. Rationale for the infant and adolescent vaccination programmes in Italy. Vaccine. 2000;18(Suppl 1):S31-4. | 12
Dalmartello M, Parazzini F, Pedron M, et al. Coverage and outcomes of antenatal tests for infections: a population based survey in the Province of Trento, Italy. J Matern Fetal Neonatal Med. 2019;32(12):2049-55. | 12
Dankner WM, Dixon SD, Lane TA, et al. Hepatitis B in a prenatal population. JAMA. 1993;269(5):589-90. | 12
Datta SK, Gulati AK, Pandey LK, et al. Hepatitis B virus carriage in pregnant women. J Commun Dis. 1988;20(3):209-12. | 12
Day E. Hepatitis B antenatal care in the community. Aust Nurs Midwifery J. 2015;23(6):51. | 3
De Gascun CF, Fraher M, Crean M, et al. The importance of being earnest: following up a low level hepatitis B surface antigen (HBsAg) result. J Clin Virol. 2010;49(2):79-81. | 3
De Groote K, Van Damme P, Deprettere A, et al. Prevention of vertical transmission of hepatitis B virus infection. Is there a standard policy in Flanders (Belgium)? Acta Gastroenterol Belg. 1997;60(4):255-8. | 12
De Souza NC, Botelho CA, Honer MR. Retrospective study of a pioneer antenatal screening program with 8,477 pregnant women in Brazil. Clin Exp Obstet Gynecol. 2004;31(3):217-20. | 12
del Canho R, Grosheide PM, Mazel JA, et al. Ten-year neonatal hepatitis B vaccination program, The Netherlands, 1982-1992: protective efficacy and long-term immunogenicity. Vaccine. 1997;15(15):1624-30. | 9
Deng L, Reekie J, Ward JS, et al. Trends in the prevalence of hepatitis B infection among women giving birth in New South Wales. Med J Aust. 2017;206(7):301-5. | 12
Denis F, Ranger-Rogez S, Alain S, et al. Screening of pregnant women for hepatitis B markers in a French Provincial University Hospital (Limoges) during 15 years. Eur J Epidemiol. 2004;19(10):973-8. | 12
Ding Y, Sheng Q, Ma L, et al. Chronic HBV infection among pregnant women and their infants in Shenyang, China. Virol J. 2013;10:17. | 11
Dong Y, Liu SL, Zhai XJ, et al. A serological and molecular survey of hepatitis B in children 15 years after inception of the national hepatitis B vaccination program in eastern China. J Med Virol. 2009;81(9):1517-24. | 1
dos Santos JI, Lopes MA, Deliège-Vasconcelos E, et al. Seroprevalence of HIV, HTLV-I/II and other perinatally-transmitted pathogens in Salvador, Bahia. Rev Inst Med Trop Sao Paulo. 1995;37(4):343-8. | 12
Driscoll DW. Perinatal transmission of hepatitis B. RN. 1992;55(4):65. | 3
Drăghicenoiu RN, Mărdărescu M, et al. Hepatitis B in children - 18 years after vaccine approval in Romania - clinical and epidemiological observations. J Gastrointest Liver Dis, 2012;21:59. | 11
Duffell EF, van de Laar MJ, Amato-Gauci AJ. Enhanced surveillance of hepatitis B in the EU, 2006-2012. J Viral Hepat. 2015;22(7):581-9. | 11
Dunn J, Shukla R, Neal K. Survey of neonatal hepatitis B vaccination in Leicestershire. Commun Dis Public Health. 1999;2(3):218-9. | 12
Dunn J, Shukla R, Neal K. Integration of hepatitis B vaccination into national immunisation programmes. Alternative strategies must be considered before universal vaccination is adopted. BMJ. 1997;315(7100):121-2. | 12
Durand AM, Sabino H Jr, Mahoney F. Success of mass vaccination of infants against hepatitis B. JAMA. 1996;276(22):1802-4. | 8
Dusheiko G. Interruption of mother-to-infant transmission of hepatitis B: time to include selective antiviral prophylaxis? Lancet. 2012;379(9830):2019-21. | 3
Dusheiko G, Easterbrook P. Bringing to an end mother-to-child transmission of hepatitis B: a role for quantitative hepatitis B surface antigen? Hepatology. 2016;64(5):1408-10. | 3
Dwyer MJ, McIntyre PG. Ante-natal screening for hepatitis B surface antigen: an appraisal of its value in a low prevalence area. Epidemiol Infect. 1996;117(1):121-31. | 2
Dyson J, Michael E, Turley A, et al. Pregnant mothers with chronic hepatitis B (HBV): how often is treatment needed? Gut. 2012;61:A139. | 12
Eisa MG, Gurtin D, Oliver T, et al. The outcome of hepatitis B immunoprophylaxis on vertical transmission: a 5-year observational hospital-based study. Unit Eur Gastroenterol J. 2015;3(5):A515. | 11
Elefsiniotis IS, Brokalaki H, Tsoumakas K, et al. Current vaccination coverage against hepatitis B among pregnant women in Greece: far away from the ideal target. Eur J Obstet Gynecol Reprod Biol. 2010:152(2):227-8. | 12
Elefsiniotis IS, Papadakis MA, Vlahos G, et al. Passive-active immunoprophylaxis for all infants born from HBeAG-negative chronic HBV-infected mothers: is it a cost-effective strategy? Hepatol Res. 2007;37(7):577-8. | 3
Elefsiniotis IS, Vezali E, Brokalaki H, et al. Hepatitis B markers and vaccination-induced protection rate among Albanian pregnant women in Greece. World J Gastroenterol. 2009;15(43):5498-9. | 12
Erdem G, Tekinalp G, Yurdakök M, et al. Perinatal transmission of hepatitis B virus infection. Lancet. 1994;343(8892):289. | 9
Eto T, Shiraki K. National project on the prevention of mother-to-infant infection by hepatitis B virus in Japan. Acta Paediatr Jpn. 1989;31(6):681-4. | 11
Euler GL, Copeland JR, Rangel MC, et al. Antibody response to postexposure prophylaxis in infants born to hepatitis B surface antigen-positive women. Pediatr Infect Dis J. 2003;22(2):123-9. | 11
Euler GL, Wooten KG, Baughman AL, et al. Hepatitis B surface antigen prevalence among pregnant women in urban areas: implications for testing, reporting, and preventing perinatal transmission. Pediatrics. 2003;111(5 Pt 2):1192-7. | 12
Evans AA, Cohen C, Huang P, et al. Prevention of perinatal hepatitis B transmission in Haimen City, China: results of a community public health initiative. Vaccine. 2015;33(26):3010-5. | 11
Fan R, Yin X, Liu Z, et al. A hepatitis B-free generation in China: from dream to reality. Lancet Infect Dis. 2016;16(10):1103-5. | 3
Farghaly AG, Hassan EM, Gawish S, et al. Vertical transmission of HBsAg in Alexandria. J Egypt Public Health Assoc. 1990;65(3-4):377-90. | 11
Farràs Llobet A, et al. Hepatitis B virus infection in pregnant women. J Perinat Med. 2015;43. | 11
Fischer G, Wang S, Ahring S, et al. An investigation of perinatal hepatitis B virus infections among a high risk population: the delivery hospital as a safety net. Pediatr Infect Dis J. 2009;28(7):593-7. | 9
Fujisawa T, Onoue M, Inui A, et al. Serial changes in titers of antibody to hepatitis B surface antigen after immunization of infants born to mothers with hepatitis B e antigen. J Pediatr Gastroenterol Nutr. 1996;23(3):270-4. | 9
Furuncuoglu Y, Bolukbas FF, Bolukbas C, et al. Changes in the prevalence of HBV infection in pregnant women in Turkey between 1995 and 2015: a 20-year evaluation. Postgrad Med J. 2016;92(1091):510-3. | 12
Ganju SA, Goel A. Sero-surveillance of HIV, HBV and HCV infections in antenatal and STD clinic attendees J Commun Dis. 2004;36(1):60-2. | 12
Gao Y, Zhou H, Singh NS, et al. Progress and challenges in maternal health in western China: a countdown to 2015 national case study. Lancet Glob Health. 2017;5(5):e523-36. | 12
Garcia Ruiz I, et al. Hepatitis B infection and pregnancy. Experience from a reference hospital in Barcelona. J Matern Fetal Neonatal Med. 2014;27:173. | 11
Gascón A, et al. Incidence and perinatal results of hepatitis B complicated pregnancies. J Matern Fetal Neonatal Med. 2012;25:61. | 9
Gay N, Miller E, et al. Antenatal screening for hepatitis B. J Med Screen. 1998;5(1):53. | 3
Gibson-Helm M, Teede H, Block A, et al. Maternal health and pregnancy outcomes among women of refugee background from African countries: a retrospective, observational study in Australia. BMC Pregnancy Childbirth. 2014;14:392. | 12
Giles ML, Grace R, Tai A, et al. Prevention of mother-to-child transmission of hepatitis B virus (HBV) during pregnancy and the puerperium: current standards of care. Aust N Z J Obstet Gynaecol. 2013;53(3):231-5. | 12
Gilleand C. Perinatal transmission of the hepatitis B virus. J Newborn Nurs. 1999;16-8. | 3
Giraudon I, Forde J, Maguire H, et al. Antenatal screening and prevalence of infection: surveillance in London, 2000-2007. Euro Surveill. 2009;14(9):8-12. | 12
Godbole G, Irish D, Basarab M, et al. Management of hepatitis B in pregnant women and infants: a multicentre audit from four London hospitals. BMC Pregnancy Childbirth. 2013;13:222. | 12
Goh KT. Prevention and control of hepatitis B virus infection in Singapore. Ann Acad Med Singapore. 1997;26(5):671-81. | 3
Goh KT, Doraisingham S, Tan KL, et al. The hepatitis B immunization programme in Singapore. Bull World Health Organ. 1989;67(1):65-70. | 11
Goldwater PN. Hepatitis B in Australia: on course for universal vaccination. Med J Aust. 1996:165(6):300-1. | 3
Gonsalkorala E, et al. The landscape of pregant women with hepatitis B in a single centre. Hepatology. 2014;60:1010A. | 12
Gonzalez A, et al. Infectious diseases in pregnancy: normalising the antenatal care for women who screen positive for hepatitis B in a London teaching hospital with two main hospital sites. BJOG. 2017;124:106-7. | 12
González-Quintero VH, Katz D, Pandya-Smith I, et al. Assessing perinatal hepatitis B screening and neonatal prophylaxis in a large, multiethnic county. J Reprod Med. 2006;51(2):101-8. | 12
Graham S, Guy RJ, Cowie B, et al. Chronic hepatitis B prevalence among Aboriginal and Torres Strait Islander Australians since universal vaccination: a systematic review and meta-analysis. BMC Infect Dis. 2013;13:403. | 2
Greenspoon JS, Martin J, Greenspoon RL, et al. Necessity for routine obstetric screening for hepatitis B surface antigen. J Reprod Med. 1989;34(9):655-8. | 12
Grimes RM, Richards EP, Rathbun KC, et al. Hepatitis B, syphilis, and human immunodeficiency virus: are different approaches to prenatal screening justified? Pediatr AIDS HIV Infect. 1997;8(2):98-101. | 3
Grob PJ. Report on Working Group 2: Austria, Belgium, Bulgaria, Germany, Greece, Hungary, Malta, Russia, Switzerland, Turkey and Uzbekistan. [Erratum appears in Vaccine. 1999;17(19):2472] Vaccine. 1998;16(Suppl):S61-2. | 3
Grosheide PM, Klokman-Houweling JM, Conyn-van Spaendonck MA. Programme for preventing perinatal hepatitis B infection through screening of pregnant women and immunisation of infants of infected mothers in The Netherlands, 1989-92. National Hepatitis B Steering Committee. BMJ. 1995;311(7014):1200-2. | 12
Grosheide PM, Wladimiroff JW, Heijtink RA, et al. Proposal for routine antenatal screening at 14 weeks for hepatitis B surface antigen. Dutch Study Group on Prevention of Neonatal Hepatitis. BMJ. 1995;311(7014):1197-9. | 12
Guan R. Hepatitis B virus infection in Singapore. Gut. 1996;38(Suppl 2):S13-7. | 3
Guirgis M, Zekry A, Yan K, et al. Chronic hepatitis B infection in an Australian antenatal population: seroprevalence and opportunities for better outcomes. J Gastroenterol Hepatol. 2009;24(6):998-1001. | 12
Guo Y, Liu J, Meng L, et al. Survey of HBsAg-positive pregnant women and their infants regarding measures to prevent maternal-infantile transmission. BMC Infect Dis. 2010;10:26. | 11
Gupta I, Ganguly, et al. Neonatal and maternal immunoprophylaxis against hepatitis B virus. Bull Postgrad Inst Med Ed Res Chandigarh. 1994;28(4):149-52. | 3
Gust ID. Control of hepatitis B in Australia. The case for alternative strategies. Med J Aust. 1992;156(12):819-21. | 3
Hahné S, van den Hoek A, Baayen D, et al. Prevention of perinatal hepatitis B virus transmission in the Netherlands, 2003-2007: children of Chinese mothers are at increased risk of breakthrough infection. Vaccine. 2012;30(9):1715-20. | 9
Hann HW, Hann RS, Maddrey WC. Hepatitis B virus infection in 6,130 unvaccinated Korean-Americans surveyed between 1988 and 1990. Am J Gastroenterol. 2007;102(4):767-72. | 11
Hansen N, Hay G, Cowan S, et al. Hepatitis B prevalence in Denmark - an estimate based on nationwide registers and a national screening programme, as on 31 December 2007. Euro Surveill. 2013;18(47). pii: 20637. | 12
Harder KM, Cowan S, Eriksen MB, et al. Universal screening for hepatitis B among pregnant women led to 96% vaccination coverage among newborns of HBsAg positive mothers in Denmark. Vaccine. 2011;29(50):9303-7. | 11
Hardie J. Hepatitis B, immunization, and pregnancy. Probe (Adelaide). 1988;22(2):79-82. | 3
Harpaz R, McMahon BJ, Margolis HS, et al. Elimination of new chronic hepatitis B virus infections: results of the Alaska immunization program. J Infect Dis. 2000;181(2):413-8. | 8
Hartmann P, et al. The introduction of viral hepatitis B preventive vaccination to the Republic of Maldives. J Prev Med Hyg. 1994;35(1-2):53-4. | 13
Has R, Yüksel A, Topuz S. Hepatitis B infection in pregnancy: is it really not harmful to the fetus? Prenat Diagn. 2001;21(8):701-2. | 12
Healy CM, Cafferkey MT, Butler KM, et al. Antenatal hepatitis B screening - is there a need for a national policy? Ir Med J. 2001;94(4):111-2, 114. | 11
Heininger U, Vaudaux B, Nidecker M, et al. Evaluation of the compliance with recommended procedures in newborns exposed to HBsAg-positive mothers: a multicenter collaborative study. Pediatr Infect Dis J. 2010;29(3):248-50. | 11
Henning KJ, Pollack DM, Friedman SM. A neonatal hepatitis B surveillance and vaccination program: New York City, 1987 to 1988. Am J Public Health. 1992;82(6):885-8. | 12
Hepburn I, Babenko N, Schade R. Chronic viral hepatitides in females of reproductive age in Ukraine. Am J Gastroenterol. 2011;106(Suppl 2):S422-3. | 12
Hepburn I, Schade R, et al. High prevalence of chronic hepatitis B among pregnant women in Ukraine: an opportunity lost. Hepatology. 2011;54(Suppl 1):590A-1. | 12
Hetenyi G, et al. Prevention of HBsAg positive mothers’ newborns against hepatitis B infection with vaccination - economic view of countrywide program in Hungary. Int J Gynecol Obstet. 2009;107(Suppl 2):S633. | 12
Hill LL, Hovell M, Benenson AS. Prevention of hepatitis B transmission in Indo-Chinese refugees with active and passive immunization. Am J Prev Med. 1991;7(1):29-32. | 11
Hokama T, Yara A, Hirayama K, et al. A survey on the vaccination practice for perinatal hepatitis B virus infection at a clinic in Okinawa, Japan. Asia Pac J Public Health. 1998;10(1):46-8. | 11
Hollinger FB. Controlling hepatitis B virus transmission in North America. The North American Regional Study Group. Vaccine. 1990;8(Suppl):S122-8; discussion S134-8. | 12
Hong Z, Smart G, Zaniewski G, et al. Epidemiological study of hepatitis B virus infection in Manitoba, Canada, 1992-2003. Eur J Clin Microbiol Infect Dis. 2005;24(7):464-70. | 1
Honigman B. Selected serology: pregnancy testing, hepatitis A and B, and infectious mononucleosis. Emerg Med Clin North Am. 1986;4(2):299-314. | 3
Houweling H, Wittevrongel CF, Verweij M, et al. Public vaccination programmes against hepatitis B in The Netherlands: assessing whether a targeted or a universal approach is appropriate. Vaccine. 2010;28(49):7723-30. | 3
Hsu HM, Chen DS, Chuang CH, et al. Efficacy of a mass hepatitis B vaccination program in Taiwan. Studies on 3464 infants of hepatitis B surface antigen-carrier mothers. JAMA. 1988:260(15):2231-5. | 11
Hu Y, Zhang S, Luo C, et al. Gaps in the prevention of perinatal transmission of hepatitis B virus between recommendations and routine practices in a highly endemic region: a provincial population-based study in China. BMC Infect Dis. 2012;12:221. | 11
Huang LM, Chang MH, Hong JY, et al. Changing aetiologic patterns of acute viral hepatitis in Taiwanese children. J Gastroenterol Hepatol. 1989;4(4):339-44. | 12
Huang Y, Li L, Sun X, et al. Screening of pregnant women for hepatitis B virus surface antigen (HBsAg) and subsequent management, Qiandongnan prefecture, Guizhou, China, 2010. Vaccine. 2013;31(Suppl 9):J62-5. | 11
Hutin Y, Hennessey K, Cairns L, et al. Improving hepatitis B vaccine timely birth dose coverage: lessons from five demonstration projects in China, 2005-2009. Vaccine. 2013;31(Suppl 9):J49-55. | 12
Huynh C, Minuk GY, Uhanova J, et al. Serological and molecular epidemiological outcomes after two decades of universal infant hepatitis B virus (HBV) vaccination in Nunavut, Canada. Vaccine. 2017;35(35 Pt B):4515-22. | 2
Ikeda RM, Birkhead GS, Flynn MK, et al. Use of multiple reporting sources for perinatal hepatitis B surveillance and follow-up. Am J Epidemiol. 1995;142(7):765-70. | 11
Ishizaki A, Bouscaillou J, Luhmann N, et al. Survey of programmatic experiences and challenges in delivery of hepatitis B and C testing in low- and middle-income countries. BMC Infect Dis. 2017;17(Suppl 1):696. | 12
Iwarson S. Report from Working Group 3 (the Czech Republic, Denmark, Finland, Norway, The Netherlands, Slovakia, Sweden and the UK). Vaccine. 1998;16(Suppl):S63-4. | 3
Jain DC, Jain RK, Ichhpujani RL, et al. Prevalence of hepatitis B virus in pregnant women. J Commun Dis. 1994;26(4):233-4. | 12
Jensen L, Heilmann C, Smith E, et al. Efficacy of selective antenatal screening for hepatitis B among pregnant women in Denmark: is selective screening still an acceptable strategy in a low-endemicity country? Scand J Infect Dis. 2003;35(6-7):378-82. | 12
Jeong SH, Yim HW, Yoon SH, et al. Changes in the intrafamilial transmission of hepatitis B virus after introduction of a hepatitis B vaccination programme in Korea. Epidemiol Infect. 2010;138(8):1090-5. | 6
Jessop AB, Watson B, Mazar R, et al. Assessment of screening, treatment, and prevention of perinatal infections in the Philadelphia birth cohort. Am J Med Qual. 2005;20(5):253-61. | 12
Jimenez G, Alex G, Paxton G, et al. B alert: hepatitis B virus infection in children in Victoria. J Paediatr Child Health. 2013;49(3):E213-6. | 11
Jindal A, Singh A, Sarin SK. Prevention of peripartum hepatitis B transmission. N Engl J Med. 2016;375(15):1496-7. | 3
Jonas MM. Hepatitis B in pregnancy. Liver Int. 2009;29(9):1447-8. | 3
Jonas MM, Reddy RK, DeMedina M, et al. Hepatitis B infection in a large municipal obstetrical population: characterization and prevention of perinatal transmission. Am J Gastroenterol. 1990;85(3):277-80. | 11
Jordan R, Law M. An appraisal of the efficacy and cost effectiveness of antenatal screening for hepatitis B. J Med Screen. 1997;4(3):117-27. | 2
Jowitt D. Contribution of hepatitis B vaccination programmes initiated by Alexander Milne and Dr Christopher Moyes to the decline in prevalence of hepatitis B infection in pregnant women in the Midlands region of the North Is, New Zealand. N Z Med J. 2011;124(1334):123-4. | 1
Kaldor JM, Plant AJ, Thompson SC, et al. The incidence of hepatitis B infection in Australia: an epidemiological review. Med J Aust. 1996;165(6):322-6. | 3
Kane MA, Hadler SC, Lee L, et al. The inception, achievements, and implications of the China GAVI Alliance Project on Hepatitis B Immunization. Vaccine. 2013;31(Suppl 9):J15-20. | 3
Kane MA, Hadler SC, Margolis HS, et al. Routine prenatal screening for hepatitis B surface antigen. JAMA. 1988:259(3):408-9. | 3
Kawabe Y, Sugiyama K, Wada Y, et al. 3-year study for the prevention of perinatal HBV infection under the standard method of the Ministry of Health and Welfare, Japan. Acta Paediatr Jpn. 1989;31(6):659-62. | 8
Keane FE, Neale J, Phillips T, et al. Offering routine antenatal testing for HIV and hepatitis B in the rural setting of Cornwall. Sex Transm Infect. 2002;78(2):133-4. | 12
Khan NR, Sadiq F. Prenatal screening for hepatitis B virus. Int J Gynaecol Obstet. 1996;55(1):79-80. | 12
Kiel FW. Increasing compliance over five years in a hepatitis B infant immunization program in Saudi Arabia. Ann Saudi Med. 1991:11(4):439-42. | 11
Kim JH, Kim JS, Lee JJ, et al. Survey of perinatal hepatitis B virus transmission after Korean National Prevention Program in a tertiary hospital. Korean J Intern Med. 2014;29(3):307-14. | 11
Kim JW. Hepatitis B virus infection in South Korea: three decades after universal vaccination. Korean J Intern Med. 2013;28(4):408-9. | 3
Klein ME. Hepatitis B virus: perinatal management. J Perinat Neonatal Nurs. 1988;1(4):12-23. | 3
Kligman E, Kwo PY. Confirming what we believed: reducing and eliminating vertical transmission of hepatitis B. Gastroenterology. 2017;152(5):1239-41. | 3
Ko SC, Fan L, Smith EA, et al. Estimated annual perinatal hepatitis B virus infections in the United States, 2000-2009. J Pediatric Infect Dis Soc. 2016;5(2):114-21. | 2
Ko SC, Schillie SF, Walker T, et al. Hepatitis B vaccine response among infants born to hepatitis B surface antigen-positive women. Vaccine. 2014;32(18):2127-33. | 11
Ko TM, Lin KH, Ho MM, et al. Perinatal transmission of hepatitis B virus in the Taoyuan area. Taiwan Yi Xue Hui Za Zhi. 1986;85(4):341-51. | 11
Koc ÖM, Konsten S, Jansen G, et al. Influence of the ethnic status in chronic hepatitis B patients: comparing the Netherlands, Belgium and Turkey. Hepatology. 2015;62(Suppl 1):996A-7A. | 12
Kohn MA, Farley TA, Scott C. The need for more aggressive follow-up of children born to hepatitis B surface antigen-positive mothers: lessons from the Louisiana Perinatal Hepatitis B Immunization Program. Pediatr Infect Dis J. 1996;15(6):535-40. | 11
Kolgelier S, Sumer S, Demir NA, et al. Monitoring and treatment results of 88 HBsAg-positive pregnant women. Clin Exp Obstet Gynecol. 2016;43(6):866-70. | 11
Komatsu H, Inui A. Chronic hepatitis B in children in the United States and Canada: international origins place the disease burden on children even in the era of universal vaccination. Transl Pediatr. 2016;5(1):1-4. | 3
Komatsu H, Inui A, Fujisawa T, et al. Transmission route and genotype of chronic hepatitis B virus infection in children in Japan between 1976 and 2010: a retrospective, multicenter study. Hepatol Res. 2015;45(6):629-37. | 5
Komatsu H, Inui A, Sogo T, et al. Source of transmission in children with chronic hepatitis B infection after the implementation of a strategy for prevention in those at high risk. Hepatol Res. 2009;39(6):569-76. | 12
Koplan JP. Prenatal screening for hepatitis B. JAMA. 1988;259(23):3408-9. | 3
Koruk I, Koruk ST, Çopur AÇ, et al. An intervention study to improve HBsAg testing and preventive practices for hepatitis B in an obstetrics hospital. TAF Prev Med Bull. 2011;10(3):287-92. | 12
Koumans EH, Rosen J, van Dyke MK, et al. Prevention of mother-to-child transmission of infections during pregnancy: implementation of recommended interventions, United States, 2003-2004. Am J Obstet Gynecol. 2012;206(2):158.e1-11. | 12
Koyama T, Matsuda I, Sato S, et al. Prevention of perinatal hepatitis B virus transmission by combined passive-active immunoprophylaxis in Iwate, Japan (1981-1992) and epidemiological evidence for its efficacy. Hepatol Res. 2003;26(4):287-92. | 9
Kravchuk I, Chumak NF, Schade RR, et al. Hepatitis B in pregnancy in Ukraine: wasted chance. J Hepatol. 2015;62(Suppl 2):S829-30. | 12
Kretzschmar M, de Wit A. Universal hepatitis B vaccination. Lancet Infect Dis. 2008;8(2):85-7; author reply 90. | 3
Kripke C. Hepatitis B vaccine for infants of HBsAg-positive mothers. Am Fam Physician. 2007;75(1):49-50. | 3
Krugman S. Hepatitis B virus and the neonate. Ann N Y Acad Sci. 1988;549:129-34. | 3
Kubo A, Marks A, Lakritz D, et al. The effectiveness of immunoprophylaxis program for neonatal transmission of hepatitis B within a large HMO. Am J Epidemiol. 2012:175(11 Suppl):S42. | 11
Kubo A, Shlager L, Corley DA. Vertical transmission of hepatitis B virus-in response. Ann Intern Med. 2014;161(10):763. | 3
Kuehn BM. Report: too little surveillance, treatment for US patients with hepatitis B and C. JAMA. 2010;303(8):713-14. | 3
Kuhn BS, Cohen SM. Care of the HBV positive mother and her infant. Health Care Women Int. 1986;7(4):329-40. | 3
Kuncio DE, Newbern EC, Ma L, et al. Capture-recapture: using existing data sources to improve perinatal hepatitis B surveillance, Philadelphia, 2008-2014. Public Health Rep. 2017;132(3):376-80. | 12
Kunoee A, Nielsen J, Cowan S. Hepatitis B vaccination coverage and risk factors associated with incomplete vaccination of children born to hepatitis B surface antigen-positive mothers, Denmark, 2006 to 2010. Euro Surveill. 2016;21(7). pii=30136. | 12
Kuzmin V. Risk of sequelae after viral infection during pregnancy. J Matern Fetal Neonatal Med. 2014;27:154-155. | 12
Ladhani SN, Flood JS, Amirthalingam G, et al. Epidemiology and clinical features of childhood chronic hepatitis B infection diagnosed in England. Pediatr Infect Dis J. 2014;33(2):130-5. | 12
Lambert JS, et al. A 3-year review of infections in pregnancy at a busy inner city maternity hospital. HIV Med. 2010;11:70. | 12
Langer B, Caneva MP, Schlaeder G. Routine prenatal care in Europe: the comparative experience of nine departments of gynaecology and obstetrics in eight different countries. Eur J Obstet Gynecol Reprod Biol. 1999;85(2):191-8. | 12
Lao TT, Cheung KL, Wong V. Hepatitis B vaccine response among infants born to hepatitis B surface antigen-positive women. Vaccine. 2015;33(1):15-6. | 12
Lao TT, Sahota DS, Suen SS, et al. Impact of neonatal hepatitis B vaccination programme on age-specific prevalence of hepatitis B infection in teenage mothers in Hong Kong. Epidemiol Infect. 2013;141(10):2131-9. | 12
Łapiński TW, Stepaniuk J, Tomasiewicz K, et al. Effect of hepatitis B virus (HBV) infection on the course of pregnancy and newborns’ health status. Clin Exp Hepatol. 2015;1(3):112-6. | 9
Larcher VF, Bourne J, Aitken C, et al. Overcoming barriers to hepatitis B immunisation by a dedicated hepatitis B immunisation service. Arch Dis Child. 2001;84(2):114-9. | 11
Larson E. Trends in neonatal infections. J Obstet Gynecol Neonatal Nurs. 1987;16(6):404-9. | 3
Lavanchy D. Public health measures in the control of viral hepatitis: a World Health Organization perspective for the next millennium. J Gastroenterol Hepatol (Aust). 2002;17(Suppl 4):S452-9. | 3
Le ST, Sahhar L, Spring S, et al. Antenatal maternal hepatitis B care is a predictor of timely perinatal administration of hepatitis B immunoglobulin. Intern Med J. 2017;47(8):915-22. | 11
Lee D, et al. Cost-effectiveness of antiviral prophylaxis during pregnancy to prevent perinatal hepatitis B infection in South Korea. Value Health. 2017;20(5):A76. | 2
Lei L, et al. Economic evaluation on hepatitis B vaccination strategies for preventing mother-to-child transmission in China. Value Health. 2014;17(7):A805. | 2
Leung N. Chronic hepatitis B in Asian women of childbearing age. Hepatol Int. 2009;3(Suppl 1):24-31. | 3
Lewin JC. Hepatitis B in Hawaii. Hawaii Med J. 1988;47(1):7-8. | 3
Li ZY, et al. A sero-epidemiological study on hepatitis B virus infection among pregnant women in Beijing. Clin Microbiol Infect. 2012;18:673-4. | 12
Liang X, Bi S, Yang W, et al. Evaluation of the impact of hepatitis B vaccination among children born during 1992-2005 in China. J Infect Dis. 2009;200(1):39-47. | 10
Lidman K, Magnius, et al. Viral hepatitis in pregnant women at term. Scand J Infect Dis Suppl. 1990;71:39-44. | 3
Lin CC, Hsieh HS, Huang YJ, et al. Hepatitis B virus infection among pregnant women in Taiwan: comparison between women born in Taiwan and other southeast countries. BMC Public Health. 2008;8:49. | 12
Lin CL, et al. Does positive maternal hepatitis B surface antigen state effect pregnancy outcome? Gastroenterology. 2012;142(5):S992. | 12
Lin CL, Kao JH. Prevention of mother-to-child transmission: the key of hepatitis B virus elimination. Hepatol Int. 2018;12(2):94-6. | 3
Lin HH, Kao JH, Chang TC, et al. Secular trend of age-specific prevalence of hepatitis B surface and e antigenemia in pregnant women in Taiwan. J Med Virol. 2003;69(4):466-70. | 12
Lin HH, Wang LY, Hu CT, et al. Decline of hepatitis B carrier rate in vaccinated and unvaccinated subjects: sixteen years after newborn vaccination program in Taiwan. J Med Virol. 2003;69(4):471-4. | 1
Liu H, et al. Preventing from mother to child transmission of hepatitis B virus infection. Hepatol Int. 2017;11(1):S704. | 11
Liu Z, et al. An epidemiological study on clinical characteristics of chronic HBV infection during pregnancy: interim report of Shield Project. Hepatol Int. 2017;11(1):S271-2. | 12
Loo NM, Kim WR, Larson JJ, et al. Hepatitis B screening in a US academic primary care practice. Arch Intern Med. 2012;172(19):1517-9. | 12
Lu SN, Liu JH, Wang JH, et al. Secular trends of HBeAg prevalence among HBsAg-positive delivery mothers in a hepatitis B endemic area. J Trop Pediatr. 2000;46(2):121-3. | 12
Luo Z, et al. Impact of the implementation of a vaccination strategy on hepatitis B virus infections in China over a 20-year period. Int J Infect Dis. 2012;16(2):e82-8. | 3
Macinko J, Marinho de Souza Mde F, Guanais FC, et al. Going to scale with community-based primary care: an analysis of the family health program and infant mortality in Brazil, 1999-2004. Soc Sci Med. 2007;65(10):2070-80. | 8
Mahaba HM, El-Tayeb Ael K, El-Sekibi DK, et al. Pattern of HBsAg positivity in selected groups at King Khalid General Hospital - Hail Region, Kingdom of Saudi Arabia. J Family Community Med. 1997;4(1):30-6. | 12
Mahony JB, Chernesky MA. Vertical transmission of viral hepatitis. Transfus Med Rev. 1993;7(2):112-20. | 3
Maini MK, Bertoletti A. HBV in 2016: global and immunotherapeutic insights into hepatitis B. Nat Rev Gastroenterol Hepatol. 2017;14(2):71-2. | 3
Malecki JM, Guarin O, Hulbert A, et al. Prevalence of hepatitis B surface antigen among women receiving prenatal care at the Palm Beach County Health Department. Am J Obstet Gynecol. 1986;154(3):625-6. | 12
Malhotra P, et al. Seroprevalence of hepatitis B infection during pregnancy in a tertiary care centre. J Clin Exp Hepatol. 2013;3(1):S50. | 12
Manos M, Darbinian, et al. Variations in chronic hepatitis B screening and management among Asian-American ethnic groups in a California managed care program. Hepatology. 2011;54:880A-1. | 12
Marillier EA, Holmes NR, Macleod AJ, et al. Direct communication with general practitioners improves management of infants at risk of hepatitis B. Commun Dis Public Health. 2000;3(1):63-4. | 12
Marwick C. Routine screening considered to end perinatal hepatitis transmission. JAMA. 1987;257(15):1999. | 3
Masia G, et al. An evaluation of the application and the effectiveness of preventive measures against the hepatitis viral infection in Sardinia. J Prev Med Hyg. 2005;46(3):108-10. | 12
Masoumy EP, Stansfield BK. Breakthrough in the prevention of mother-to-child hepatitis B transmission? J Perinatol. 2017;37(4):333-4. | 3
Massey J, Nair A, Dietz S, et al. Hospital, maternal, and birth factors associated with hepatitis B vaccination at birth - West Virginia, 2015. Pediatr Infect Dis J. 2018;37(7):691-6. | 12
Mast EE, Mahoney FJ, Alter MJ, et al. Progress toward elimination of hepatitis B virus transmission in the United States. Vaccine. 1998;16(16 Suppl):S48-51. | 3
Matthews HC, et al. Perinatal hepatitis B in a high prevalence inner city population: direct electronic referral improves care. Gut. 2012;61:A79-80. | 12
McGinty DL, Toffler WL. Prenatal evaluation for hepatitis B surface antigen. West J Med. 1989;150(2):198. | 3
McGregor K, Gonzalez, et al. Infectious diseases in pregnancy: making a difference for women who screen positive for hepatitis B in a London teaching hospital. Department of Obstetrics and Gynaecology, Royal Free London NHS Foundation Trust, London. 2017. | 12
Meints L, Chescheir N. Screening for infectious diseases in pregnant, foreign-born women from multiple global areas. J Reprod Med. 2010;55(9-10):382-6. | 12
Mercier CE, Barry SE, Paul K, et al. Improving newborn preventive services at the birth hospitalization: a collaborative, hospital-based quality-improvement project. Pediatrics. 2007;120(3):481-8. | 12
Meyer MC, Mead PB, Capeless EL. Hepatitis B surface antigen screening in a nonindigent population. J Reprod Med. 1992;37(12):953-5. | 12
Meyers D. Preventing neonatal hepatitis B virus infection. J Neonatal Nurs. 1991;10(2):11-5. | 3
Michigan Department of Community Health. Perinatal hepatitis B prevention. Mich Med. 2009;108(4):17. | 3
Michitaka K, Akbar F, Onji M, et al. Prevention of hepatitis B virus infection by vaccination: progress and problems. Hepatol Res. 2007;37(9):673-5. | 3
Miller R, et al. Routine HIV and HBV antibody screening. Br J Midwifery. 2002;10(7):428-32. | 12
Minuk GY, Zhang M, Wong SG, et al. Viral hepatitis in a Canadian First Nations community. Can J Gastroenterol. 2003;17(10):593-6. | 12
Mittal R, et al. Health care disparity in delivering optimal care to chronic hepatitis B pregnant mothers. Hepatology. 2015;62:976A. | 12
Mittal R, et al. Impact of clinical alerts within electronic health record on infant immunization born to CHB pregnant mothers. Gastroenterology. 2016;150(4):S152-S153. | 12
Miyakawa Y, Yoshizawa H. Immunoprophylaxis of perinatal infection with hepatitis B virus on the national scale. Hepatol Res. 2006;36(4):255-8. | 3
Mohan N, Kamsakul W, Wirth S, et al. Hepatitis B and C: report of the FISPGHAN working group. J Pediatr Gastroenterol Nutr. 2012;55(5):631-6. | 3
Monna T, Kuroki T, Oka H, et al. Prevention of vertical transmission of HBV by administration of hepatitis B vaccine combined with HBIG and long-term follow-up of HBsAb titer. Osaka City Med J. 1988;34(1):9-17. | 9
Morgan-Capner P. Viral infections in pregnancy. Br J Hosp Med. 1991;45(3):150-7. | 3
Murray-Lyon IM. Strategies for preventing hepatitis B. Q J Med. 1989;71(264):277-8. | 3
Myers HI, Spracklen CN, Ryckman KK, et al. A retrospective study of administration of vaccination for hepatitis B among newborn infants prior to hospital discharge at a midwestern tertiary care center. Vaccine. 2015;33(20):2316-21. | 12
Nabulsi MM, Khalil AM, Farah AE, et al. Prevalence of hepatitis B surface antigen in pregnant Lebanese women. Int J Gynaecol Obstet. 1997;58(2):243-4. | 12
Nair IS. Prevention of mother-to-child transmission of hepatitis B infection. Perinatology. 2013;14(3):114-8. | 13
Nakano LA, Katayose JT, Abreu RM, et al. Assessment of the prevalence of vertical hepatitis B transmission in two consecutive generations. Rev Assoc Med Bras (1992). 2018;64(2):154-8. | 2
National Toxicology Program. Hepatitis B virus. Rep Carcinog. 2011;12:216-8. | 3
Newell ML, et al. Mother-to-child transmission of hepatitis B infection. Fetal Matern Med Rev. 1998;10(2):109-19. | 3
Newell ML, Thorne C, Pembrey L, et al. Antenatal screening for hepatitis B infection and syphilis in the UK. Br J Obstet Gynaecol. 1999;106(1):66-71. | 12
Ni YH, Huang LM, Chang MH, et al. Two decades of universal hepatitis B vaccination in Taiwan: impact and implication for future strategies Gastroenterology. 2007;132(4):1287-93. | 12
Niederau C, Amani A, Thiel A. Long-term follow-up of HBsAg-positive patients in Germany. Eur J Gastroenterol Hepatol. 2016;28(1):48-56. | 6
Noto H, Terao T, Ryou S, et al. Combined passive and active immunoprophylaxis for preventing perinatal transmission of the hepatitis B virus carrier state in Shizuoka, Japan during 1980-1994. J Gastroenterol Hepatol. 2003;18(8):943-9. | 11
O’Connell K, Cormican M, Hanahoe B, et al. Prevalence of antenatal hepatitis B virus carriage in the west of Ireland. Ir Med J. 2010;103(3):91-2. | 12
O’Leary ST, Nelson C, Duran J. Maternal characteristics and hospital policies as risk factors for nonreceipt of hepatitis B vaccine in the newborn nursery. Pediatr Infect Dis J. 2012;31(1):1-4. | 12
Oats JJ. Routine antenatal screening: a need to evaluate Australian practice. Med J Aust. 2000;172(7):311-2. | 3
Okun NB, Larke RP, Waters JR, et al. Success of a program of routine prenatal screening for hepatitis B surface antigen: the first 2 years. CMAJ. 1990;143(12):1317-21. | 11
Ona S, et al. Sexually tramsmitted infection screening and follow-up in a high-risk urban obstetric clinic. Sex Transm Infect. 2015;91:A164. | 12
Op de Coul EL, Hahné S, van Weert YW, et al. Antenatal screening for HIV, hepatitis B and syphilis in the Netherlands is effective. BMC Infect Dis. 2011;11:185. | 12
Osterholm MT. Hepatitis B infection in Minnesota: a case for universal immunization. Pediatr Infect Dis J. 1998;17(7 Suppl):S30-4. | 12
Otgonbayar B, et al. Mother to child transmission of HBV and HCV in Mongolia. Hepatol Int. 2015;9(1):S32. | 11
Ozaras R, Balkan Il, Yemisen M, et al. Elimination of mother-to-child transmission of hepatitis B. Lancet Infect Dis. 2016;16(1):20-1. | 3
Ozsoylu S. Prevention of perinatal transmission of hepatitis B virus infection. Am J Dis Child. 1993;147(6):610-1. | 9
Pan CQ, Han G, Wang W. Prevention of peripartum hepatitis B transmission. N Engl J Med. 2016;375(15):1497-8. | 3
Panaretto KS, Mitchell MR, Anderson L, et al. Sustainable antenatal care services in an urban Indigenous community: the Townsville experience. Med J Aust. 2007;187(1):18-22. | 12
Panda SK, Gupta A, Datta R, et al. Transplacental transmission of hepatitis B virus. Lancet. 1986;2(8512):919-20. | 11
Pantazis KD, Elefsiniotis IS, Brokalaki H. New data concerning the epidemiology of hepatitis B virus infection in Greece. Gastroenterol Res Pract. 2008;2008:580341. | 3
Papaevangelou G. Hepatitis B immunization programme: lessons learnt in Greece. Vaccine. 1998;16(Suppl):S45-7. | 12
Papaevangelou V, Hadjichristodoulou C, Cassimos D, et al. Adherence to the screening program for HBV infection in pregnant women delivering in Greece. BMC Infect Dis. 2006;6:84. | 12
Park NH, Chung YH, Lee HS. Impacts of vaccination on hepatitis B viral infections in Korea over a 25-year period. Intervirology. 2010;53(1):20-8. | 3
Parker PJ, Gyorkos TW, Dylewski JS, et al. Prevention of perinatal hepatitis B virus transmission in an obstetric/infant population. Can J Infect Dis. 1993;4(5):288-91. | 11
Paul C, Thomas M. Screening for hepatitis B carriers: a perspective from New Zealand. Aust N Z J Med. 1997;27(6):698-705. | 3
Petermann S, Ernest JM. Intrapartum hepatitis B screening. Am J Obstet Gynecol. 1995;173(2):369-73; discussion 373-4. | 12
Petersen J. HBV treatment and pregnancy. J Hepatol. 2011;55(6):1171-3. | 3
Pierce RL, Smith S, Rowe-West B, et al. Hepatitis B maternal screening, infant vaccination, and infant prophylaxis practices in North Carolina. Arch Pediatr Adolesc Med. 1999;153(6):619-23. | 12
Plitt SS, Somily AM, Singh AE. Outcomes from a Canadian public health prenatal screening program for hepatitis B: 1997-2004. Can J Public Health. 2007;98(3):194-7. | 11
Polakoff S. Immunoprophylaxis of infants born to hepatitis B virus exposed mothers. Arch Dis Child. 1986;61(12):1242-7. | 3
Polatti F, et al. The value of serologic screening for hepatitis B virus in pregnancy for the control of HBV infection. Ital J Gynaecol Obstet. 1996;8(3):99-102. | 11
Pongpipat D. Prevention of hepatitis B virus infections. Asian Pac J Allergy Immunol. 1986;4(1):1-3. | 3
Poovorawan Y. Success of Thai universal immunization program in preventing perinatal hepatitis B virus infection. Hepatol Res. 2010;40(7):726. | 8
Poovorawan Y, Chongsrisawat V, Theamboonlers A, et al. Evidence of protection against clinical and chronic hepatitis B infection 20 years after infant vaccination in a high endemicity region. J Viral Hepat. 2011;18(5):369-75. | 9
Poovorawan Y, Sanpavat S, Pongpunlert W, et al. Protective efficacy of a recombinant DNA hepatitis B vaccine in neonates of HBe antigen-positive mothers. JAMA. 1989;261(22):3278-81. | 9
Porgo TV, Gilca V, De Serres G, et al. Dramatic reduction in hepatitis B through school-based immunization without a routine infant program in a low endemicity region. BMC Infect Dis. 2015;15:227. | 8
Poustchi H, Ostovaneh, et al. Impact of universal neonatal immunization to prevent mother-to-infant transmission of HBV. Hepatol Int. 2013;7:S262. | 11
Pressman A, et al. Vertical transmission of hepatitis B virus (HBV) due to immunization failure: a United States (US) population study. J Hepatol. 2012;56:S190. | 11
Przybilla J, Johnson A, Hooker C. Perinatal hepatitis B prevention: adapting Public Health Services to meet the changing needs of a diverse community. Public Health Rep. 2009;124(3):454-7. | 12
Pujol FH, Rodríguez I, Martínez N, et al. Viral hepatitis serological markers among pregnant women in Caracas, Venezuela: implication for perinatal transmission of hepatitis B and C. Gen. 1994;48(1):25-8. | 12
Puliyel J. Vaccine uptake rather than disease mitigation seems to be aim of universal hepatitis B vaccination in the UK. BMJ. 2013;347:f5187. | 3
Punzalan CM, et al. Factors associated with immunoprophylaxis failure against vertical transmission of hepatitis B virus among a cohort of New York City children and mothers. Hepatology. 2012;56:638A. | 11
Punzalan C, et al. Changing trends in the evaluation and management of pregnant women chronically infected with hepatitis B virus (HBV) in a New York city public health network, 2004-2010. Hepatology. 2011;54:885A. | 12
Qin G, Zhuang X. Cost-effectiveness of augmenting current perinatal hepatitis B prevention program with maternal antiviral therapy. Hepatology. 2017;65(3):1074-5. | 3
Qirbi N, Hall AJ. Epidemiology of hepatitis B virus infection in the Middle East. East Mediterr Health J. 2001;7(6):1034-45. | 3
Qirko R, et al. Evaluation of hepatitis B infection in pregnancy and fetal outcome. J Perinat Med. 2013;41. | 12
Quak SH. Hepatitis B vaccination programme in Singapore. Sing Paediatr J. 2001;43(4):124-5. | 12
Radoń-Pokracka M, Piasecki M, Lachowska A, et al. Assessment of the implementation of the infectious diseases screening programmes among pregnant women in the Lesser Poland region and comparison with similar programmes conducted in other European Union countries. Ginekol Pol. 2017;88(3):151-155. | 12
Rahim MN, et al. Outcomes of screening for hepatitis B virus during pregnancy. Gut. 2016;65:A271. | 12
Raimondo G, Tanzi E, et al. HBV transmission from mother to offspring. J Prev Med Hyg. 1993;34(1-2):9-10. | 11
Rajbhandari R, Barton, Juncadella AC, et al. Discontinuity of care for mothers with chronic hepatitis B diagnosed during pregnancy. J Viral Hepat. 2016;23(7):561-8. | 12
Rajbhandari R, Juncadella AC, et al. Inadequate hepatitis B care in mothers after pregnancy. Hepatology. 2014;60:945A. | 12
Ramia S, Arif M. Perinatal transmission of hepatitis B virus infection: a recommended strategy for prevention and control. A review. Br J Obstet Gynaecol. 1991;98(2):141-6. | 3
Rani M. Progress in hepatitis B vaccination and its impact on hepatitis B transmission in the Western Pacific region. Hepatol Res. 2010;40(7):726-7. | 3
Read JS, Cannon MJ, Stanberry LR, et al. Prevention of mother-to-child transmission of viral infections. Curr Probl Pediatr Adolesc Health Care. 2008;38(9):274-97. | 3
Reekie J, Gidding HF, Kaldor JM, et al. Country of birth and other factors associated with hepatitis B prevalence in a population with high levels of immigration. J Gastroenterol Hepatol. 2013;328(9):1539-44. | 12
Reznik RB. A hepatitis B vaccination programme for inner metropolitan Sydney neonates. Med J Aust. 1991;155(3):153-6. | 11
Roome A, Rak M, Hadler J. Follow-up of infants of hepatitis B-infected women after hepatitis B vaccination, Connecticut, 1994 to 1997. Pediatr Infect Dis J. 2000;19(6):573-5. | 11
Ropero Álvarez AM, Pérez-Vilar S, Pacis-Tirso C, et al. Progress in vaccination towards hepatitis B control and elimination in the Region of the Americas. BMC Public Health. 2017;17(1):325. | 8
Ross JW. Prenatal screening for hepatitis B antigen. JAMA. 1989;261(12):1727-8. | 12
Roure C. Overview of epidemiology and disease burden of hepatitis B in the European region. Vaccine. 1995;13(Suppl 1):S18-21. | 12
Rushworth RL, Bell SM, Morrell S, et al. Validation of hepatitis B surveillance data. Aust N Z J Public Health. 1997;21(2):217. | 12
Russell WJ. A retrospective study of the management of HIV, hepatitis B and hepatitis C-positive pregnancies in Edinburgh, UK from 1997-2002. McGill J Med. 2004;7(2):135-142. | 11
Ryoo, YG, Chang YH, Choi GS, et al. Hepatitis B viral markers in pregnant women and newborn infants in Korea. Korean J Intern Med. 1987;2(2):258-68. | 11
Sahhar L, et al. Prevention of vertical transmission of hepatitis B: an evaluation of adherence rates and risk factors for failure to provide immunoprophylaxis therapy in a single Australian centre. J Hepatol. 2015;62:S544. | 12
Sainato RJ, Simmons EG, Muench DF, et al. Management of infants born to women infected with hepatitis B in the military healthcare system. BMC Res Notes. 2013;6:338. | 11
Salemi JL, Spooner KK, Mejia de Grubb MC, et al. National trends of hepatitis B and C during pregnancy across sociodemographic, behavioral, and clinical factors, United States, 1998-2011. J Med Virol. 2017;89(6):1025-32. | 12
Salihu HM, Connell L, Salemi JL, et al. Prevalence and temporal trends of hepatitis B, hepatitis C, and HIV/AIDS co-infection during pregnancy across the decade, 1998-2007. J Womens Health (Larchmt). 2012;21(1):66-72. | 12
Salkin IF. Letter from America: incidence of acute hepatitis B in the United States, 1990-2002. AIDS Hepatitis Dig. 2004;6(100):6. | 3
Sapuri M, Babona DM, Klufio CA, et al. Hepatitis B surface and e antigen seropositivity in mothers and cord blood at Port Moresby General Hospital: implications for a control program. P N G Med J. 1991;34(4):234-7. | 12
Sarkar M, Terrault NA. Ending vertical transmission of hepatitis B: the third trimester intervention. Hepatology. 2014;60(2):448-51. | 3
Satodia P, Owoeye, et al. Maternal hepatitis B-does an integrated care pathway help in achieving complete immunisation schedule in babies? Arch Dis Child Fetal Neonatal Ed. 2014;99:A30. | 11
Schalm SW, Mazel JA, de Gast GC, et al. Prevention of hepatitis B infection in newborns through mass screening and delayed vaccination of all infants of mothers with hepatitis B surface antigen. Pediatrics. 1989;83(6):1041-8. | 9
Schalm SW, Pit-Grosheide P. Prevention of hepatitis B transmission at birth. Lancet. 1989;1(8628):44. | 3
Schillie S, Walker T, Veselsky S, et al. Outcomes of infants born to women infected with hepatitis B. Pediatrics. 2015;135(5):e1141-7. | 11
Schiraldi O, Dentico P. Virus B hepatitis and pregnancy. The fetus as a patient ‘88: Proceedings of the 4th International Symposium “The Fetus as a Patient” held in Bari, Italy, 22-24 September 1988 (International congress series): Excerpta Medica; 1989. p. 167-74. | 11
Schoen EJ. Special perinatal services in a large health maintenance organization. Curr Opin Pediatr. 1996;8(2):188-93. | 12
Schultz R, Romanes F, Krause V. Hepatitis B prevalence and prevention: antenatal screening and protection of infants at risk in the Northern Territory. Aust N Z J Public Health. 2008;32(6):575-6. | 12
Schwarz KB. More lessons from the Taiwanese hepatitis B virus vaccine program. J Infect Dis. 2012;205(5):702. | 3
Sekla LH, Hammond G, Stackiw W, et al. Testing pregnant women for HBsAg: a pilot study in Manitoba. Can Dis Wkly Rep. 1988;14(31):137-40. | 12
Sellier P, Lopes A, Bergmann JF, et al. Vertical transmission of hepatitis B virus. Ann Intern Med. 2014;161(10):762-3. | 3
Sharts-Hopko NC. Preventing hepatitis B in infants. Am J Matern Child Nurs. 1992;17(6):336. | 3
Shiraki K. Blocking of mother-to-infant transmission of hepatitis B virus. Asian Med J. 1988;31(6):348-54. | 12
Siney C. Routine antenatal hepatitis B (HBV) screening. MIDIRS Midwifery Dig. 1999;9(4):443-4. | 3
Smith N, Yusuf H, Averhoff F. Surveillance and prevention of hepatitis B virus transmission. Am J Public Health. 1999;89(1):11-13. | 3
Spada E, Tosti ME, Zuccaro O, et al; Collaborating Study Group. Evaluation of the compliance with the protocol for preventing perinatal hepatitis B infection in Italy. J Infect. 2011;62(2):165-71. | 12
Specialist Panel on Chronic Hepatitis B in the Middle East. A review of chronic hepatitis B epidemiology and management issues in selected countries in the Middle East. J Viral Hepat. 2012;19(1):9-22. | 3
Steben M. HBV Screening during pregnancy. Can Fam Physician. 1989;35:470-2. | 3
Stevens CE. Perinatal hepatitis B virus infection: screening of pregnant women and protection of the infant. Ann Intern Med. 1987;107(3):412-3. | 3
Stratton LE, et al. Improving referral of women with chronic hepatitis B from antenatal services to a specialist hepatitis clinic: the Northern Ireland experience. J Hepatol. 2015;62:S550. | 12
Stroffolini T, Bianco E, Szklo A, et al. Factors affecting the compliance of the antenatal hepatitis B screening programme in Italy. Vaccine. 2003;21(11-12):1246-9. | 12
Stroffolini T, Pasquini P. Five years of vaccination campaign against hepatitis B in Italy in infants of hepatitis B surface antigen carrier mothers. Ital J Gastroenterol. 1990;22(4):195-7. | 12
Stroffolini T, Pasquini P, Mele A. A nationwide vaccination programme in Italy against hepatitis B virus infection in infants of hepatitis B surface antigen-carrier mothers Vaccine. 1989;7(2):152-4. | 12
Stroffolini T, Pasquini, Mele A. HBsAg carriers among pregnant women in Italy: results from the screening during a vaccination campaign against hepatitis B. Public Health. 1988;102(4):329-33. | 12
Struve J. Hepatitis B virus infection among Swedish adults: aspects on seroepidemiology, transmission, and vaccine response. Scand J Infect Dis Suppl. 1992;82:1-57. | 12
Su WJ, Chen HL, Chang MH. Breakthrough hepatitis B virus (HBV) infection from mother-to-infant transmission is the key problem hindering HBV eradication. J Infect Dis. 2013;208(6):1036-7. | 3
Su WJ, Liu CC, Liu DP, et al. Effect of age on the incidence of acute hepatitis B after 25 years of a universal newborn hepatitis B immunization program in Taiwan. J Infect Dis. 2012;205(5):757-62. | 12
Su WJ, et al. Reduction of the incidence of acute hepatitis B after universal hepatitis B immunization program in Taiwan. Hepatol Int. 2010;4(1):104. | 12
Sugiura T, et al. Implementation of a new protocol to prevent mother-to-child transmission of hepatitis B virus infection in Japan. J Pediatr Gastroenterol Nutr. 2016;63:S204-5. | 11
Sugiyama A, Ohisa M, Nagashima S, et al. Reduced prevalence of hepatitis B surface antigen positivity among pregnant women born after the national implementation of immunoprophylaxis for babies born to hepatitis B virus-carrier mothers in Japan. Hepatol Res. 2017;47(12):1329-34. | 12
Sugiyama H, et al. Factors in vertical transmission of HBV. Acta Paediatr Jpn. 1986;28(3):317-22. | 3
Sun HY, Ko WC, Tsai JJ, et al. Seroprevalence of chronic hepatitis B virus infection among Taiwanese human immunodeficiency virus type 1-positive persons in the era of nationwide hepatitis B vaccination. Am J Gastroenterol. 2009;104(4):877-84. | 6
Sung JL. Hepatitis B virus eradication strategy for Asia. The Asian Regional Study Group. Vaccine. 1990;8(Suppl):S95-9. | 12
Sweet LE, Brown MG, Lee SH, et al. Hepatitis B prenatal screening survey, Nova Scotia, 1990-1991. Can J Public Health. 1993;84(4):279-82. | 12
Tada H, Uga N, Fuse Y, et al. Prevention of perinatal transmission of hepatitis B virus carrier state. Acta Paediatr Jpn. 1992;34(6):656-9. | 9
Tada H, et al. Combined passive and active immunization for preventing perinatal transmission of hepatitis B virus carrier state. Acta Paediatr Jpn. 1986;28(3):306-1. | 9
Takahashi K, Kobayashi J, Sugiura Y. The relevance of Japan’s hepatitis vaccine policy to national hepatitis B prevention and control. J Public Health Policy. 2012;33(1):136-8. | 3
Takano T, Tajiri H, Hosono S. Natural history of chronic hepatitis B virus infection in children in Japan: a comparison of mother-to-child transmission with horizontal transmission. J Gastroenterol. 2017;52(9):1041-50. | 1
Tam FK, et al. Antenatal hepatitis B screening in women from the Mainland China versus local residents. Hepatol Int. 2009;3(1):128. | 12
Tan SS, Chua A. Preventing mother-to-child transmission of hepatitis B virus - a success story which can be enhanced. Med J Malaysia. 2013;68(2):103-4. | 3
Tang JR, Hsu HY, Lin HH. Hepatitis B surface antigenemia at birth: a long-term follow-up study. J Pediatr. 1998;133(3):374-7. | 11
Tao G, et al. Suboptimal prenatal testing for syphilis and other STDs among commercially-insured women in the United States, 2013. Sex Transm Infect. 2015;91:A154-5. | 12
Tash E, Cacciottolo T, Wright N, et al. Hepatitis B prevalence in a multi-ethnic community in South England: a 3 year retrospective study. Public Health. 2014;128(8):764-5. | 12
Taylor MJ, Liversedge H, et al. Implementation of an NHS first trimester screening clinic. Ultrasound. 2008;16(2):105-9. | 12
Tehami N, et al. Outcome of the management of hepatitis B infection in pregnancy. Gut. 2011;60:A248-9. | 12
Tekin Koruk S, Batirel A, Kose S, et al. Evaluation of hepatitis B virus transmission and antiviral therapy among hepatitis B surface antigen-positive pregnant women. J Obstet Gynaecol Res. 2015;41(12):1870-6. | 9
Terrault NA, Lok AS, McMahon BJ, et al. Update on prevention, diagnosis, and treatment of chronic hepatitis B: AASLD 2018 hepatitis B guidance. Hepatology. 2018;67(4):1560-99. | 3
Thanuntaseth C, Theppisai U, Chiewsilp P, et al. Prevalence of HBe Ag (hepatitis B e antigen) and anti-HBe (anti-hepatitis B e) in asymptomatic HBs Ag carrier mothers and HBV infection in their families. J Med Assoc Thai. 1988;71(Suppl 1):98-101. | 12
Thies N. Universal neonatal immunization for hepatitis B. J Paediatr Child Health. 2002;38(2):211; author reply 211-2. | 3
Thomas AR, Fiore AE, Corwith HL, et al. Hepatitis B vaccine coverage among infants born to women without prenatal screening for hepatitis B virus infection: effects of the Joint Statement on Thimerosal in Vaccines. Pediatr Infect Dis J. 2004;23(4):313-8. | 12
Thompson SC. Perinatal transmission of hepatitis B virus: an Australian experience. Med J Aust. 2009;191(6):357; author reply 357. | 3
Thompson SC, Oman K. Why should Australia adopt universal infant hepatitis B vaccination? Aust N Z J Public Health. 1996;20(4):436-9. | 3
Thompson SC, Stevenson E, Wilby R, et al. Hepatitis B infection in Victoria 1992: time to review the high-risk vaccination strategy. Med J Aust. 1993;159(8):562-3. | 12
Thursz M, Njie R, Lemoine M. Hepatitis: global eradication of hepatitis B-feasible or fallacy? Nat Rev Gastroenterol Hepatol. 20129(9):492-4. | 3
Thye HM, deCosta C. Screening for hepatitis B in antenatal patients. Med J Aust. 1987;147(4):202. | 12
Torii Y, Kimura H, Hayashi K, et al. Causes of vertical transmission of hepatitis B virus under the at-risk prevention strategy in Japan. Microbiol Immunol. 2013;57(2):118-21. | 11
Torii Y, Kimura H, Ito Y, et al. Clinicoepidemiologic status of mother-to-child infections: a nationwide survey in Japan. Pediatr Infect Dis J. 2013;32(6):699-701. | 11
Tormans G, Van Damme P, Carrin G, et al. Cost-effectiveness analysis of prenatal screening and vaccination against hepatitis B virus-the case of Belgium. Soc Sci Med. 1993;37(2):173-81. | 2
Tran TT. Hepatitis B virus in pregnancy. Clin Liver Dis. 2013;2(1):29-33. | 3
Tran TT, et al. Management of the pregnant hepatitis B patient. Curr Hepat Rep. 2008;7(1):12-7. | 3
Tran TT, Martin P. Hepatitis B: epidemiology and natural history. Clin Liver Dis. 2004;8(2):255-66. | 3
Tuinakelo LR, Tayler-Smith K, Khogali M, et al. Prevalence of anaemia, syphilis and hepatitis B in pregnant women in Nausori, Fiji. Public Health Action. 2013;3(1):72-5. | 12
Turine-Neto P, Figueiró-Filho EA, et al. Frequency of sexually transmitted diseases in pregnant women from Brazil. Int J Gynecol Obstet. 2009;107:S574. | 12
Ugbebor OU, et al. Risk reduction approach for the prevention of maternal-infant transmission of viral hepatitis B in high endemic areas. J Clin Exp Hepatol. 2013;3(1):S48. | 11
Umar M, Hamama-Tul-Bushra, Umar S, et al. HBV perinatal transmission. Int J Hepatol. 2013;2013:875791. | 3
Van Damme P, Leuridan E, Hendrickx G, et al. Should Europe have a universal hepatitis B vaccination programme? BMJ. 2013;347:f4057. | 3
van Schalkwyk J, Nourmoussavi M, Massey A, et al. Missed opportunities for prevention of perinatal transmission of hepatitis B: a retrospective cohort study. Can J Gastroenterol Hepatol. 2014;28(10):525-8. | 11
van Steenbergen JE, Baayen D, Peerbooms PG, et al. Much gained by integrating contact tracing and vaccination in the hepatitis B antenatal screening program in Amsterdam, 1992-1999. J Hepatol. 2004;40(6):979-85. | 12
van Steenbergen JE, Leentvaar-Kuijpers, Baayen D, et al. Evaluation of the hepatitis B antenatal screening and neonatal immunization program in Amsterdam, 1993-1998. Vaccine. 2001;20(1-2):7-11. | 11
Vegnente A, Iorio R, de Rosa E. Universal hepatitis B immunization: the dose of HBIg that should be administered at birth. Pediatrics. 1994;94(2 Pt 1):242-3. | 3
Ramanan PV, Premkumar S, Khanna P, et al. Seroconversion rate after postnatal immunoprophylaxis for exposed infants in prevention of hepatitis B vertical transmission. J Trop Pediatr. 2011;57(5):399. | 4
Walker TY, Smith EA, Fenlon N, et al. Characteristics of pregnant women with hepatitis B virus infection in 5 US public health jurisdictions, 2008-2012. Public Health Rep. 2016;131(5):685-94. | 12
Walz A, Wirth S, Hucke J, et al. Vertical transmission of hepatitis B virus (HBV) from mothers negative for HBV surface antigen and positive for antibody to HBV core antigen. J Infect Dis. 2009;200(8):1227-31. | 11
Wang AL, Qiao YP, Wang LH, et al. Integrated prevention of mother-to-child transmission for human immunodeficiency virus, syphilis and hepatitis B virus in China. Bull World Health Organ. 2015;93(1):52-6. | 12
Wang F, Zhang G, Zheng H, et al. Post-vaccination serologic testing of infants born to hepatitis B surface antigen positive mothers in 4 provinces of China. Vaccine. 2017;35(33):4229-35. | 11
Wang F, Zheng H, Zhang G, et al. Effectiveness of prevention of mother-to-child transmission practice in three provinces of Southern China. Hum Vaccin Immunother. 2015;11(8):2061-7. | 11
Wang SH, et al. Comprehensive management of pregnant hepatitis B patients in a community health setting: the Hepatitis B Moms Program. Hepatology. 2012;56:360A. | 12
Ward JW, Byrd KK. Hepatitis B in the United States: a major health disparity affecting many foreign-born populations. Hepatology. 2012;56(2):419-21. | 3
Waters JR. Universal prenatal screening for hepatitis B, Alberta, 1985-1988. Can Dis Wkly Rep. 1989;15(6):29-32. | 12
Waters VV. Prevalence of hepatitis B in pregnant women. JAMA. 1992;267(14):1919; author reply 1920. | 3
Weerasinghe I, Bannister N, Huang V, et al. The role of the patient-centered medical home in addressing hepatitis B perinatal transmission: Charles B. Wang Community Health Center’s Hep B Moms Program. AAPI Nexus. 2014;12(1-2):140-60. | 12
Weis N, Cowan S, Hallager S, et al. Vertical transmission of hepatitis B virus during pregnancy and delivery in Denmark. Scand J Gastroenterol. 2017;52(2):178-84. | 11
Wendland A, Ehmsen BK, Lenskjold V, et al. Undocumented migrant women in Denmark have inadequate access to pregnancy screening and have a higher prevalence hepatitis B virus infection compared to documented migrants in Denmark: a prevalence study. BMC Public Health. 2016;16:426. | 12
West DJ, Margolis HS. Prevention of hepatitis B virus infection in the United States: a pediatric perspective. Pediatr Infect Dis J. 1992;11(10):866-74. | 3
White CB, Pratt SR, Bass JW, et al. Prenatal screening for hepatitis B infection in the military population in Hawaii. Pediatr Infect Dis J. 1988;7(2):138-40. | 12
Willis BC, Wortley P, Wang SA, et al. Gaps in hospital policies and practices to prevent perinatal transmission of hepatitis B virus. Pediatrics. 2010;125(4):704-11. | 12
Wiseman E, Fraser MA, Holden S, et al. Perinatal transmission of hepatitis B virus: an Australian experience. Med J Aust. 2009;190(9):489-92. | 11
Withers J, Bradshaw E. Preventing neonatal hepatitis-B infection. Am J Matern Child Nurs. 1986;11(4):270-2. | 3
Wong WC, Tsang KK. A mass hepatitis B vaccination programme in Taiwan: its preparation, results and reasons for uncompleted vaccinations. Vaccine. 1994;12(3):229-34. | 11
Wood N, Warlow M, Quinn H, et al. Establishment of a surveillance system (utilising Midwifes Data Collection Systems) for monitoring the impact of hepatitis B vaccination on the population prevalence of chronic hepatitis B virus infection in Australia. Aust N Z J Public Health. 2008;32(3):272-5. | 12
Wozniak TM, Smith M, Maher L. Hepatitis B. N S W Public Health Bull. 2013;24(2):94. | 3
Wu CH, Hsu TY, Kung FT, et al. Changes in the prevalence of HBsAg and HBeAg: a study of 8696 parturients in a well vaccinated area. Sci Rep. 2017;7(1):1212. | 8
Wu DY, et al. Inadequate treatment of chronic hepatitis B in pregnant women at high risk for vertical transmission. Hepatology. 2015;62:1001A. | 12
Xiaoyan Wet al. Analysis of testing and infection status of hepatitis B among maternities during 2012-2014 in China. Hepatol Int. 2017;11(1):S32. | 12
Xu Y, et al. The next step in controlling HBV in China: focus on preventing perinatal transmission of the virus. BMJ. 2013;347(7918). | 3
Yang M, et al. Five years epidemiological trends and virological traits of hepatitis B virus infection in pregnant women and neonates. Hepatol Int. 2017;11(1):S72-3. | 11
Yano M, et al. Prevention of HBV mother-infant transmission. Acta Paediatr Jpn. 1986;28(3):300-5. | 9
Yao JL. Perinatal transmission of hepatitis B virus infection and vaccination in China. Gut. 1996;38(Suppl 2):S37-8. | 3
Yap PS, Moons V. Hepatic problems during pregnancy. Neth J Med. 2002;60(9):340-2. | 3
Yee Leung NW. How to prevent HBV infection in infants born to high viraemic carriers. J Gastroenterol Hepatol. 2012;27:25. | 3
Yeh CT, Lai MW. Eliminating hepatitis B virus through neonatal vaccination: can we make it? J Hepatol. 2012;57(3):484-5. | 3
Yeo Y, Gwack J, Kang S, et al. Viral hepatitis and liver cancer in Korea: an epidemiological perspective. Asian Pac J Cancer Prev. 2013;14(11):6227-31. | 3
Yonghao G, Pumei D, Jianhui Y, et al. A retrospective study of hepatitis B mother-to-child transmission prevention and postvaccination serological test results of infants at risk of perinatal transmission in two counties of middle China. J Viral Hepat. 2017;24(8):687-95. | 9
Yoo KY. Viral hepatitis and liver cancer in Korea: an epidemiologic perspective. Hepatol Int. 2012;6(1):10. | 12
Yoshizawa H. Trends of hepatitis virus carriers; Hepatol Res; 2002;24(Suppl 1):S28-39. | 12
Yusuf HR, Mahoney FJ, Shapiro CN, et al. Hospital-based evaluation of programs to prevent perinatal hepatitis B virus transmission. Arch Pediatr Adolesc Med. 1996;150(6):593-7. | 12
Zahirovic A, et al. Comparation of congenital and perinatal infections in Bosnia as increasing number in last decade. Intensive Care Med. 2011;37:S436. | 3
Zanetti AR. Maternal-neonatal transmission of hepatitis B virus. Epidemiology and prevention. Ann Ist Super Sanita. 1987;24(2):277-84. | 3
Zhai X, et al. Prevention of perinatal transmission of hepatitis B: a retrospective cohort study in China. Hepatology. 2015;62:982A. | 11
Zhang F, Zhang Y. Perinatal transmission of hepatitis B virus: could hospitals be doing more? Exp Rev Anti Infect Ther. 2010;8(7):735-8. | 3
Zhang L, Gui X, Wang B, et al. A study of immunoprophylaxis failure and risk factors of hepatitis B virus mother-to-infant transmission. Eur J Pediatr. 2014;173(9):1161-8. | 11
Zhang L, Ko S, Lv J, et al. Perinatal hepatitis B prevention program in Shandong Province, China. Evaluation and progress. Hum Vaccin Immunother. 2014;10(9):2755-60. | 12
Zhao Z, Murphy TV, Jacques-Carroll L. Progress in newborn hepatitis B vaccination by birth year cohorts-1998-2007, USA. Vaccine. 2011;30(1):14-20. | 12
Zhou Y, He H, Deng X, et al. Significant reduction in notification and seroprevalence rates of hepatitis B virus infection among the population of Zhejiang Province, China, aged between 1 and 29 years from 2006 to 2014. Vaccine. 2017;35(34):4355-61. | 12
Zimmerman R. Prenatal screening for hepatitis B. J Fam Pract. 1990;30(4):392-3. | 3
Zuckerman E, et al. Hepatitis B virus infection after the implementation of the vaccine program in Israel. Hepatology. 2017;66:1030A-1. | 12