# Appendix A Literature Search Strategies for Primary Literature

Screening for Hepatitis B Virus Infection in Pregnant Women | Search strategies

Smyth Lai, 09/26/2017

Sources searched:

Cumulative Index for Nursing and Allied Health Literature (CINAHL), via EBSCO

Cochrane Central Register of Controlled Clinical Trials, via Wiley

Cochrane Database of Systematic Reviews, via Wiley

EMBASE

MEDLINE, via Ovid

PsycInfo, via Ovid

PubMed, publisher-supplied

Key:

- * = truncation
- $ = truncation
- ab = word in abstract
- de = index term
- exp = explode
- id = keyword
- kw = keyword
- la = language
- lim = limit
- py = publication year
- ti = word in title

## CINAHL

Published Date: 1986 01/01-2017 12/31; English Language; Exclude MEDLINE records

S12 | S3 AND S11
S11 | S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10
S10 | TI (((vertical* or maternal* or mother or fetomaternal* or foetomaternal* or maternofetal* or maternofoetal*) N3 (transmission or transmit* or transfer*)) OR AB (((vertical* or maternal* or mother or fetomaternal* or foetomaternal* or maternofetal* or maternofoetal*) N3 (transmission or transmit* or transfer*))
S9 | TI ((pregnan* or prenatal or “pre natal” or perinatal or “peri natal” or peripartum or “peri partum” or obstetric*)) OR AB ((pregnan* or prenatal or “pre natal” or perinatal or “peri natal” or peripartum or “peri partum” or obstetric*))
S8 | (MH “Disease Transmission, Vertical”)
S7 | (MH “Pregnancy Outcomes”)
S6 | (MH “Prenatal Care”) OR (MH “Maternal-Child Care”) OR (MH “Obstetric Care”) OR (MH “Perinatal Care”)
S5 | (MH “Pregnancy+”) OR (MH “Pregnancy Trimesters+”)
S4 | (MH “Expectant Mothers”)
S3 | (S1 OR S2)
S2 | TI ((“hepatitis b” or hbv)) OR AB ((“hepatitis b” or hbv))
S1 | (MH “Hepatitis B”) OR (MH “Hepatitis B, Chronic”)

Cochrane Central Register of Controlled Trials: Issue 8 of 12, August 2017

#1 | (“hepatitis b” or hbv):ti,ab,kw
#2 | pregnan*:ti,ab,kw
#3 | (prenatal or “pre natal”):ti,ab,kw
#4 | (perinatal or “peri natal”):ti,ab,kw
#5 | (antenatal or “anti natal”):ti,ab,kw
#6 | (antepartum or “ante partum”):ti,ab,kw
#7 | (peripartum or “peri partum”):ti,ab,kw
#8 | obstetric*:ti,ab,kw
#9 | (vertical* or maternal* or mother or fetomaternal* or foetomaternal* or maternofetal* or maternofoetal*):ti,ab,kw near/3 (transmission or transmit* or transfer*):ti,ab,kw
#10 | ^41-#9-#9^ 41439
#11 | #1 and #10 Publication Year from 1986 to 2017

## EMBASE

#17; #16 AND ‘english’:la AND [1986-2017]/py
#16; #4 AND #15
#15; #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #14
#14; #12 AND #13
#13; ‘transmission’:ti OR ‘transmit*’:ti OR ‘transfer*’:ti
#12; ‘vertical*’:ti OR ‘maternal*’:ti OR ‘mother’:ti OR ‘fetomaternal*’:ti OR ‘foetomaternal*’:ti OR ‘maternofetal*’:ti OR ‘maternofoetal*’:ti
#11; ‘pregnan*’:ti OR ‘prenatal’:ti OR ‘pre natal’:ti OR ‘perinatal’:ti OR ‘peri natal’:ti OR ‘peripartum’:ti OR ‘peri partum’:ti OR ‘obstetric*’:ti
#10; ‘vertical transmission’/de
#9; ‘obstetric procedure’/de
#8; ‘perinatal care’/de OR ‘perinatal period’/de OR ‘perinatal exposure’/de
#7; ‘prenatal care’/de OR ‘prenatal period’/de OR ‘prenatal exposure’/de
#6; ‘pregnant woman’/de
#5; ‘pregnancy’/exp
#4; #1 OR #2 OR #3
#3; ‘hepatitis b’:ti,ab,kw OR ‘hbv’:ti,ab,kw
#2; ‘hepatitis b virus’/exp
#1; ‘hepatitis b’/exp

## MEDLINE

Database: Ovid MEDLINE(R) <1946 to September Week 2 2017>, Ovid MEDLINE(R) Epub Ahead of Print <September 25, 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <September 25, 2017>, Ovid MEDLINE(R) Daily Update <September 25, 2017>

Search Strategy:

1 | Hepatitis B/
2 | Hepatitis B, Chronic/
3 | Hepatitis B virus/
4 | (hepatitis b or hbv).ti,ab.
5 | or/1-4
6 | Pregnancy/
7 | Pregnancy Trimester, First/
8 | Pregnancy Trimester, Second/
9 | Pregnancy Trimester, Third/
10 | Pregnant women/
11 | Prenatal Care/
12 | Perinatal Care/
13 | Prenatal Diagnosis/
14 | Pregnancy Outcome/
15 | Pregnancy Complications, Infectious/
16 | Infectious Disease Transmission, Vertical/
17 | (pregnan$ or prenatal or pre natal or perinatal or peri natal or antenatal or ante natal or antepartum or ante partum or peripartum or peri partum or obstetric$).ti,ab.
18 | ((vertical$ or maternal$ or mother or fetomaternal$ or foetomaternal$ or maternofetal$ or maternofoetal$) adj3 (transmission or transmit$ or transfer$)).ti,ab.
19 | or/6-18
20 | 5 and 19
21 | Animals/ not (Humans/ and Animals/)
22 | 20 not 21
23 | limit 22 to (english language and yr=“1986 -Current”)
24 | remove duplicates from 23

## PsycInfo

Database: PsycINFO <1806 to September Week 3 2017>

1 | (hepatitis b or HBV).ti,ab,id.
2 | Pregnancy/
3 | Prenatal Care/
4 | Perinatal Period/
5 | Expectant Mothers/
6 | Mother Child Relations/
7 | Obstetrics/
8 | Pregnancy Outcomes/
9 | pregnan$.ti,ab,id.
10 | prenatal.ti,ab,id.
11 | pre natal.ti,ab,id.
12 | perinatal.ti,ab,id.
13 | peri natal.ti,ab,id.
14 | peripartum.ti,ab,id.
15 | peri partum.ti,ab,id.
16 | obstetric$.ti,ab,id.
17 | ((vertical$ or maternal$ or mother or fetomaternal$ or foetomaternal$ or maternofetal$ or maternofoetal$) adj3 (transmission or transmit$ or transfer$)).ti,ab,id.
18 | or/2-17
19 | 1 and 18
20 | limit 19 to (english language and yr=“1986 -Current”)

## PubMed [publisher-supplied records]

#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | #4 AND publisher[sb] AND English[Language] AND (“1986”[Date - Publication]: “3000”[Date - Publication])
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | #1 AND (#2 OR #3)
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | (vertical*[tiab] OR maternal*[tiab] OR mother[tiab] OR fetomaternal*[tiab] OR foetalmaternal*[tiab] OR maternofetal*[tiab] OR maternofoetal*[tiab]) AND (transmission[tiab] OR tranmit*[tiab] OR transfer*[tiab])
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | pregnan*[tiab] OR prenatal[tiab] OR “pre natal”[tiab] OR perinatal[tiab] OR “peri natal”[tiab] OR antenatal[tiab] OR “ante natal”[tiab] OR antepartum[tiab] OR “ante partum”[tiab] OR peripartum[tiab] OR “peri partum”[tiab] OR obstetric*[tiab]
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | “hepatitis b”[tiab] OR hbv[tiab]

Appendix A Table 1 Inclusion and Exclusion Criteria

| Included | Excluded
Aim | To evaluate the effects of prenatal screening for hepatitis B virus infection on health outcomes and transmission rates and the effects of management and treatment programs among pregnant women with hepatitis B virus infection
Populations | KQs 1, 2: Pregnant women at any gestation who are not known to have an acute or chronic hepatitis B virus infection; KQs 3, 4: Pregnant women with acute or chronic hepatitis B virus infection | KQs 1, 2: Pregnant women who are known to have hepatitis B virus infection; women who are not pregnant; male partners of pregnant women
Interventions | KQs 1, 2: Universal screening for hepatitis B surface antigen; KQs 3, 4: Organized programs aimed at preventing vertical transmission of hepatitis B virus infection among pregnant women; management and followup programs that deliver effective/recommended prophylactic interventions for women and neonates to reduce vertical transmission of hepatitis B virus infection | KQs 1, 2: Viral load followup testing among screen-positive women
Comparisons | KQs 1, 2: No screening; targeted screening; KQs 3, 4: Comparisons of vertical transmission of hepatitis B virus infection associated with program implementation across time, geographic sites, or populations, both with and without case management for followup and immunotherapy
Outcomes | KQs 1, 3: Mother-to-child transmission of hepatitis B virus infection; infant morbidity and mortality from perinatal hepatitis B virus infection; KQ 2: Harms from the screening test or receipt of test results; KQ 4: Harms from management of screen-detected hepatitis B virus infection; negative effects on maternal and infant health | KQ 1: Diagnostic accuracy; KQ 3: Effects of individual interventions for hepatitis B virus infection (e.g., antiviral treatment) administered outside of a care program; KQ 4: Harms of specific pharmacologic interventions
Setting | Any health care setting or level of care | Settings where universal vaccination of newborns for hepatitis B virus infection is not recommended or practiced
Country | Studies conducted in countries categorized as “high” to “very high” on the Human Development Index (as defined by the United Nations Development Programme) | Studies conducted in countries not categorized as “high” or “very high” on the Human Development Index
Study Design | KQ 1: Randomized or clinical controlled trials, systematic reviews, before-after, and observational cohort and ecologic studies with a historical or geographic comparator; KQs 2–4: All of the above plus cohort studies, case series, and registry data | KQs 3, 4: Trials examining the effectiveness of individual pharmacologic treatments to prevent vertical transmission of hepatitis B virus infection administered outside of a care management program
Language | English-language only | Languages other than English
Study Quality | Fair- or good-quality studies | Poor-quality studies
Publication Dates | 1986 to the present | Studies conducted prior to the introduction of vaccination for hepatitis B virus infection

Appendix A Table 2 Quality Rating Criteria

Study Design | Criteria
Cohort studies, adapted from the Newcastle-Ottawa Scale^55^ | Was the exposed cohort(s) representative of the general population?; Was the non-exposed cohort selected from the same community as the exposed cohort?; How was “exposure” ascertained?; Was it demonstrated that the outcome of interest was not present at the start of the study?; Were the cohorts comparable on the basis of the design or analysis?; Were outcome assessors blind?; Was followup long enough for outcomes to occur?; Was there adequate followup of cohorts?
National Heart, Lung, and Blood Institute tool for before-after (prepost) studies with no control group^54^ | Was the study question or objective clearly stated?; Were eligibility/selection criteria prespecified and clearly described?; Were participants representative of the general population?; Were all eligible participants enrolled?; Was the sample size sufficiently large?; Was the test/service/intervention clearly described and delivered consistently?; Were the outcome measures prespecified, clearly defined, valid, reliable, and assessed consistently?; Were outcome assessors blind?; Was loss to followup ≤20% and those lost to follow-up accounted for in analysis?; Did statistical methods examine changes in outcome measures from before to after the intervention? Were p values provided?; Were outcome measures taken multiple times before and after the intervention?; If a group-level intervention, did statistical analysis take into account the use of individual-level data to determine group-level effects?

Appendix A Figure 1 Literature Flow Diagram

Appendix A Figure 1 displays the literature search results and article flow for the review. A total of 5,686 articles were identified through database searching and 2 articles through other sources. 5,688 articles were screened and 499 full-text articles were assessed for eligibility. 2 articles (2 studies) were included for KQ3. No articles were included for any other key question.