# References

1 Centers for Disease Control and Prevention. 1993 Revised classification system for HIV infection and expanded surveillance case definition for AIDS among adolescents and adults. MMWR Recomm Rep. 1992 December 18;41(RR-17) PMID: 1361652.1361652
2 Centers for Disease Control and Prevention. HIV-2 Infection Surveillance- United States, 1987-2009. 2011. https://www.cdc.gov/mmwr/preview/mmwrhtml/mm6029a3.htm. Accessed December 8, 2017.
3 Centers for Disease Control and Prevention. HIV surveillance report. Volume 28. Diagnoses of HIV infection in the United States and dependent areas, 2016. 2016. https://www.cdc.gov/hiv/pdf/library/reports/surveillance/cdc-hiv-surveillance-report-2016-vol-28.pdf. Accessed December 8, 2017.
4 Dailey AF, Hoots BE, Hall HI, . Vital aigns: human immunodeficiency virus testing and diagnosis delays - United States. MMWR Morb Mortal Wkly Rep. 2017 Dec 1;66(47):1300–6. doi: 10.15585/mmwr.mm6647e1. PMID: 29190267.29190267
5 Centers for Disease Control and Prevention. HIV in the United States. 2011. http://www.cdc.gov/hiv/resources/factsheets/us.htm. Accessed December 8, 2017.
6 Centers for Disease Control and Prevention. HIV surveillance - United States, 1981-2008. MMWR Morb Mortal Wkly Rep. 2011;60(21):689–93. PMID: 21637182.21637182
7 Campsmith ML, Rhodes PH, Hall I, . Undiagnosed HIV prevalence among adults and adolescents in the United States at the end of 2006. J Acquir Immune Defic Syndr. 2010;53:619–24. PMID: 19838124.19838124
8 Prejean J, Song R, Hernandez A, . Estimated HIV incidence in the United States, 2006–2009. PLoS One. 2011 Aug 3;6(8):e17502. doi:10.1371/journal.pone.0017502. PMID: 21826193.21826193
9 Quinn TC, Wawer MJ, Sewankambo NK, . Viral load and heterosexual transmission of human immunodeficiency virus type 1. N Engl J Med. 2000;342(13):921–9. PMID: 10738050.10738050
10 Gray RH, Wawer MJ, Brookmeyer R, . Probability of HIV-1 transmission per coital act in monogamous, heterosexual, HIV-1-discordant couples in Rakai, Uganda. Lancet. 2001;357(9263):1149–53. doi: 10.1016/s0140-6736(00)04331-2. PMID: 11323041.11323041
11 Doherty MC, Garfein RS, Monterroso E, . Correlates of HIV infection among young adult short-term injection drug users. AIDS. 2000 Apr 14;14(6):717–26. PMID: 10807195.10807195
12 Kahn JO, Walker BD. Acute human immunodeficiency virus type 1 infection. N Engl J Med. 1998;339(1):33–9. doi: 10.1056/NEJM199807023390107. PMID: 9647878.9647878
13 Schacker T, Collier AC, Hughes J, . Clinical and epidemiologic features of primary HIV infection. Ann Intern Med. 1996 Aug 15;125(4):257–64. PMID: 8678387.8678387
14 Vanhems P, Allard R, Cooper DA, . Acute human immunodeficiency virus type 1 disease as a mononucleosis-like illness: is the diagnosis too restrictive? Clin Infect Dis. 1997 May 1, 1997;24(5):965–70. doi: 10.1093/clinids/24.5.965. PMID: 9142802.9142802
15 Daar ES, Moudgil T, Meyer RD, . Transient high levels of viremia in patients with primary human immunodeficiency virus type 1 infection. N Engl J Med. 1991;324(14):961–4. doi: 10.1056/NEJM199104043241405. PMID: 1823118.1823118
16 Henrard DR, Phillips JF, Muenz LR, . Natural history of HIV-1 cell-free viremia. JAMA. 1995 Aug 16;274(7):554–8. PMID: 7629984.7629984
17 Ho DD, Neumann AU, Perelson AS, . Rapid turnover of plasma virions and CD4 lymphocytes in HIV-1 infection. Nature. 1995 Jan 12;373(6510):123–6. doi: 10.1038/373123a0. PMID: 7816094.7816094
18 Schacker TW, Hughes JP, Shea T, . Biological and virologic characteristics of primary HIV infection. Ann Intern Med. 1998 Apr 15;128(8):613–20. PMID: 9537934.9537934
19 Touloumi G, Pantazis N, Babiker AG, . Differences in HIV RNA levels before the initiation of antiretroviral therapy among 1864 individuals with known HIV-1 seroconversion dates. AIDS. 2004 Aug 20;18(12):1697–705. PMID: 15280781.15280781
20 Wei X, Ghosh SK, Taylor ME, . Viral dynamics in human immunodeficiency virus type 1 infection. Nature. 1995 Jan 12;373(6510):117–22. doi: 10.1038/373117a0. PMID: 7529365.7529365
21 Collaborative Group on AIDS Incubation and HIV Survival including the CASCADE EU Concerted Action. Time from HIV-1 seroconversion to AIDS and death before widespread use of highly-active antiretroviral therapy: a collaborative re-analysis. Lancet. 2000 Apr 2000;355(9210):1131–7. PMID: 10791375.10791375
22 Koblin B, van Benthem B, Buchbinder S, . Long-term survival after Infection with human immunodeficiency virus type 1 (HIV-1) among homosexual hen in hepatitis B vaccine trial cohorts in Amsterdam, New York City, and San Francisco, 1978–1995. Am J Epidemiol. 1999 November 15, 1999;150(10):1026–30. PMID: 10568617.10568617
23 Stein DS, Korvick JA, Vermund SH. CD4+ lymphocyte cell enumeration for prediction of clinical course of human immunodeficiency virus disease: a review. J Infect Dis. 1992 Feb;165(2):352–63. PMID: 1346152.1346152
24 Kaslow RA, Phair JP, Friedman HB, . Infection with the human immunodeficiency virus: clinical manifestations and their relationship to immune deficiency. A report from the Multicenter AIDS Cohort Study. Ann Intern Med. 1987 Oct;107(4):474–80. PMID: 2957944.2957944
25 Phillips A, Gazzard B, Gilson R, . Rate of AIDS diseases or death in HIV-infected antiretroviral therapy-naive individuals with high CD4 cell count. AIDS. 2007;21(13):1717–21. PMID: 17690569.17690569
26 Egger M, May M, Chene G, . Prognosis of HIV-1-infected patients starting highly active antiretroviral therapy: a collaborative analysis of prospective studies. Lancet. 2002 Jul 2002;360(9327):119–29. PMID: 12126821.12126821
27 Phillips A, Pezzotti P. Short-term risk of AIDS according to current CD4 cell count and viral load in antiretroviral drug-naive individuals and those treated in the monotherapy era. AIDS. 2004 Jan 2004;18(1):51–8. PMID: 15090829.15090829
28 Phillips AN, Lee CA, Elford J, . Serial CD4 lymphocyte counts and development of AIDS. Lancet. 1991 Feb 1991;337(8738):389–92. PMID: 1671424.1671424
29 Mellors JW, Kingsley LA, Rinaldo CR, Jr., . Quantitation of HIV-1 RNA in plasma predicts outcome after seroconversion. Ann Intern Med. 1995 Apr 1995;122(8):573–9. PMID: 7887550.7887550
30 Mellors JW, Munoz A, Giorgi JV, . Plasma viral load and CD4+ lymphocytes as prognostic markers of HIV-1 infection. Ann Intern Med. 1997 Jun 1997;126(12):946–54. PMID: 9182471.9182471
31 Phair JP, Mellors JW, Detels R, . Virologic and immunologic values allowing safe deferral of antiretroviral therapy. AIDS. 2002 Dec 2002;16(18):2455–9. PMID: 12461420.12461420
32 Babiker AG, Peto T, Porter K, . Age as a determinant of survival in HIV infection. J Clin Epidemiol. 2001 Dec;54: Suppl 1:S16–21. PMID: 11750205.11750205
33 Vella S, Giuliano M, Floridia M, . Effect of sex, age and transmission category on the progression to AIDS and survival of zidovudine-treated symptomatic patients. AIDS. 1995 Jan;9(1):51–6. PMID: 7893441.7893441
34 Pedersen C, Lindhardt BO, Jensen BL, . Clinical course of primary HIV infection: consequences for subsequent course of infection. BMJ. 1989;299(6692):154–7. PMID: 2569901.2569901
35 de Roda Husman A-M, Koot M, Cornelissen M, . Association between CCR5 genotype and the clinical course of HIV-1 Infection. Ann Intern Med. 1997 November 15, 1997;127(10):882–90. PMID: 9382366.9382366
36 Ioannidis JP, Rosenberg PS, Goedert JJ, . Effects of CCR5-Delta32, CCR2-64I, and SDF-1 3’A alleles on HIV-1 disease progression: an international meta-analysis of individual-patient data. Ann Intern Med. 2001 Nov 2001;135(9):782–95. PMID: 11694103.11694103
37 Lathey JL, Tierney C, Chang SY, . Associations of CCR5, CCR2, and stromal cell-derived factor 1 genotypes with human immunodeficiency virus disease progression in patients receiving nucleoside therapy. J Infect Dis. 2001 Dec 2001;184(11):1402–11. doi: 10.1086/324427. PMID: 11709782.11709782
38 Marmor M, Sheppard HW, Donnell D, . Homozygous and heterozygous CCR5-Delta32 genotypes are associated with resistance to HIV infection. J Acquir Immune Defic Syndr. 2001 Aug 2001;27(5):472–81. PMID: 11511825.11511825
39 Nolan D, Gaudieri S, John M, . Impact of host genetics on HIV disease progression and treatment: new conflicts on an ancient battleground. AIDS. 2004 Jun 2004;18(9):1231–40. PMID: 15362655.15362655
40 Baggaley RF, Boily MC, White RG, . Risk of HIV-1 transmission for parenteral exposure and blood transfusion: a systematic review and meta-analysis. AIDS. 2006 Apr 2006;20(6):805–12. doi: 10.1097/01.aids.0000218543.46963.6d. PMID: 16549963.16549963
41 Moore R. Epidemiology of HIV infection in the United States: implications for linkage to care. Clin Infect Dis. 2011;52:(Suppl 2):S208–S13. doi: 10.1093/cid/ciq044. PMID: 21342909.21342909
42 Baral SD, Poteat T, Stromdahl S, . Worldwide burden of HIV in transgender women: a systematic review and meta-analysis. Lancet Infect Dis. 2013 Mar;13(3):214–22. doi: 10.1016/s1473-3099(12)70315-8. PMID: 23260128.23260128
43 Chou R, Huffman LH, Fu R, . Screening for HIV: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2005 Jul 2005;143(1):55–73. PMID: 15998755.15998755
44 Moyer VA, U. S. Preventive Services Task Force. Screening for HIV: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013 Jul 2013;159(1):51–60. PMID: 23698354.23698354
45 Cohen MS, Chen YQ, McCauley M, . Prevention of HIV-1 infection with early antiretroviral therapy. N Engl J Med. 2011 Aug 2011;365(6):493–505. doi: 10.1056/NEJMoa1105243. PMID: 21767103.21767103
46 Wilton J, Senn H, Sharma M, . Pre-exposure prophylaxis for sexually-acquired HIV risk management: a review. HIV AIDS (Auckl). 2015;7:125–36. doi: 10.2147/HIV.S50025. PMID: 25987851.25987851
47 Centers for Disease Control and Prevention. Updated Guidelines for Antiretroviral Postexposure Prophylaxis After Sexual, Injection Drug Use, or Other Nonoccupational Exposure to HIV- United States, 2016 U.S. Department of Health and Human Services. 2016. https://www.cdc.gov/hiv/pdf/programresources/cdc-hiv-npep-guidelines.pdf Accessed November 28, 2017.
48 Krakower DS, Mayer KH. Pre-exposure prophylaxis to prevent HIV infection: current status, future opportunities and challenges. Drugs. 2015 Feb;75(3):243–51. doi: 10.1007/s40265-015-0355-4. PMID: 25673022.25673022
49 FDA Approves First Drug For Reducing the Risk of Sexually Acquired HIV Infection. FDA News Release. Silver Spring, MD: U.S. Food and Drug Administration; 2012. https://wayback.archive-it.org/7993/20170112032741/http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm312210.htm. Accessed December 8, 2017.
50 Department of Health and Human Services. Supplement Approval. 2018. https://www.accessdata.fda.gov/drugsatfda_docs/appletter/2018/021752Orig1s055ltr.pdf Accessed August 3, 2018.
51 Amico KR, Stirratt MJ. Adherence to preexposure prophylaxis: current, emerging, and anticipated bases of evidence. Clin Infect Dis. 2014 Jul;59: Suppl 1:S55–60. doi: 10.1093/cid/ciu266. PMID: 24926036.24926036
52 Molina JM, Capitant C, Spire B, . On-demand preexposure prophylaxis in men at high risk for HIV-1 Infection. N Engl J Med. 2015 Dec 2015;373(23):2237–46. doi: 10.1056/NEJMoa1506273. PMID: 26624850.26624850
53 Mutua G, Sanders E, Mugo P, . Safety and adherence to intermittent pre-exposure prophylaxis (PrEP) for HIV-1 in African men who have sex with men and female sex workers. PLoS One. 2012;7(4):e33103. doi: 10.1371/journal.pone.0033103. PMID: 22511916.22511916
54 Kibengo FM, Ruzagira E, Katende D, . Safety, adherence and acceptability of intermittent tenofovir/emtricitabine as HIV pre-exposure prophylaxis (PrEP) among HIV-uninfected Ugandan volunteers living in HIV-serodiscordant relationships: a randomized, clinical trial. PLoS One. 2013;8(9):e74314. doi: 10.1371/journal.pone.0074314. PMID: 24086333.24086333
55 Jackson A, McGowan I. Long-acting rilpivirine for HIV prevention. Curr Opin HIV AIDS. 2015 Jul;10(4):253–7. doi: 10.1097/COH.0000000000000160. PMID: 26049950.26049950
56 Baum MM, Butkyavichene I, Churchman SA, . An intravaginal ring for the sustained delivery of tenofovir disoproxil fumarate. Int J Pharm. 2015 Nov 2015;495(1):579–87. doi: 10.1016/j.ijpharm.2015.09.028. PMID: 26386138.26386138
57 Hankins C, Macklin R, Warren M. Translating PrEP effectiveness into public health impact: key considerations for decision-makers on cost-effectiveness, price, regulatory issues, distributive justice and advocacy for access. J Int AIDS Soc. 2015;18(4 Suppl 3):19973. doi: 10.7448/IAS.18.4.19973. PMID: 26198343.26198343
58 Caceres CF, Koechlin F, Goicochea P, . The promises and challenges of pre-exposure prophylaxis as part of the emerging paradigm of combination HIV prevention. J Int AIDS Soc. 2015;18(4 Suppl 3):19949. doi: 10.7448/IAS.18.4.19949. PMID: 26198341.26198341
59 Falutz J. Editorial commentary: unmasking the bare bones of HIV preexposure prophylaxis. Clin Infect Dis. 2015 Aug 2015;61(4):581–3. doi: 10.1093/cid/civ329. PMID: 25908681.25908681
60 U. S. Public Health Service, Centers for Disease Control and Prevention. Preexposure Prophylaxis for the Prevention of HIV infection in the United States—2014: a Clinical Practice Guideline. 2014. https://www.cdc.gov/hiv/pdf/guidelines/PrEPguidelines2014.pdf. Accessed December 8, 2017.
61 World Health Organization. Guidance on oral pre-exposure prophylaxis (PrEP) for serodiscordant couples, men and transgender women who have sex with men at high risk of HIV. Recommendations for use in the context of demonstration projects. Geneva: WHO; 2012. http://www.who.int/hiv/pub/guidance_prep/en/. Accessed December 11, 2017.
62 World Health Organization. WHO implementation tool for pre-exposure prophylaxis (PrEP) of HIV infection. 2017. http://www.who.int/hiv/pub/prep/prep-implementation-tool-policy/en/. Accessed 12.11.18.
63 Weinstein M, Yang OO, Cohen AC. Were we prepared for PrEP? Five years of implementation. AIDS. 2017;31(16):2303–5. doi: 10.1097/QAD.0000000000001626. PMID: 28857829.28857829
64 Smith DK, Van Handel M, Wolitski RJ, . Vital signs: Estimated percentages and numbers of adults with indications for preexposure prophylaxis to prevent HIV acquisition - United States, 2015. MMWR Morb Mortal Wkly Rep. 2015;64(46):1291–5. doi: 10.15585/mmwr.mm6446a4. PMID: 26606148.26606148
65 Krakower DS, Mayer KH. The role of healthcare providers in the roll out of preexposure prophylaxis. Curr Opin HIV AIDS. 2016 Jan;11(1):41–8. doi: 10.1097/COH.0000000000000206. PMID: 26417953.26417953
66 Petroll AE, Walsh JL, Owczarzak JL, . PrEP awareness, familiarity, comfort, and prescribing experience among US primary care providers and HIV specialists. AIDS Behav. 2017 May 2017;21(5):1256–67. doi: 10.1007/s10461-016-1625-1. PMID: 27885552.27885552
67 Blackstock OJ, Moore BA, Berkenblit GV, . A cross-sectional online survey of HIV pre-exposure prophylaxis adoption among primary care physicians. J Gen Intern Med. 2017 Jan;32(1):62–70. doi: 10.1007/s11606-016-3903-z. PMID: 27778215.27778215
68 Walsh JL, Petroll AE. Factors related to pre-exposure prophylaxis prescription by U.S. primary care physicians. Am J Prev Med. 2017 2017/06/01/;52(6):e165–e72. doi: 10.1016/j.amepre.2017.01.025. PMID: 28363410.28363410
69 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed December 8, 2017.
70 Baeten JM, Donnell D, Ndase P, . Antiretroviral prophylaxis for HIV-1 prevention in heterosexual men and women. N Engl J Med. 2012 Aug 2012;367(5):399–410. doi: 10.1056/NEJMoa1108524. PMID: 22784037.22784037
71 Gulick R, Wilkin TJ, Chen Y, . HPTN 069/ACTG 5305: Phase II study of maraviroc-based regimens for HIV PrEP in MSM [Abstract]. Conference on Retroviruses and Opportunistic Infections (CROI); February 22-25, 2016; Boston, MA.
72 Kiser PF, Johnson TJ, Clark JT. State of the art in intravaginal ring technology for topical prophylaxis of HIV infection. AIDS Rev. 2012 Jan–Mar;14(1):62–77. PMID: 22297505.22297505
73 Baeten JM, Palanee-Phillips T, Brown ER, . Use of a vaginal ring containing dapivirine for HIV-1 prevention in women. N Engl J Med. 2016 Dec;375(22):2121–32. doi: 10.1056/NEJMoa1506110. PMID: 26900902.26900902
74 Nel A, van Niekerk N, Kapiga S, . Safety and efficacy of a dapivirine vaginal ring for HIV prevention in women. N Engl J Med. 2013;375:2133–43. PMID: 27959766.27959766
75 Abdool Karim Q, Abdool Karim SS, Frohlich JA, . Effectiveness and safety of tenofovir gel, an antiretroviral microbicide, for the prevention of HIV infection in women. Science. 2010 Sep 2010;329(5996):1168–74. doi: 10.1126/science.1193748. PMID: 20643915.20643915
76 Marrazzo JM, Ramjee G, Richardson BA, . Tenofovir-based preexposure prophylaxis for HIV infection among African women. N Engl J Med. 2015 Feb 2015;372(6):509–18. doi: 10.1056/NEJMoa1402269. PMID: 25651245.25651245
77 Rees H, Delany-Moretlwe S, Lombard C, . FACTS 001 phase III trial of pericoital tenofovir 1% gel for HIV prevention in women. Presented at the Conference on Retroviruses and Opportunistic Infections (CROI), Seattle, February 23–26, 2015.
78 McCormack S, Dunn DT, Desai M, . Pre-exposure prophylaxis to prevent the acquisition of HIV-1 infection (PROUD): effectiveness results from the pilot phase of a pragmatic open-label randomised trial. Lancet. 2016 Jan 2016;387(10013):53–60. doi: 10.1016/S0140-6736(15)00056-2. PMID: 26364263.26364263
79 Abdool Karim SS, Abdool Karim Q, Kharsany AB, . Tenofovir gel for the prevention of herpes simplex virus type 2 infection. N Engl J Med. 2015 Aug 2015;373(6):530–9. doi: 10.1056/NEJMoa1410649. PMID: 26244306.26244306
80 Celum C, Morrow RA, Donnell D, . Daily oral tenofovir and emtricitabine-tenofovir preexposure prophylaxis reduces herpes simplex virus type 2 acquisition among heterosexual HIV-1-uninfected men and women: a subgroup analysis of a randomized trial. Ann Intern Med. 2014 Jul 2014;161(1):11–9. doi: 10.7326/M13-2471. PMID: 24979446.24979446
81 Liu AY, Cohen SE, Vittinghoff E, . Preexposure prophylaxis for HIV infection integrated with municipal- and community-based sexual health services. JAMA Intern Med. 2016 Jan;176(1):75–84. doi: 10.1001/jamainternmed.2015.4683. PMID: 26571482.26571482
82 Hurt CB, Eron JJ, Jr., Cohen MS. Pre-exposure prophylaxis and antiretroviral resistance: HIV prevention at a cost? Clin Infect Dis. 2011 Dec;53(12):1265–70. doi: 10.1093/cid/cir684. PMID: 21976467.21976467
83 Chou R, Aronson N, Atkins D, . AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. 2010 May;63(5):502–12. doi: 10.1016/j.jclinepi.2008.06.007. PMID: 18823754.18823754
84 Chou R, Helfand M. Challenges in systematic reviews that assess treatment harms. Ann Intern Med. 2005 Jun 2005;142(12 Pt 2):1090–9. PMID: 15968034.15968034
85 Grohskopf LA, Chillag KL, Gvetadze R, . Randomized trial of clinical safety of daily oral tenofovir disoproxil fumarate among HIV-uninfected men who have sex with men in the United States. J Acquir Immune Defic Syndr. 2013 Sep 2013;64(1):79–86. doi: 10.1097/QAI.0b013e31828ece33. PMID: 23466649.23466649
86 Sun X, Briel M, Walter SD, . Is a subgroup effect believable? Updating criteria to evaluate the credibility of subgroup analyses. BMJ. 2010;340 doi: 10.1136/bmj.c117. PMID: 20354011.20354011
87 Higgins JP, Thompson SG, Deeks JJ, . Measuring inconsistency in meta-analyses. BMJ. 2003 Sep 2003;327(7414):557–60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
88 Cornell JE, Mulrow CD, Localio R, . Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. 2014 Feb 2014;160(4):267–70. doi: 10.7326/M13-2886. PMID: 24727843.24727843
89 Center for Drug Evaluation and Research. Clinical Review. 2011. https://www.accessdata.fda.gov/drugsatfda_docs/nda/2012/021752Orig1s030MedR.pdf. Accessed February 2, 2018.
90 Fonner VA, Dalglish SL, Kennedy CE, . Effectiveness and safety of oral HIV preexposure prophylaxis for all populations. AIDS. 2016 Jul 2016;30(12):1973–83. doi: 10.1097/QAD.0000000000001145. PMID: 27149090.27149090
91 Sterne JA, Sutton AJ, Ioannidis JP, . Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011 Jul 2011;343:d4002. doi: 10.1136/bmj.d4002. PMID: 21784880.21784880
92 Hosek SG, Landovitz RJ, Kapogiannis B, . Safety and feasibility of antiretroviral preexposure prophylaxis for adolescent men who have sex with men aged 15 to 17 years in the United States. JAMA Pediatr. 2017 Sep 05 doi: 10.1001/jamapediatrics.2017.2007. PMID: 28873128.28873128
93 Hosek SG, Rudy B, Landovitz R, . An HIV preexposure prophylaxis demonstration project and safety study for young MSM. J Acquir Immune Defic Syndr. 2017 Jan 2017;74(1):21–9. doi: 10.1097/qai.0000000000001179. PMID: 27632233.27632233
94 Hosek SG, Siberry G, Bell M, . The acceptability and feasibility of an HIV preexposure prophylaxis (PrEP) trial with young men who have sex with men. J Acquir Immune Defic Syndr. 2013 Apr 2013;62(4):447–56. doi: 10.1097/QAI.0b013e3182801081. PMID: 24135734.24135734
95 Agot K, Taylor D, Corneli AL, . Accuracy of self-report and pill-count measures of adherence in the FEM-PrEP clinical trial: implications for future HIV-prevention trials. AIDS Behav. 2015 May;19(5):743–51. doi: 10.1007/s10461-014-0859-z. PMID: 25100053.25100053
96 Chirwa LI, Johnson JA, Niska RW, . CD4(+) cell count, viral load, and drug resistance patterns among heterosexual breakthrough HIV infections in a study of oral preexposure prophylaxis. AIDS. 2014 Jan 2014;28(2):223–6. doi: 10.1097/QAD.0000000000000102. PMID: 24361682.24361682
97 Choopanya K, Martin M, Suntharasamai P, . Antiretroviral prophylaxis for HIV infection in injecting drug users in Bangkok, Thailand (the Bangkok tenofovir study): a randomised, double-blind, placebo-controlled phase 3 trial. Lancet. 2013 Jun 2013;381(9883):2083–90. doi: 10.1016/S0140-6736(13)61127-7. PMID: 23769234.23769234
98 Deutsch MB, Glidden DV, Sevelius J, . HIV pre-exposure prophylaxis in transgender women: a subgroup analysis of the iPrEx trial. Lancet HIV. 2015 Dec;2(12):e512–9. doi: 10.1016/S2352-3018(15)00206–4. PMID: 26614965.26614965
99 Donnell D, Baeten JM, Bumpus NN, . HIV protective efficacy and correlates of tenofovir blood concentrations in a clinical trial of PrEP for HIV prevention. J Acquir Immune Defic Syndr. 2014 Jul 2014;66(3):340–8. doi: 10.1097/QAI.0000000000000172. PMID: 24784763.24784763
100 Grant RM, Lama JR, Anderson PL, . Preexposure chemoprophylaxis for HIV prevention in men who have sex with men. N Engl J Med. 2010 Dec 2010;363(27):2587–99. doi: 10.1056/NEJMoa1011205. PMID: 21091279.21091279
101 Haberer JE, Baeten JM, Campbell J, . Adherence to antiretroviral prophylaxis for HIV prevention: a substudy cohort within a clinical trial of serodiscordant couples in East Africa. PLoS Med. 2013;10(9):e1001511. doi: 10.1371/journal.pmed.1001511. PMID: 24058300.24058300
102 Heffron R, Mugo N, Were E, . Preexposure prophylaxis is efficacious for HIV-1 prevention among women using depot medroxyprogesterone acetate for contraception. AIDS. 2014 Nov 2014;28(18):2771–6. doi: 10.1097/QAD.0000000000000493. PMID: 25493602.25493602
103 Lehman DA, Baeten JM, McCoy CO, . Risk of drug resistance among persons acquiring HIV within a randomized clinical trial of single- or dual-agent preexposure prophylaxis. J Infect Dis. 2015 Apr 2015;211(8):1211–8. doi: 10.1093/infdis/jiu677. PMID: 25587020.25587020
104 Liu AY, Vittinghoff E, Sellmeyer DE, . Bone mineral density in HIV-negative men participating in a tenofovir pre-exposure prophylaxis randomized clinical trial in San Francisco. PLoS One. 2011;6(8):e23688. doi: 10.1371/journal.pone.0023688. PMID: 21897852.21897852
105 Liu A, Glidden DV, Anderson PL, . Patterns and correlates of PrEP drug detection among MSM and transgender women in the Global iPrEx Study. J Acquir Immune Defic Syndr. 2014 Dec 2014;67(5):528–37. doi: 10.1097/QAI.0000000000000351. PMID: 25230290.25230290
106 Mandala J, Nanda K, Wang M, . Liver and renal safety of tenofovir disoproxil fumarate in combination with emtricitabine among African women in a pre-exposure prophylaxis trial. BMC Pharmacol Toxicol. 2014;15:77. doi: 10.1186/2050-6511-15-77. PMID: 25539648.25539648
107 Marcus JL, Glidden DV, McMahan V, . Daily oral emtricitabine/tenofovir preexposure prophylaxis and herpes simplex virus type 2 among men who have sex with men. PLoS One. 2014;9(3):e91513. doi: 10.1371/journal.pone.0091513. PMID: 24637511.24637511
108 Martin M, Vanichseni S, Suntharasamai P, . Renal function of participants in the Bangkok tenofovir study--Thailand, 2005-2012. Clin Infect Dis. 2014 Sep 2014;59(5):716–24. doi: 10.1093/cid/ciu355. PMID: 24829212.24829212
109 Martin M, Vanichseni S, Suntharasamai P, . The impact of adherence to preexposure prophylaxis on the risk of HIV infection among people who inject drugs. AIDS. 2015 Apr 2015;29(7):819–24. doi: 10.1097/QAD.0000000000000613. PMID: 25985403.25985403
110 Matthews LT, Heffron R, Mugo NR, . High medication adherence during periconception periods among HIV-1-uninfected women participating in a clinical trial of antiretroviral pre-exposure prophylaxis. J Acquir Immune Defic Syndr. 2014 Sep 2014;67(1):91–7. doi: 10.1097/QAI.0000000000000246. PMID: 25118795.25118795
111 Mirembe BG, Kelly CW, Mgodi N, . Bone mineral density changes among young, healthy African women receiving oral tenofovir for HIV preexposure prophylaxis. J Acquir Immune Defic Syndr. 2016 Mar 2016;71(3):287–94. doi: 10.1097/QAI.0000000000000858. PMID: 26866954.26866954
112 Mugo NR, Hong T, Celum C, . Pregnancy incidence and outcomes among women receiving preexposure prophylaxis for HIV prevention: a randomized clinical trial. JAMA. 2014 Jul 23–30;312(4):362–71. doi: 10.1001/jama.2014.8735. PMID: 25038355.25038355
113 Mugwanya KK, Wyatt C, Celum C, . Changes in glomerular kidney function among HIV-1-uninfected men and women receiving emtricitabine-tenofovir disoproxil fumarate preexposure prophylaxis: a randomized clinical trial. JAMA Intern Med. 2015 Feb;175(2):246–54. doi: 10.1001/jamainternmed.2014.6786. PMID: 25531343.25531343
114 Mulligan K, Glidden DV, Anderson PL, . Effects of emtricitabine/tenofovir on bone mineral density in HIV-negative persons in a randomized, double-blind, placebo-controlled trial. Clin Infect Dis. 2015 Aug 2015;61(4):572–80. doi: 10.1093/cid/civ324. PMID: 25908682.25908682
115 Murnane PM, Celum C, Mugo N, . Efficacy of preexposure prophylaxis for HIV-1 prevention among high-risk heterosexuals: subgroup analyses from a randomized trial. AIDS. 2013 Aug 2013;27(13):2155–60. doi: 10.1097/QAD.0b013e3283629037. PMID: 24384592.24384592
116 Murnane PM, Brown ER, Donnell D, . Estimating efficacy in a randomized trial with product nonadherence: application of multiple methods to a trial of preexposure prophylaxis for HIV prevention. Am J Epidemiol. 2015 Nov 2015;182(10):848–56. doi: 10.1093/aje/kwv202. PMID: 26487343.26487343
117 Peterson L, Taylor D, Roddy R, . Tenofovir disoproxil fumarate for prevention of HIV infection in women: a phase 2, double-blind, randomized, placebo-controlled trial. PLoS Clin Trials. 2007;2(5):e27. doi: 10.1371/journal.pctr.0020027. PMID: 17525796.17525796
118 Solomon MM, Lama JR, Glidden DV, . Changes in renal function associated with oral emtricitabine/tenofovir disoproxil fumarate use for HIV pre-exposure prophylaxis. AIDS. 2014 Mar 2014;28(6):851–9. doi: 10.1097/QAD.0000000000000156. PMID: 24499951.24499951
119 Thigpen MC, Kebaabetswe PM, Paxton LA, . Antiretroviral preexposure prophylaxis for heterosexual HIV transmission in Botswana. N Engl J Med. 2012 Aug 2012;367(5):423–34. doi: 10.1056/NEJMoa1110711. PMID: 22784038.22784038
120 Van Damme L, Corneli A, Ahmed K, . Preexposure prophylaxis for HIV infection among African women. N Engl J Med. 2012 Aug 2012;367(5):411–22. doi: 10.1056/NEJMoa1202614. PMID: 22784040.22784040
121 Were EO, Heffron R, Mugo NR, . Pre-exposure prophylaxis does not affect the fertility of HIV-1-uninfected men. AIDS. 2014 Aug 2014;28(13):1977–82. doi: 10.1097/QAD.0000000000000313. PMID: 25259704.25259704
122 Bekker LG, Roux S, Sebastien E, . Daily and non-daily pre-exposure prophylaxis in African women (HPTN 067/ADAPT Cape Town trial): a randomised, open-label, phase 2 trial. Lancet HIV. 2018 02;5(2):e68–e78. doi: 10.1016/S2352-3018(17)30156-X. PMID: 28986029.28986029
123 Grant RM, Mannheimer S, Hughes JP, . Daily and nondaily oral preexposure prophylaxis in men and transgender women who have sex with men: The Human Immunodeficiency Virus Prevention Trials Network 067/ADAPT study. Clin Infect Dis. 2018 May 2018;66(11):1712–21. doi: 10.1093/cid/cix1086. PMID: 29420695.29420695
124 Chan PA, Mena L, Patel R, . Retention in care outcomes for HIV pre-exposure prophylaxis implementation programmes among men who have sex with men in three US cities. J Int AIDS Soc. 2016;19(1):20903. doi: 10.7448/IAS.19.1.20903. PMID: 27302837.27302837
125 Grant RM, Anderson PL, McMahan V, . Uptake of pre-exposure prophylaxis, sexual practices, and HIV incidence in men and transgender women who have sex with men: a cohort study. Lancet Infect Dis. 2014 Sep;14(9):820–9. doi: 10.1016/S1473-3099(14)70847-3. PMID: 25065857.25065857
126 Landovitz RJ, Beymer M, Kofron R, . Plasma tenofovir levels to support adherence to TDF/FTC preexposure prophylaxis for HIV prevention in MSM in Los Angeles, California. J Acquir Immune Defic Syndr. 2017 Dec 2017;76(5):501–11. doi: 10.1097/QAI.0000000000001538. PMID: 28902074.28902074
127 Montgomery MC, Oldenburg CE, Nunn AS, . Adherence to pre-exposure prophylaxis for HIV prevention in a clinical setting. PLoS One. 2016;11(6):e0157742. doi: 10.1371/journal.pone.0157742. PMID: 27333000.27333000
128 van Epps P, Maier M, Lund B, . Medication adherence in a nationwide cohort of veterans initiating pre-exposure prophylaxis (PrEP) to prevent HIV infection. J Acquir Immune Defic Syndr. 2018 Mar 2018;77(3):272–8. doi: 10.1097/QAI.0000000000001598. PMID: 29210835.29210835
129 Beymer MR, Weiss RE, Sugar CA, . Are Centers for Disease Control and Prevention guidelines for preexposure prophylaxis specific enough? Formulation of a personalized HIV risk score for pre-exposure prophylaxis initiation. Sex Transm Dis. 2017 Jan;44(1):48–56. doi: 10.1097/olq.0000000000000535. PMID: 27898570.27898570
130 Hoenigl M, Weibel N, Mehta SR, . Development and validation of the San Diego early test score to predict acute and early HIV infection risk in men who have sex with men. Clin Infect Dis. 2015 Aug 2015;61(3):468–75. doi: 10.1093/cid/civ335. PMID: 25904374.25904374
131 Menza TW, Hughes JP, Celum CL, . Prediction of HIV acquisition among men who have sex with men. Sex Transm Dis. 2009 Sep;36(9):547–55. doi: 10.1097/OLQ.0b013e3181a9cc41. PMID: 19707108.19707108
132 Smith DK, Pals SL, Herbst JH, . Development of a clinical screening index predictive of incident HIV infection among men who have sex with men in the United States. J Acquir Immune Defic Syndr. 2012 Aug 2012;60(4):421–7. doi: 10.1097/QAI.0b013e318256b2f6. PMID: 22487585.22487585
133 Smith DK, Pan Y, Rose CE, . A brief screening tool to assess the risk of contracting HIV infection among active injection drug users. J Addict Med. 2015 May–Jun;9(3):226–32. doi: 10.1097/ADM.0000000000000123. PMID: 25961495.25961495
134 Lancki N, Almirol E, Alon L, . Preexposure prophylaxis guidelines have low sensitivity for identifying seroconverters in a sample of young Black MSM in Chicago. AIDS. 2018 Jan 2018;32(3):383–92. doi: 10.1097/qad.0000000000001710. PMID: 29194116.29194116
135 Jones J, Hoenigl M, Siegler AJ, . Assessing the performance of 3 human immunodeficiency virus incidence risk scores in a cohort of black and white men who have sex with men in the South. Sex Transm Dis. 2017 May;44(5):297–302. doi: 10.1097/OLQ.0000000000000596. PMID: 28407646.28407646
136 Pintye J, Drake AL, Kinuthia J, . A risk assessment tool for identifying pregnant and postpartum women who may benefit from preexposure prophylaxis. Clin Infect Dis. 2017 Mar 2017;64(6):751–8. doi: 10.1093/cid/ciw850. PMID: 28034882.28034882
137 Kahle EM, Hughes JP, Lingappa JR, . An empiric risk scoring tool for identifying high-risk heterosexual HIV-1-serodiscordant couples for targeted HIV-1 prevention. J Acquir Immune Defic Syndr. 2013 Mar 2013;62(3):339–47. doi: 10.1097/QAI.0b013e31827e622d. PMID: 23187945.23187945
138 Balkus JE, Brown E, Palanee T, . An empiric HIV risk scoring tool to predict HIV-1 acquisition in African women. J Acquir Immune Defic Syndr. 2016 Jul 2016;72(3):333–43. doi: 10.1097/QAI.0000000000000974. PMID: 26918545.26918545
139 Castillo-Mancilla JR, Searls K, Caraway P, . Short communication: Tenofovir diphosphate in dried blood spots as an objective measure of adherence in HIV-infected women. AIDS Res Hum Retroviruses. 2015 Apr;31(4):428–32. doi: 10.1089/aid.2014.0229. PMID: 25328112.25328112
140 Castillo-Mancilla JR, Zheng JH, Rower JE, . Tenofovir, emtricitabine, and tenofovir diphosphate in dried blood spots for determining recent and cumulative drug exposure. AIDS Res Hum Retroviruses. 2013 Feb;29(2):384–90. doi: 10.1089/aid.2012.0089. PMID: 22935078.22935078
141 Anderson PL, Glidden DV, Liu A, . Emtricitabine-tenofovir concentrations and pre-exposure prophylaxis efficacy in men who have sex with men. Sci Transl Med. 2012 Sep 2012;4(151):1–8. PMID: 22972843.22972843
142 Glidden DV, Amico KR, Liu AY, . Symptoms, side effects and adherence in the iPrEx open-label extension. Clin Infect Dis. 2016 May 2016;62(9):1172–7. doi: 10.1093/cid/ciw022. PMID: 26797207.26797207
143 Kebaabetswe PM, Stirratt MJ, McLellan-Lemal E, . Factors associated with adherence and concordance between measurement strategies in an HIV daily oral tenofovir/emtricitibine as pre-exposure prophylaxis (Prep) clinical trial, Botswana, 2007-2010. AIDS Behav. 2015 May;19(5):758–69. doi: 10.1007/s10461-014-0891-z. PMID: 25186785.25186785
144 Koss CA, Hosek SG, Bacchetti P, . Comparison of measures of adherence to human immunodeficiency virus preexposure prophylaxis among adolescent and young men who have sex with men in the United States. Clin Infect Dis. 2018;66(2):213–9. PMID: 29020194.29020194
145 Corneli AL, McKenna K, Perry B, . The science of being a study participant: FEM-PrEP participants’ explanations for overreporting adherence to the study pills and for the whereabouts of unused pills. J Acquir Immune Defic Syndr. 2015 Apr 2015;68(5):578–84. doi: 10.1097/QAI.0000000000000525. PMID: 25761233.25761233
146 Cohen SE, Vittinghoff E, Bacon O, . High interest in preexposure prophylaxis among men who have sex with men at risk for HIV infection: baseline data from the US PrEP demonstration project. J Acquir Immune Defic Syndr. 2015 Apr 2015;68(4):439–48. doi: 10.1097/QAI.0000000000000479. PMID: 25501614.25501614
147 Kasonde M, Niska RW, Rose C, . Bone mineral density changes among HIV-uninfected young adults in a randomised trial of pre-exposure prophylaxis with tenofovir-emtricitabine or placebo in Botswana. PLoS ONE. 2014;9(3):e90111. doi: 10.1371/journal.pone.0090111. PMID: 24625530.24625530
148 Martin M, Vanichseni S, Suntharasamai P, . Factors associated with the uptake of and adherence to HIV pre-exposure prophylaxis in people who have injected drugs: an observational, open-label extension of the Bangkok Tenofovir Study. Lancet HIV. 2017 Feb;4(2):e59–e66. doi: 10.1016/s2352-3018(16)30207-7. PMID: 27866873.27866873
149 Roberts ST, Haberer J, Celum C, . Intimate partner violence and adherence to HIV pre-exposure prophylaxis (PrEP) in African women in HIV serodiscordant relationships: A prospective cohort study. J Acquir Immune Defic Syndr. 2016 Nov 2016;73(3):313–22. doi: 10.1097/qai.0000000000001093. PMID: 27243900.27243900
150 Weis JF, Baeten JM, McCoy CO, . Preexposure prophylaxis-selected drug resistance decays rapidly after drug cessation. AIDS. 2016 Jan 2016;30(1):31–5. doi: 10.1097/QAD.0000000000000915. PMID: 26731753.26731753
151 Antoni G. On-demand PrEP with TDF/FTC remains highly effective among MSM with infrequent sexual intercourse: a sub-study of the ANRS IPERGAY trial. 2017. http://programme.ias2017.org/Abstract/Abstract/3629. Accessed January 3, 2018.
152 Cottrell ML, Yang KH, Prince HM, . A translational pharmacology approach to predicting outcomes of preexposure prophylaxis against HIV in men and women using tenofovir disoproxil fumarate with or without emtricitabine. J Infect Dis. 2016 Jul 2016;214(1):55–64. doi: 10.1093/infdis/jiw077. PMID: 26917574.26917574
153 Massud I, Mitchell J, Babusis D, . Chemoprophylaxis with oral emtricitabine and tenofovir alafenamide combination protects macaques from rectal simian/human immunodeficiency virus infection. J Infect Dis. 2016 Oct 2016;214(7):1058–62. doi: 10.1093/infdis/jiw312. PMID: 27465645.27465645
154 Koester K, Amico RK, Gilmore H, . Risk, safety and sex among male PrEP users: time for a new understanding. Cult Health Sex. 2017 Dec;19(12):1301–13. doi: 10.1080/13691058.2017.1310927. PMID: 28415911.28415911
155 Tang MW, Shafer RW. HIV-1 antiretroviral resistance: scientific principles and clinical applications. Drugs. 2012 September 2012;72(9):e1–e25. doi: 10.2165/11633630-000000000-00000. PMID: 22686620.22686620
156 Traeger MW, Schroeder SE, Wright EJ, . Effects of pre-exposure prophylaxis for the prevention of HIV infection on sexual risk behavior in men who have sex with men: a systematic review and meta-analysis. Clin Infect Dis. 2018 Mar 2 doi: 10.1093/cid/ciy182. PMID: 29509889.29509889
157 Volk JE, Marcus JL, Phengrasamy T, . Incident hepatitis C virus infections among users of HIV preexposure prophylaxis in a clinical practice setting. Clin Infect Dis. 2015 Jun 2015;60(11):1728–9. doi: 10.1093/cid/civ129. PMID: 25694649.25694649
158 Okwundu CI, Uthman OA, Okoromah CA. Antiretroviral pre-exposure prophylaxis (PrEP) for preventing HIV in high-risk individuals. Cochrane Database Syst Rev. 2012;7:CD007189. doi: 10.1002/14651858.CD007189.pub3. PMID: 22786505.22786505
159 Jiang J, Yang X, Ye L, . Pre-exposure prophylaxis for the prevention of HIV infection in high risk populations: a meta-analysis of randomized controlled trials. PLoS ONE. 2014;9(2):e87674. doi: 10.1371/journal.pone.0087674. PMID: 24498350.24498350
160 Hendrix CW. Exploring concentration response in HIV pre-exposure prophylaxis to optimize clinical care and trial design. Cell. 2013 Oct 2013;155(3):515–8. doi: 10.1016/j.cell.2013.09.030. PMID: 24243011.24243011
161 Yacoub R, Nadkarni GN, Weikum D, . Elevations in serum creatinine with tenofovir-based HIV pre-exposure prophylaxis: A meta-analysis of randomized placebo-controlled trials. J Acquir Immune Defic Syndr. 2016 Apr 2016;71(4):e115–8. doi: 10.1097/QAI.0000000000000906. PMID: 26627105.26627105
162 Wang L, Kourtis AP, Ellington S, . Safety of tenofovir during pregnancy for the mother and fetus: a systematic review. Clin Infect Dis. 2013;57(12):1773–81. doi: 10.1093/cid/cit601. PMID: 24046310.24046310
163 Fowler MG, Qin M, Fiscus SA, . Benefits and risks of antiretroviral therapy for perinatal HIV prevention. N Engl J Med. 2016 Nov 2016;375(18):1726–37. doi: 10.1056/NEJMoa1511691. PMID: 27806243.27806243
164 Glenn-Fowler M. Comments on the PROMISE data interpretation in Siemieniuk meta-analysis from PROMISE team. BMJ Open. 2017 September 19, 2017.
165 Morrison A, Polisena J, Husereau D, . The effect of English-language restriction on systematic review-based meta-analyses: a systematic review of empirical studies. Int J Technol Assess Health Care. 2012 Apr;28(2):138–44. doi: 10.1017/s0266462312000086. PMID: 22559755.22559755
166 Pham B, Klassen TP, Lawson ML, . Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. 2005 Aug;58(8):769–76. PMID: 16086467.16086467
167 Ray AS, Fordyce MW, Hitchcock MJM. Tenofovir alafenamide: A novel prodrug of tenofovir for the treatment of Human Immunodeficiency Virus. Antiviral Res. 2016 2016/01/01/;125(Supplement C):63–70. doi: 10.1016/j.antiviral.2015.11.009. PMID: 26640223.26640223
168 Gilead Sciences. Safety and Efficacy of Emtricitabine and Tenofovir Alafenamide (F/TAF) Fixed-Dose Combination Once Daily for Pre-Exposure Prophylaxis in Men and Transgender Women Who Have Sex With Men and Are At Risk of HIV-1 Infection. 2016. https://clinicaltrials.gov/ct2/show/NCT02842086?term=NCT02842086&rank=1. Accessed December 8, 2017.
169 Schlesinger E, Johengen D, Luecke E, . A tunable, biodegradable, thin-film polymer device as a long-acting implant delivering tenofovir alafenamide fumarate for HIV pre-exposure prophylaxis. Pharm Res. 2016 Jul;33(7):1649–56. doi: 10.1007/s11095-016-1904-6. PMID: 26975357.26975357
170 Gulick RM, Wilkin TJ, Chen YQ, . Safety and tolerability of maraviroc-containing regimens to prevent HIV infection in women: A phase 2 randomized trial. Ann Intern Med. 2017;167(6):384–93. doi: 10.7326/M17-0520. PMID: 28828489.28828489
171 Gulick RM, Wilkin TJ, Chen YQ, . Phase 2 study of the safety and tolerability of maraviroc-containing regimens to prevent HIV Infection in men who have sex with men (HPTN 069/ACTG A5305). J Infect Dis. 2017 Jan 2017;215(2):238–46. doi: 10.1093/infdis/jiw525. PMID: 27811319.27811319
172 Landovitz RJ, Kofron R, McCauley M. The promise and pitfalls of long-acting injectable agents for HIV prevention. Curr Opin HIV AIDS. 2016 Jan;11(1):122–8. doi: 10.1097/COH.0000000000000219. PMID: 26633643.26633643
173 Bush S, Magnuson D, Rawlings MK, . Racial Characteristics of FTC/TDF for Pre-exposure Prophylaxis (PrEP) Users in the US #2651. Boston, MA: June 16–20 2016. https://www.aidshealth.org/wp-content/uploads/2016/07/GILD_Bush-PrEP-Race-Utilization.ext-June-2016.pdf Accessed November 28, 2017.
174 Wu H, Mendoza MC, Huang YA, . Uptake of HIV preexposure prophylaxis among commercially insured persons-United States, 2010-2014. Clin Infect Dis. 2017 Jan 2017;64(2):144–9. doi: 10.1093/cid/ciw701. PMID: 27986691.27986691
175 Parsons JT, Rendina HJ, Lassiter JM, . Uptake of HIV pre-exposure prophylaxis (PrEP) in a national cohort of gay and bisexual men in the United States: The motivational PrEP cascade. J Acquir Immune Defic Syndr. 2017:285–92. doi: 10.1097/QAI.0000000000001251. PMID: 28187084.28187084
176 Kuhns LM, Hotton AL, Schneider J, . Use of pre-exposure prophylaxis (PrEP) in young men who have sex with men is associated with race, sexual risk behavior and peer network size. AIDS Behav. 2017 May 2017;21(5):1376–82. doi: 10.1007/s10461-017-1739-0. PMID: 28238119.28238119
177 Rolle C-P, Rosenberg ES, Siegler AJ, . Challenges in translating PrEP interest into uptake in an observational study of young black MSM. J Acquir Immune Defic Syndr. 2017;76(3):250–8. doi: 10.1097/qai.0000000000001497. PMID: 28708811.28708811
178 Wilson EC, Jin H, Liu A, . Knowledge, indications and willingness to take pre-exposure prophylaxis among transwomen in San Francisco, 2013. PLoS ONE. 2015;10(6):e0128971. doi: 10.1371/journal.pone.0128971. PMID: 26039511.26039511
179 Desai M, Field N, Grant R, . Recent advances in pre-exposure prophylaxis for HIV. BMJ. 2017 Dec 2017;359:j5011. doi: 10.1136/bmj.j5011. PMID: 29229609.29229609
180 Johns Hopkins University. Finding the right tenofovir/emtricitabine regimen for pre-exposure prophylaxis (PrEP) in transgender women. clinicaltrials.gov; 2017. https://clinicaltrials.gov/ct2/show/study/NCT03060785?view=results. Accessed February 2, 2018.
181 Liu A. The stay study: a demonstration project advancing PrEP delivery in the San Francisco Bay Area Transgender Community. clinicaltrials.gov; 2017. https://clinicaltrials.gov/ct2/show/NCT03120936. Accessed February 2, 2018.
182 University of Nebraska. A Pharmacokinetic Evaluation of Tenofovir/Emtricitabine as HIV Pre-Exposure Prophylaxis in Transgender Women. clinicaltrials.gov; 2017. https://clinicaltrials.gov/ct2/show/NCT03270969. Accessed February 2, 2018.
183 Poteat T, Scheim A, Xavier J, . Global epidemiology of HIV infection and related syndemics affecting transgender people. JAIDS. 2016 07/18;72(Suppl 3):S210–S9. doi: 10.1097/QAI.0000000000001087. PMID: 27429185.27429185
184 Kuo I, Olsen H, Patrick R, . Willingness to use HIV pre-exposure prophylaxis among community-recruited, older people who inject drugs in Washington, DC. Drug Alcohol Depend. 2016 Jul 2016;164:8–13. doi: 10.1016/j.drugalcdep.2016.02.044. PMID: 27177804.27177804
185 Escudero DJ, Kerr T, Wood E, . Acceptability of HIV pre-exposure prophylaxis (PREP) among People Who Inject Drugs (PWID) in a Canadian setting. Aids Behav. 2015 May;19(5):752–7. doi: 10.1007/s10461-014-0867-z. PMID: 25086669.25086669
186 National Institute of Allergy and Infectious Diseases. Safety and efficacy study of injectable cabotegravir compared to daily oral tenofovir disoproxil fumarate/emtricitabine (TDF/FTC), for pre-exposure prophylaxis in HIV-uninfected cisgender men and transgender women who have sex with men. ClinicalTrials.gov; 2016. https://clinicaltrials.gov/ct2/show/NCT02720094. Accessed December 11, 2017.
187 National Institute of Allergy and Infectious Diseases. Evaluating the Safety and Efficacy of Long-Acting Injectable Cabotegravir Compared to Daily Oral TDF/FTC for Pre-Exposure Prophylaxis in HIV-Uninfected Women. clinicaltrials.gov; 2017. https://clinicaltrials.gov/ct2/show/NCT03164564. Accessed February 2, 2018.
188 PATH. Phase II Safety and Acceptability of an Investigational Injectable Product, TMC278LA, for Pre-Exposure Prophylaxis (TMC278LA). clinicaltrials.gov; 2017. https://clinicaltrials.gov/ct2/show/NCT02165202. Accessed December 8, 2017.
189 Columbia University. PrEPared and strong: Clinic-based PrEP for black MSM (P&S). ClinicalTrials.gov; 2016. https://clinicaltrials.gov/ct2/show/NCT02167386?term=NCT02167386&rank=1. Accessed December 8, 2017.
190 Hyman S. Sex Pro: A Personalized HIV Risk Assessment Tool for Men Who Have Sex With Men. 2015. http://www.croiconference.org/sessions/sex-pro-personalized-hiv-risk-assessment-tool-men-who-have-sex-men. Accessed February 2, 2018.