# Acknowledgments

The authors thank the AHRQ Medical Officer, Howard Tracer, MD, as well as the U.S. Preventive Services Task Force.