# Chapter 4 Discussion

## Summary of Review Findings

This report synthesizes evidence on effects of PrEP on risk of HIV infection, harms, and other clinical outcomes; effects of adherence on effectiveness; estimates of adherence in U.S. populations on PrEP; and the diagnostic accuracy of instruments for identifying potential candidates for PrEP. Table 10 summarizes the evidence reviewed for this report.

Table 10 Summary of Evidence

Key question | Number of studies (k); Number of participants^*^ (n); Study design | Summary of findings by outcome | Consistency/precision Reporting bias | Overall quality | Body of evidence limitations | Strength of evidence | Applicability
KQ1.; Benefits of PrEP vs. placebo or no PrEP | HIV infection: k=12 RCTs (n=18,244) | 11 trials; RR, 0.46 (95% CI, 0.33 to 0.66); I^2^=67%; ARR, −2.0% (95% CI, −2.8% to −1.2%) after 4 months to 4 years; Stratified by adherence (p=0.0002 for interaction) ≥70% adherence: 6 trials; RR, 0.27 (95% CI, 0.19 to 0.39); I^2^=0%; >40% to <70% adherence: 3 trials; RR, 0.51 (95% CI, 0.38 to 0.70); I^2^=0%; ≤40% adherence: 2 trials; RR, 0.93 (95% CI, 0.72 to 1.20); I^2^=0% | Some inconsistency explained by level of adherence; precise; Funnel plot asymmetry and Egger test statistically significant (p=0.03), but no unpublished studies identified | Good | Variability in duration of followup, although results consistent when trials stratified according to followup duration.; Three trials reported some industry support, but no difference between studies that only reported industry support and those that only reported governmental or nonprofit funding on estimates. | High | Studies of women and men at increased risk via heterosexual contact conducted in Africa; the only study of PWID was conducted in Asia; several studies of MSM were conducted in the U.S., Europe, and Canada.; PrEP was more effective in trials conducted in the U.S., Europe, and Canada (all of these trials reported high adherence and enrolled MSM).
KQ1.; Benefits of PrEP vs. placebo or no PrEP | Mortality: k=9 RCTs (n=17,756) | RR, 0.81 (95% CI, 0.59 to 1.11); I^2^=0% | Consistent; imprecise; No reporting bias detected | Good | See Body of Evidence Limitations for KQ1, HIV infection. | Moderate | See Applicability for KQ1, HIV infection.
KQ1.; Benefits of PrEP vs. placebo or no PrEP | Quality of life: k=0 | -- | -- | -- | -- | -- | --
KQ1a.; Benefits of PrEP by population subgroups | HIV infection: k=12 RCTs (n=18,244) | Stratified by risk category (p=0.43 for interaction); MSM: 4 trials; RR, 0.23 (95% CI, 0.08 to 0.62); I^2^=64%; PWID: 1 trial; RR, 0.52 (95% CI, 0.29 to 0.92); Heterosexual contact: 5 trials; RR, 0.54 (95% CI, 0.31 to 0.97); I^2^=82%; No differences in within-study subgroup analyses on age (4 trials) or sex (3 trials) | Some inconsistency within risk category subgroups; precise; No reporting bias detected | Good | See Body of Evidence Limitations for KQ1, HIV infection. | Moderate | Studies of women and men at increased risk via heterosexual contact conducted in Africa; the only study of PWID conducted in Asia; several studies of MSM conducted in the U.S., Europe, and Canada.
KQ1b.; Benefits of PrEP by dosing strategy or regimen | HIV infection: k=12 RCTs of PrEP vs. placebo or no PrEP (n=18,172), 1 RCT of daily vs. intermittent or on-demand PrEP (n=535) | PrEP vs. placebo or no PrEP: Stratified by TDF or TDF-FTC (p=0.65 for interaction); TDF: 5 trials; RR, 0.49 (95% CI, 0.28 to 0.84); I^2^=58%; TDF-FTC: 8 trials; RR, 0.44 (95% CI, 0.27 to 0.72); I^2^=74%; Stratified by daily or on-demand dosing (p=0.13 for interaction); Daily dosing: 9 trials; RR, 0.47 (95% CI, 0.32 to 0.71); I^2^=75%; On-demand dosing: 1 trial; RR, 0.14 (95% CI, 0.03 to 0.63); One head-to-head trial found no difference between daily vs. intermittent or on-demand PrEP, but not powered to assess effects on HIV infection | Some inconsistency in stratified analyses (may be explained by level of adherence); precise; No reporting bias detected | Good | See Body of Evidence Limitations for KQ1, HIV infection. | High for TDF vs. TDF-FTC, moderate for daily dosing vs. on-demand dosing | Five trials evaluated TDF alone, which is not approved for PrEP in the U.S.; 1 trial evaluated on-demand dosing of PrEP vs. placebo in MSM; no studies on intermittent or on-demand dosing in women or PWID.
KQ2.; Diagnostic accuracy of instruments for identifying persons at risk of incident HIV infection | k=7 studies of risk prediction or diagnostic accuracy (n=32,311) | MSM: AUROC, 0.66 to 0.72 for different instruments in 3 studies; a fourth study reported better goodness of fit than with instruments evaluated in other studies (AUROC NR). AUROC, 0.49 to 0.63 for different instruments in 2 studies of black MSM.; PWID: AUROC, 0.72 in 1 study. | Consistent; precise; No reporting bias detected | Fair | Retrospective design; each instrument validated in 1 study or not validated in a cohort independent from the one used to develop the instrument; cutoffs not predefined in any study. | Low | All studies conducted in the U.S.; 3 studies used cohorts that included persons who underwent HIV testing prior to the year 2000; no study evaluated a U.S.-applicable instrument for risk prediction in women.
KQ3.; Adherence to PrEP in U.S. primary care–applicable settings | k=10 (3 RCTs and 7 observational studies) (n=3,177) | In 5 studies of U.S. MSM, adherence to PrEP (based on dried blood spot sampling levels consistent with ≥4 doses/weeks) ranged from 22% to 90%; adherence rates were lower in studies of younger (mean age, 16 to 20 years) MSM.; One RCT of U.S. MSM found higher adherence with daily than intermittent or event-driven PrEP. | Inconsistent; precise; No reporting bias detected | Fair | Observational data from implementation studies; variability in duration of PrEP use; high attrition; variability in methods for measuring adherence. | Moderate | Most studies evaluated U.S. MSM; no direct evidence on adherence in U.S. PWID or women and men at increased risk of HIV infection via heterosexual contact; adherence rates were higher in some studies that evaluated a lower threshold for adherence.
KQ4.; Association between adherence to PrEP and effectiveness for preventing HIV acquisition | k=12 (7 RCTs and 5 observational studies) (n=11,479) | Three RCTs found higher adherence to PrEP associated with greater effectiveness for reducing risk of HIV infection than lower adherence.; Four of 5 RCTs found presence of tenofovir in plasma samples associated with decreased likelihood of HIV infection compared with no detectable tenofovir (ORs ranged from 0.10 to 0.54). | Consistent; precise; No reporting bias detected; however, not all RCTs of PrEP reported on the association between adherence and PrEP effectiveness | Good | Findings based on within-study subgroup analyses from RCTs and case-control analyses of patients randomized to PrEP; some studies reported small numbers of seroconverters on PrEP. | High | Studies performed in diverse geographic settings; only 1 study evaluated PWID.
KQ5.; Harms of PrEP | Serious adverse events: k=12 (n=18,282) | RR, 0.93 (95% CI, 0.77 to 1.12); I^2^=56% | Some inconsistency; some imprecision; No reporting bias detected | Good | Small number of serious adverse events in most trials. Composite outcome, some trials had limited details on serious adverse events. | Moderate | See Applicability for KQ1, HIV infection.
KQ5.; Harms of PrEP | Withdrawals due to adverse events: k=4 (n=10,563) | RR, 1.25 (95% CI, 0.99 to 1.59); I^2^=0% | Consistent; some imprecision; No reporting bias detected, but most trials did not report withdrawals due to adverse events | Good | Most trials did not report withdrawals due to adverse events. Composite outcome, with variability in cause of withdrawal (clinical or laboratory adverse event) and whether adverse event temporary or permanent. | Moderate | See Applicability for KQ1, HIV infection.
KQ5.; Harms of PrEP | Renal adverse events: k=12 (n=18,170) | RR, 1.43 (95% CI, 1.18 to 1.75); I^2^=0%; ARD, 0.56% (95% CI, 0.09% to 1.04%) | Consistent; precise; No reporting bias detected | Good | Variability in definition of adverse renal events (most trials defined as ≥1 grade 1 serum creatinine elevations). | High | See Applicability for KQ1, HIV infection.
KQ5.; Harms of PrEP | Gastrointestinal adverse events: k=12 (n=18,300) | RR, 1.63 (95% CI, 1.26 to 2.11); I^2^=43%; ARD, 1.95% (95% CI, 0.48% to 3.43%) | Some inconsistency; precise; No reporting bias detected | Good | Composite outcome, with no difference for specific gastrointestinal adverse events. | High | See Applicability for KQ1, HIV infection.
KQ5.; Harms of PrEP | Fracture: k=7 (n=15,241) | RR, 1.23 (95% CI, 0.97 to 1.56); I^2^=0% | Consistent; precise; No reporting bias detected | Moderate | Limited details on fracture site; most fractures traumatic in studies that provided this information. Results heavily weighted by 1 trial. | Low | See Applicability for KQ1, HIV infection.
KQ5.; Harms of PrEP | Syphilis: k=4 (n=10,775) | RR, 1.08 (95% CI, 0.98 to 1.18); I^2^=0% | Consistent; precise; No reporting bias detected, but NR in most trials | Good | Most trials were blinded, which might affect behaviors differently than when patients know they are on PrEP. | Moderate | See Applicability for KQ1, HIV infection.
KQ5.; Harms of PrEP | Gonorrhea: k=5 (n=9,296) | RR, 1.07 (95% CI, 0.82 to 1.39); I^2^=49% | Some inconsistency; some imprecision; No reporting bias detected, but NR in most trials | Good | Most trials were blinded, which might affect behaviors differently than when patients know they are on PrEP. | Moderate | See Applicability for KQ1, HIV infection.
KQ5.; Harms of PrEP | Chlamydia: k=5 (n=9,296) | RR, 0.97 (95% CI, 0.80 to 1.18); I^2^=59% | Consistent; precise; No reporting bias detected, but NR in most trials | Good | Most trials were blinded, which might affect behaviors differently than when patients know they are on PrEP. | Moderate | See Applicability for KQ1, HIV infection.
KQ5.; Harms of PrEP | Combined bacterial STIs: k=2 (n=5,291) | RR, 1.14 (95% CI, 0.97 to 1.34); I^2^=0% | Consistent; some imprecision; No reporting bias detected, but NR in most trials | Good | Most trials were blinded, which might affect behaviors differently than when patients know they are on PrEP. | Moderate | See Applicability for KQ1, HIV infection.
KQ5.; Harms of PrEP | Herpes simplex virus infection: k=3 (n=4,103) | RR, 0.85 (95% CI, 0.67 to 1.07); I^2^=19% | Some inconsistency; some imprecision; No reporting bias detected, but NR in most trials | Good | Trials were blinded, which might affect behaviors differently than when patients know they are on PrEP. | Moderate | See Applicability fo KQ1, HIV infection
KQ5.; Harms of PrEP | Hepatitis C virus infection: k=2 (n=896) | RR, 0.73 (95% CI, 0.25 to 2.10); I^2^=0% | Some inconsistency; imprecise; No reporting bias detected, but NR in most trials | Good | One trial was blinded, which might affect behaviors differently than when patients know they are on PrEP. | Low | See Applicability fo KQ1, HIV infection
KQ5.; Harms of PrEP | Spontaneous abortion^†^: k=3 (n=485) | RR, 1.09 (95% CI, 0.79 to 1.50); I^2^=0% | Consistent; some imprecision; No reporting bias detected | Good | Analysis restricted to women who became pregnant in trials of PrEP and were taken off PrEP. | Moderate | Analyses of women at high risk of HIV infection via heterosexual contact who were taken off PrEP at time of pregnancy

* For KQs 1 and 5, number of participants included in analysis.

† In women who became pregnant while on PrEP.

Abbreviations: ARD=adjusted risk difference; aRR=adjusted relative risk; AUROC=area under the receiver operating characteristics curve; CI=confidence interval; KQ=key question; NR=not reported; OR=odds ratio; PrEP=pre-exposure prophylaxis; RCT=randomized, controlled trial; RR=relative risk; STI=sexually transmitted infection; U.S.=United States.

In randomized trials, PrEP was associated with decreased risk of acquiring HIV infection compared with placebo or no PrEP (11 trials, RR 0.46, 95% CI 0.33 to 0.66, I^2^=67%).^52–54,70,76,78,^ ^85,97,100,117,119,120^ The absolute difference in risk of HIV infection was about 2 percent after 4 months to 4 years, for a number needed to treat with PrEP to prevent 1 case of HIV infection of about 50. In three trials conducted in the United States and Europe, each of which evaluated men who have sex with men (HIV incidence, 4% to 8% with placebo or no PrEP), the pooled absolute difference was about 5 percent after 9 months to 2 years (range, 4% to 6%), for a number needed to treat of about 20.^52,78,85^ In the United States, the only approved regimen for PrEP is daily TDF-FTC. However, effects of PrEP on HIV infection risk were very similar for TDF alone (RR, 0.49 [95% CI, 0.28 to 0.84]; I^2^=58%) and TDF-FTC (RR, 0.44 [95% CI, 0.27 to 0.72]; I^2^=74%). Therefore, the overall pooled estimate includes both regimens. Statistical heterogeneity was present in the pooled estimate, but not related to use of TDF alone or TDF-FTC. Among individual trials, PrEP was least effective in two trials of African women at increased risk of HIV infection because of heterosexual activity characterized by low rates of PrEP adherence.^76,120^ There was a strong association between the degree of study-level adherence and estimates of effectiveness, when adherence was analyzed as either a categorical or continuous variable. In six trials in which adherence was 70 percent or greater, the pooled RR was 0.27 (95% CI, 0.19 to 0.39; I^2^=0%), with no statistical heterogeneity.^52,53,70,78,85,119^

Additional analyses also support an association between higher PrEP adherence and greater effectiveness, including subgroup analyses of trial participants stratified according to level of PrEP adherence and analyses on the association between tenofovir levels and risk of HIV infection in persons using PrEP.^70,76,97,99,100,109,119,120^ Modeling based on trial data indicates that PrEP is highly effective in men who have sex with men taking four doses per week (estimated reduction in risk, 96%), and reduction in risk is high even at two doses per week (reduction in risk, 76%),^141^ suggesting important benefits of PrEP even with incomplete adherence. These findings also suggest the potential use of event-driven (targeted at periods of higher HIV risk) or intermittent (regular nondaily) dosing strategies in this population. In fact, one trial (IPERGAY) found event-driven PrEP in men who have sex with men associated with substantially reduced risk of HIV infection versus no PrEP (RR, 0.14 [95% CI, 0.03 to 0.63]).^52^ IPERGAY evaluated a population of men who have sex with men with relatively frequent sexual intercourse (median, 10 episodes per month) and dosing of PrEP (median, 15 doses per month), potentially limiting applicability to populations in which dosing is less frequent. However, a post hoc subgroup analysis of IPERGAY found that event-driven PrEP was also effective in men who used 15 or fewer doses per month (HIV incidence, 0 vs. 9.3/100 person-years; relative reduction in risk of HIV infection, 100% [95% CI, 20 to 100]).^151^

The applicability of evidence on effects of adherence and event-driven or intermittent dosing from studies of men who have sex with men to other populations is uncertain. Tenofovir accumulates rapidly and at high concentrations in rectal compared with vaginal tissue, which could reduce the effectiveness of nondaily dosing in women in whom the primary mode of transmission is through receptive vaginal intercourse. A modeling study estimated that 98 percent or greater of the population achieved protective mucosal tissue levels by the third day of exposure with TDF-FTC, although six doses/week were required to protect the lower female genital tract, compared with two doses/week to protect colorectal tissue.^152^ On the other hand, simian studies have shown protective effects of tenofovir alafenamide from rectal simian HIV challenge despite low rectal mucosal concentrations, suggesting that the correlation between rectal or genital mucosal concentrations of tenofovir and protection from HIV infection may be limited.^153^ No study evaluated effectiveness of intermittent or event-driven dosing in women or persons who inject drugs.

Findings regarding effectiveness of PrEP were robust in subgroup and stratified analyses based on HIV risk category (men who have sex with men, persons who inject drugs, or persons at risk of HIV infection via heterosexual contact), study duration, study quality, age, and sex. However, evidence in persons who inject drugs was limited to one Thai-based trial in which most patients received directly observed therapy and sterile syringes were not provided (RR, 0.52 [95% CI, 0.29 to 0.92]),^97^ and all trials of persons at risk via heterosexual contact were conducted in Africa, which might limit applicability to U.S. practice. Effects of PrEP were stronger in trials conducted in the United States, Europe, and Canada (RR, 0.13 [95% CI, 0.05 to 0.32]) than in studies conducted in Africa, Asia, or internationally (RR, 0.54 [95% CI, 0.37 to 0.79]); this could be related to high adherence in the North American and European trials or differences across countries in HIV epidemiology and management (e.g., differences in the proportion of HIV-infected partners treated with ART). No study evaluated effectiveness of PrEP according to an HIV-infected sexual partner’s use of ART or viral load,^52,78,85^ and no randomized trial enrolled adolescents. However, in 2018 the FDA approved TDF-FTC for PrEP in adolescents weighing at least 35 kg. This decision was informed by a demonstration study of PrEP in men who have sex with men ages 15 to 17 years that found a similar safety profile for TDF-FTC compared with the safety profile observed in adults.^92^

Evidence on beneficial effects of PrEP on clinical outcomes other than HIV infection was sparse. PrEP was associated with a statistically nonsignificant trend toward reduced risk of mortality versus no PrEP or placebo (RR, 0.81 [95% CI, 0.59 to 1.11]; I^2^=0%), and trials were not designed to address this outcome.^52,53,70,76,78,85,97,100,117,119,120^ No trial reported effects of PrEP on quality of life, although limited qualitative research suggests that PrEP may reduce anxiety or worry about getting HIV.^154^

Although PrEP was associated with some harms, most appeared relatively mild and reversible with discontinuation of PrEP. PrEP was not associated with an increased risk of serious adverse events,^52–54,70,76,78,85,97,100,117,119,120^ and there was a statistically nonsignificant trend toward increased risk of withdrawal due to adverse events (RR, 1.25 [95% CI, 0.99 to 1.59]).^52,70,100,117,^ ^120^ PrEP was associated with increased risk of gastrointestinal events (RR, 1.63 [95% CI, 1.26 to 2.11]; ARD, 1.95%),^52–54,70,76,78,85,97,100,117,119,120^ that generally improved with longer duration of therapy. Consistent with renal effects of tenofovir, PrEP was also associated with an increased risk of renal insufficiency (RR, 1.43 [95% CI, 1.18 to 1.75]; ARD, 0.56%),^52–54,70,76,78,85,97,100,117,^ ^119,120^ which generally appeared to be mild and resolved with cessation of PrEP. Consistent with effects of tenofovir on bone loss, PrEP was associated with a statistically nonsignificant trend toward increased risk of fracture (RR, 1.23 [95% CI, 0.97 to 1.56]);^52,70,76,85,97,100,119^ results of the fracture meta-analysis were heavily weighted by the Bangkok Tenofovir Study.^97^ Studies with longer-term followup would be helpful for clarifying fracture risk, given the relatively short followup in the trials (4 months to 4 years) and potential long-term effects of tenofovir on bone density and fracture risk. Based on currently available shorter-term data, any effects of PrEP on fracture risk appear small (ARD, 0.21%). For all harms, low adherence could attenuate risk estimates.

The rate of resistance mutations to tenofovir or emtricitabine appears low. Most cases of antiretroviral resistance occurred in persons who were HIV-infected at baseline, underscoring the importance of clinical history and HIV testing to rule out acute or chronic HIV infection before initiation of PrEP. There was insufficient evidence to determine the effects of antiretroviral resistance on clinical outcomes, which is likely to depend on the specific resistance mutation, persistence of antiretroviral resistance following cessation of PrEP, the propensity for resistance to return with re-exposure, and the selection and effectiveness of alternative therapy, if needed.^155^ In U.S. settings, alternative antiretroviral regimens are generally available for the common (K65R, M184I, M184V) resistance mutations observed in trials of PrEP. Furthermore, the number of HIV cases averted by PrEP appears to be substantially higher than the number of cases of antiretroviral resistance caused.^103^

A concern about PrEP has been the potential for behavioral risk compensation. There was no association between PrEP and increased risk of bacterial STIs in RCTs.^70,78,100,119,120^ However, in most trials, patients were blinded to whether they were randomized to PrEP or placebo, which might affect sexual behaviors differently than when patients know they are on PrEP, such as in clinical practice. One open-label trial (PROUD) found no statistically significant association between PrEP and STIs in men who have sex with men, but there was a trend toward increased risk, consistent with the higher prevalence of risky sexual behaviors among men randomized to PrEP that was observed in this trial.^78^ In addition, participants in randomized trials may differ from the general population of PrEP users with regard to STI risk behaviors. Although a U.S. demonstration project found a high rate of STIs in men who have sex with men on PrEP, it was not possible to determine if PrEP increased the risk of STIs, since it did not include a no-PrEP comparison group.^81^ A recent systematic review that included PROUD, the U.S. demonstration study, and other open-label, nonrandomized studies found PrEP associated with an increased risk of rectal chlamydia (4 studies; OR, 1.59 [95% CI, 1.19 to 2.13]), but no statistically significant association between PrEP and risk of chlamydia at any site (5 studies; OR, 1.23 [95% CI, 1.00 to 1.51]), STIs overall (8 studies; OR, 1.24 [95% CI, 0.99 to 1.54]), syphilis (6 studies; OR, 1.12 [95% CI, 0.86 to 1.47]), or gonorrhea (5 studies; OR, 1.13 [95% CI, 0.78 to 1.64]).^156^ Methodological shortcomings of the nonrandomized studies included use of a before-after study design, failure to adjust for differential STI testing rates, and use of self-report to determine STI rates before initiation of PrEP. Some data suggest that persons who engage in riskier behaviors tend to be more adherent to PrEP (see Contextual Question 1),^81,93,97^ which might offset negative effects related to any increase in risky behaviors. There was no association between PrEP and risk of HSV infection,^80,107,119^ although some trials^80,119^ found decreased risk or a trend toward decreased risk, consistent with antiviral effects of tenofovir on HSV.^79,80^ Cases of acute hepatitis C virus infection have been reported in U.S. men who have sex with men using PrEP,^157^ but data from randomized trials are too limited to determine effects on risk of hepatitis C virus infection.^52,78^

Our findings are generally consistent with other recent meta-analyses that found PrEP to be effective at reducing risk of HIV infection and greater estimates of effectiveness in trials reporting higher adherence.^90,158,159^ For example, a review by Fonner et al also found a roughly linear relationship between adherence and PrEP effectiveness (based on the log RR).^90^ Our findings were strengthened with the addition of recent, large trials that were published subsequent to the previous reviews, including the only trial of event-driven PrEP (IPERGAY)^52^ and an open-label pragmatic trial (PROUD).^78^ A sigmoid-shaped association between mean tenofovir plasma levels in trials of PrEP and effectiveness for preventing HIV infection has been proposed, but the analysis included data from trials of nonoral PrEP, was based on relatively few studies reporting plasma levels, and did not include some recently published trials.^160^ Previous reviews also reported similar findings of no increased risk of serious adverse events or any adverse event, although most reviews did not focus on individual harms.^90,158,159^ Our finding of an increased risk of renal adverse events was consistent with a recent review that found PrEP associated with increased risk of grade 1 creatinine elevation or worse (OR, 1.39 [95% CI, 1.09 to 1.71]).^161^

Data on effects of PrEP in pregnancy were very limited. Trials that enrolled women excluded pregnant women and discontinued PrEP in women who became pregnant. However, among women who became pregnant in the trials, PrEP was not associated with increased risk of spontaneous abortion (RR, 1.09 [95% CI, 0.79 to 1.50])^54,112,120^ or other adverse pregnancy outcomes. A systematic review of women infected with HIV or hepatitis B virus who received tenofovir during pregnancy (not for PrEP) found mild-to-moderate maternal and infant harms that were not considered to be tenofovir-related, no increased risk of growth or bone abnormalities in infants exposed in utero, and no increased risk of congenital abnormalities.^162^ Although FDA labeling information and perinatal antiretroviral treatment guidelines permit use of TDF-FTC during pregnancy, guidelines note that data on safety of PrEP use during pregnancy and lactation are limited.^47^ A recent African randomized trail found combination ART with tenofovir associated with increased risk of early infant death compared with combination ART with zidovudine,^163^ although methodological issues in the trial have been noted,^164^ and applicability to U.S. practice is uncertain. TDF-FTC is a FDA pregnancy category B drug, and the FDA-approved label recommends that nursing mothers not breastfeed if they are taking TDF-FTC.

Understanding adherence to PrEP in U.S. primary care and primary care–applicable settings could help to inform applicability of RCTs, which were primarily conducted in low-income settings. Two implementation studies of U.S. men who have sex with men (mean age, 34 to 35 years) found high levels of adherence (80% to 90%) based on documentation of highly protective drug levels.^81,127^ Studies of younger (mean age, 16 to 20 years) U.S. men who have sex with men found lower levels of adherence that declined over time, highlighting the need for additional PrEP adherence support strategies in this population.^92,93^ One RCT of U.S. men who have sex with men found higher adherence with daily than intermittent or event-driven PrEP.^123^ Data on adherence to PrEP in U.S. persons who inject drugs and persons at risk via heterosexual contact are needed.

Instruments that are accurate for predicting risk of incident HIV infection could help inform decisions regarding eligibility for PrEP. Several instruments for predicting incident HIV infection in men who have sex with men found moderate discrimination (AUROC estimates ranged from 0.66 to 0.72), but require further validation.^129–132^ All studies applied instruments retrospectively and some instruments were developed using data from older cohorts in which the effects of factors associated with HIV incidence (e.g., nitrates, amphetamines) may differ from contemporary populations. One instrument for predicting incidence of HIV infection in persons who inject drugs also reported moderate discrimination, but has not been validated.^133^ Several studies evaluated instruments for predicting risk of HIV infection in women but were developed using data from African cohorts, with limited applicability to U.S. settings. CDC guidelines include criteria for determining eligibility for PrEP in men who have sex with men, persons who inject drugs, and persons at risk via heterosexual activity, but more validation is needed.^47^ No study evaluated an instrument for predicting incident HIV infection in persons not already identified as belonging to a risk category. This is relevant because patients who are at risk of acquiring HIV infection may not be recognized as belonging to an HIV risk category.

## Limitations

Our review had some limitations. As statistical heterogeneity was anticipated in pooled analyses, we used the DerSimonian and Laird random-effects model to pool studies. The DerSimonian and Laird random-effects model may result in CIs that are too narrow when heterogeneity is present, particularly when the number of studies is small.^88^ Therefore, we repeated analyses in which statistical heterogeneity was present using the profile likelihood method, which resulted in similar findings. To explore statistical heterogeneity, we also performed sensitivity and subgroup analyses based on adherence level, study quality, duration of followup, HIV risk category, PrEP regimen, and geographic setting. Although statistical heterogeneity remained present in some analyses, results consistently favored PrEP, although estimates varied according to level of adherence and geographic setting. We did not have access to individual patient data. Therefore, our findings are based on analyses of study-level data and our ability to analyze subgroup effects was restricted to published reports. We excluded non-English–language articles, which could result in language bias. However, some research suggests that English-language restriction has little effect on the conclusions of systematic reviews of topics other than complementary medicine, and we did not identify large non-English trials of PrEP versus placebo in other systematic reviews.^165,166^ We only assessed for publication bias using statistical and graphical methods to assess for small sample effects when there were at least 10 studies, as research indicates that such methods can be misleading with smaller numbers of studies.^91^ Funnel plot asymmetry was present (Appendix C Figure 1) for the outcome of HIV infection and a test for small sample effects was statistically significant. Although small sample effects may be due to publication bias, graphical and statistical tests can be difficult to interpret in the presence of other factors that could influence study results, such as differences across trials in geographic setting, adherence levels, HIV risk category, and other factors. We identified no unpublished trials of PrEP in searches on a clinical trials database (clinicaltrials.gov). Our primary analyses were based on data reported in journal publications. In three trials included in the FDA medical review of PrEP with tenofovir and emtricitabine, there were some discrepancies between the journal articles and the FDA report for numbers of HIV cases and fractures.^89^ In the iPrEx trial, more HIV infections in both the PrEP and placebo arms were reported in the FDA review than in the journal publication.^100^ A sensitivity analysis that used the FDA data resulted in similar results for iPrEx (RR, 0.58 [95% CI, 0.41 to 0.82]) compared with results in the journal publication (RR, 0.53 [95% CI, 0.36 to 0.77]) and no change in the pooled estimate (RR, 0.45 [95% CI, 0.30 to 0.66]). Similarly, although there were some discrepancies in fractures rates between the journal publications and the FDA review for the iPrEx, Partners PrEP, and CDC Safety Study trials, a sensitivity analysis based on FDA data did not affect the estimate for fracture risk. Although publication and reporting bias may be associated with industry funding, few PrEP trials reported receipt of industry support, with support in those trials primarily consisting of provision of study drugs. Stratified analyses did not indicate better results for PrEP in trials that reported some industry support. However, some trials that received donated study drugs may not have reported it, which could have resulted in some misclassification.

## Emerging Issues/Next Steps

Alternative PrEP regimens that are easier to tolerate, do not require daily administration, are not associated with adverse renal and gastrointestinal effects, do not select for drug resistance, and achieve protective levels could increase the effectiveness of PrEP, improve the balance of benefits to harms, and facilitate greater uptake of PrEP. Regimens under investigation include an alternative form of tenofovir with fewer adverse effects, long-acting injectable formulations, vaginal gels or rings, and implants.

The specific prodrug of tenofovir currently approved by the FDA for PrEP is TDF. A different prodrug, tenofovir alafenamide phosphate, appears to be associated with fewer renal adverse effects and fractures than TDF,^167^ and is undergoing evaluation in combination with FTC for PrEP.^168^ Tenofovir could also be delivered as a biodegradable, long-acting implant.^169^

Maraviroc is a cysteine-cysteine chemokine receptor 5 antagonist HIV entry inhibitor that achieves high concentrations in cervicovaginal fluid, vaginal tissues, and rectal tissues; does not interact with commonly used oral contraceptives; does not select for drug resistance to recommended first-line antiretroviral drugs; and is associated with less bone loss than TDF and has been investigated for PrEP. A recent randomized trial of 188 women who reported recent condomless vaginal intercourse with at least one man with HIV infection or of unknown serostatus was not designed to assess efficacy, but reported no cases of HIV infection in women randomized to daily maraviroc only, maraviroc with TDF, maraviroc with FTC, or TDF-FTC, with no difference in risk of adverse events.^170^ A similarly designed trial of 406 men who have sex with men and transgender women was also not powered to assess efficacy, but reported 5 cases of HIV infection with maraviroc alone, 1 with maraviroc with TDF, and none with maraviroc with FTC or TDF-FTC (p=0.32 for differences by regimen).^171^

Long-acting injectable formulations of antiretroviral drugs that provide sustained drug delivery can be dosed as infrequently as once every 2 or 3 months.^172^ Two long-acting injectable agents are cabotegravir and rilpivirine, although data on effects on HIV infection versus placebo or standard PrEP are not yet available. A potential drawback of long-acting injectable agents is the extremely long half-life following administration. Missed or delayed doses would result in a prolonged pharmacological tail period with subtherapeutic drug levels that could increase the likelihood of resistance mutations if HIV infection is acquired. This differs from implants, which could be removed if needed without a prolonged pharmacological tail period.

In women, PrEP could be delivered vaginally via gel or a ring. Although one trial found pericoital 1 percent tenofovir gel associated with a reduction in risk of HIV transmission of nearly 40 percent,^75^ other trials found no effect,^76,77^ with some evidence of an association between higher adherence and greater effectiveness. Two trials found that the dapivirine vaginal ring, inserted monthly, was associated with a reduction in risk of HIV infection of about 30 percent versus placebo,^73,74^ or lower than the efficacy reported in most trials of daily oral PrEP. As in trials of other PrEP formulations, effectiveness was higher in women who were more adherent. The vaginal ring was not effective in younger (age <21 years) women, a subgroup with lower adherence.

## Relevance for Priority Populations, Particularly Racial/Ethnic Minorities

In the United States, HIV disproportionately affects racial/ethnic minorities, in particular black and Hispanic persons. One trial found no difference in effectiveness of PrEP between Hispanic and non-Hispanic persons,^100^ and trials found PrEP to be effective in diverse racial/ethnic populations worldwide. However, one study found that the proportion of PrEP initiators who are black (10%) or Hispanic (12%) is low relative to the rate of new HIV infections in these groups (44% and 23%, respectively),^173^ suggesting disparities in provision of PrEP. Nearly three-quarters of new PrEP initiators are white, despite accounting for about one-quarter of new infections.

Although PrEP was associated with decreased risk of HIV infection in women at high risk of acquisition via heterosexual contact, all trials were conducted in Africa. Some data suggest disparities in the United States with regard to implementation of PrEP in women. In one study, women comprised about 20 percent of PrEP initiators,^173^ despite accounting for about 40 percent of PrEP-eligible persons.^64^ Another study found that only 2.5 percent of persons with commercial insurance prescribed PrEP were women.^174^ Data on the number of pregnant or lactating women on PrEP are not available, but use in these populations is likely to be low.

Evidence also suggested ongoing barriers to implementation of PrEP in men who have sex with men. In U.S. men who have sex with men who met CDC criteria for PrEP, more than half were unwilling to take it or believed they were inappropriate candidates.^175^ Less than 10 percent of persons who were appropriate candidates were using and adherent to PrEP. A study of young (ages 16 to 29 years) men who have sex with men found that about 12 percent reported ever taking PrEP; among black participants, the proportion was even lower, at 4.7 percent.^176^ A study of young (ages 16 to 29 years) black men who have sex with men found that more than half of those who were eligible for and interested in starting PrEP did not follow up for initiation, even though the study was designed to cover clinic, laboratory, and prescription costs.^177^ Data on uptake and effectiveness of PrEP in transgender women is limited. A study of transgender women in San Francisco found that by the end of 2013, 14 percent knew about PrEP, despite a high HIV prevalence in this population.^178^ Although it is unlikely that there are significant drug interactions between hormone treatments and PrEP, pharmacological interaction studies in transgender women are lacking,^179^ although several studies are underway.^180–182^ Randomized trials that included transgender women have not been powered to evaluate effectiveness in this subgroup. A post hoc analysis of iPrEx^100^ found that PrEP was effective in men who have sex with men (HR, 0.50 [95% CI, 0.34 to 0.75]) but not in transgender women (HR, 1.1 [95% CI, 0.5 to 2.7]), although the interaction was not statistically significant (p=0.09),^98^ precluding reliable conclusions about a subgroup difference. In the iPrEx trial, adherence was lower in transgender women than in men who have sex with men, particularly among those who reported receptive anal intercourse without a condom. In addition, there was an association between TFV drug level detectability and decreased risk of HIV infection, highlighting adherence as a potentially important implementation challenge in this population. No PrEP trial enrolled transgender men and data on the prevalence of HIV infection in this population are lacking.^183^

One Asian trial found PrEP to be effective in persons who inject drugs.^97^ Uptake of PrEP in persons who inject drugs appears relatively low. A 2012 study of persons who inject drugs in Washington, D.C., found that only 13 percent had ever heard of PrEP and none had ever used PrEP or knew someone who had.^184^ About 50 percent were very likely and one-quarter somewhat likely to take PrEP if it was available without cost. Factors associated with willingness to use PrEP included younger age, sharing injection equipment, and believing they would no longer need to use clean needles. A 2012 to 2013 study of persons who inject drugs in Vancouver, Canada, found that approximately one third expressed willingness to use PrEP.^185^ Factors associated with willingness to use PrEP included younger age, engaging in sex work, and reporting multiple recent sexual partners. Further PrEP studies in persons who inject drugs are indicated.

The FDA recently approved daily oral TDF-FTC in adolescents weighing at least 35 kg. Data indicate increasing incidence of HIV infection among adolescents and young adults. Persons younger than age 25 years represent about 7.5 percent of PrEP initiators.^173^ A recent implementation study of men who have sex with men ages 15 to 17 years in which patients were permitted to autonomously consent found low adherence that decreased over time, with a high incidence of STIs and HIV infection.^92^

## Future Research

A number of trials of PrEP are ongoing. These include trials on the safety and efficacy of injectable cabotegravir compared with daily oral TDF-FTC for PrEP in HIV-uninfected women, men who have sex with men, and transgender women;^186,187^ a trial on safety and efficacy of emtricitabine and tenofovir alafenamide fixed-dose combination once daily for PrEP in men and transgender women who have sex with men and are at risk of HIV-1 infection;^168^ a trial of injectable rilpivirine in HIV-uninfected women;^188^ and a trial of an enhanced versus standard PrEP adherence intervention in young, black men who have sex with men.^189^ Trials that compare daily versus event-driven or intermittent dosing and are sufficiently powered to evaluate effects on risk of HIV acquisition would be helpful for clarifying effective and efficient dosing strategies in different populations. A recent trial conducted in Africa (n=622) of daily, intermittent (twice weekly with an additional dose after sexual intercourse) or event-driven (24 to 48 hours before and within 2 hours after sexual intercourse) TDF-FTC for PrEP in men who have sex with men and women at risk of HIV infection via heterosexual contact was not designed to assess comparative efficacy for preventing HIV infection, and reported only 5 cases of seroconversion following randomization, although adherence was highest with the daily regimen.^122,123^ Research is needed to better understand the adherence implications of different dosing regimens in U.S. populations and effect on PrEP effectiveness.

Randomized trials or demonstration projects of PrEP in U.S. populations of women at high risk via heterosexual contact and persons who inject drugs are needed to verify the applicability of trials conducted in low-income settings to the United States, including the effectiveness of PrEP in primary care settings. Studies should measure adherence and evaluate the association between adherence and effectiveness. Research is needed to determine the safety and effectiveness of PrEP during pregnancy or lactation and in transgender women, the effectiveness and long-term safety (e.g., bone effects) of PrEP in adolescents, and to understand effects of PrEP on quality of life. Studies on factors associated with adherence and methods for increasing uptake and adherence to PrEP would be very helpful for guiding strategies to increase uptake and adherence to PrEP, particularly in populations with low adherence, such as adolescents and racial/ethnic minorities.

Additional research would help clarify effects of PrEP related to behavioral risk compensation. Open-label studies, including observational studies that include a concurrent no-PrEP comparison group and account for differential STI rates would be helpful for understanding behavioral risk compensation effects in clinical practice. Research is also needed to clarify whether oral PrEP confers protective effects against HSV and how any observed effects on HSV affect HIV acquisition risk. Research is also needed on effects of PrEP on hepatitis C virus infection, particularly in populations at high risk of hepatitis C virus (e.g., persons who inject drugs, men who have sex with men).

Research is also needed to develop and validate instruments for identifying persons at high risk of acquiring HIV infection. Existing instruments in men who have sex with men and persons who inject drugs require further validation in independent cohorts, ideally with prospective application of risk assessment instruments and assessment of HIV incidence, and should be applicable to racial/ethnic minorities. Initial instruments of men who have sex with men were developed using cohorts in which racial/ethnic minorities were underrepresented, with some studies showing poor predictive utility of existing instruments in black men who have sex with men.^134,135^ A study of a new risk instrument (Sex Pro) specifically designed for black men who have sex with men has been conducted, but only published as a conference abstract.^190^ Instruments are also needed for assessing risk of HIV infection in heterosexually active U.S. women.

## Conclusions

In adults at increased risk of HIV infection, PrEP with oral TDF or TDF-FTC is associated with decreased risk of HIV infection compared with placebo or no PrEP, although effectiveness decreases with inadequate adherence. PrEP is associated with increased risk of renal and gastrointestinal events, but the incidence of nongastrointestinal adverse events is low and most adverse events appear mild and reversible with discontinuation of PrEP. Evidence on the accuracy of instruments for identifying persons at high risk of HIV infection is limited, with further validation required.