# Chapter 3 Results

A total of 3,116 references from electronic database searches and manual searches of recently published studies were reviewed and 308 full-text papers were evaluated for inclusion. Across all Key Questions, 14 RCTs (in 37 articles^52–54,70,76,78,85,94–123^), eight observational studies,^81,92,93,124–128^ and seven studies of diagnostic accuracy of HIV risk prediction instruments^129–135^ were included. Included studies and quality ratings are described in Appendix B.

## Key Question 1 What Are the Benefits of PrEP in Persons Without Pre-Existing HIV Infection Versus Placebo or No PrEP (Including Deferred PrEP) on the Prevention of HIV Infection and Quality of Life?

### Summary

- PrEP was associated with decreased risk of HIV infection versus placebo or no PrEP in populations at higher risk of acquiring HIV (11 trials; relative risk [RR], 0.46 [95% CI, 0.33 to 0.66], I^2^=67%; absolute risk reduction [ARR], −2.0% [95% CI, −2.8 to −1.2%] after 4 months to 4 years).^52,53,70,76,78,85,97,100,117,119,120^
- There was a strong association between degree of adherence and PrEP effectiveness (p<0.00001 for interaction)
  ○ Adherence ≥70%: 6 trials; RR, 0.27 [95% CI, 0.19 to 0.39]; I^2^=0%^52,53,70,78,85,119^
  ○ Adherence >40% to <70%: 3 trials; RR, 0.51 [95% CI, 0.38 to 0.70]; I^2^=0%^97,100,117^
  ○ Adherence ≤40%: 2 trials; RR, 0.93 [95% CI, 0.72 to 1.20]; I^2^=0%^76,120^
- PrEP was consistently associated with decreased risk of HIV infection when trials were stratified according to risk category, study duration, setting (high- or low-income), and study quality, and in subgroup analyses based on age^70,97,100,120^ and sex.^70,97,119^
- Effects of PrEP versus placebo or no PrEP on risk of HIV infection were similar with TDF alone (RR, 0.49 [95% CI, 0.28 to 0.84]; I^2^=58%) and TDF-FTC (RR, 0.44 [95% CI, 0.27 to 0.72]; I^2^=74%); one trial of men who have sex with men^52^ evaluated event-driven (as opposed to daily) PrEP (RR, 0.14 [95% CI, 0.03 to 0.63]).
- PrEP was associated with a statistically nonsignificant trend toward reduced risk of mortality versus no PrEP or placebo (9 trials; RR, 0.81 [95% CI, 0.59 to 1.11]; I^2^=0%).^70,^ ^76,78,85,97,100,117,119,120^
- No trial reported effects of PrEP versus placebo or no PrEP on quality of life.

### Evidence

Twelve RCTs (reported in 29 publications^52–54,70,76,78,85,95–98,100,102–104,106–109,111–115,117–121^) evaluated PrEP versus placebo or no PrEP (Table 2; Appendix B Tables 1–3). Two trials^53,54^ enrolled 72 patients each; in the other 10 trials, the sample sizes ranged from 400 to 4,726 (total N=18,244). Duration of followup ranged from 4 months to 4 years. Eleven RCTs randomized patients to PrEP or placebo. The other trial randomized patients to immediate PrEP versus delayed PrEP (no PrEP for 1 year, after which patients received PrEP).^78^ Six trials^54,70,76,117,119,120^ enrolled men and women at increased risk of HIV infection via heterosexual contact, four trials^52,78,85,100^ enrolled men who have sex with men or transgender women, one trial^53^ enrolled both men who have sex with men and high-risk women, and one trial^97^ enrolled persons who inject drugs. The mean age in all trials was younger than age 40 years. No trial enrolled pregnant women or persons younger than age 18 years.

Table 2 Study Characteristics of RCTs of PrEP

Study name; Author, year^*^; Country; Duration of followup; Quality | Interventions^†^ | HIV risk group(s); Risk-based inclusion criteria | Patient characteristics | Adherence (method for measuring adherence)
Bangkok Tenofovir Study; Choopanya, 2013^97^; Thailand; 4 years (mean); Good | A. TDF 300mg (n=1,204); B. Placebo (n=1,209) | PWID:; Injection drug use in the previous 12 months | [underlined: A vs. B]; Age 20 to 29: 43% vs. 43%; Age 30 to 39: 38% vs. 37%; Age 40 to 49: 15% vs. 15%; Age 50 to 60: 5% vs. 5%; Male: 80% vs. 80%.; Race: NR | 67% (plasma)
FEM PrEP; Van Damme 2012^120^; Kenya, South Africa, Tanzania; 1 year; Good | A. TDF-FTC 300/200mg (n=1,062); B. Placebo (n=1,058) | High-risk women:; >1 vaginal sex acts in previous 2 weeks or >1 sex partner in the previous month | [underlined: A vs. B]; Age (mean): 24 vs. 24 years; Female: 100%; Race: NR | 37% (plasma)
CDC Safety Study; Grohskopf 2013; U.S.^85^; 2 years; Good | A. TDF 300 mg (n=201); B. Placebo (n=199) | MSM:; Biological male engaging in anal sex with another man in the previous 12 months | [underlined: A vs. B]; Age (mean): 38 vs. 37 years; Male: 100% vs. 100%; White: 79.6% vs. 66.8%; African American: 23% vs. 37%; Asian/Pacific Islander: 10% vs. 4%; Other race: 8% vs. 25% | 92% (pill count)
IAVI Uganda Study; Kibengo 2013^54^; Uganda; 4 months; Good | A. TDF-FTC 300/200mg (n=24); B. Intermittent TDF-FTC (n=24); C. Daily placebo (n=12); D. Intermittent placebo (n=12) | High-risk heterosexual men and women:; Unprotected vaginal sex with ART-naive HIV-infected partner in the previous 3 months | [underlined: A vs. B vs. C vs. D]; Age (mean): 33 vs. 33 vs. 33 vs. 33 years; Female: 50% vs. 46% vs. 67% vs. 42%; Race NR | 98% (MEMS)
IAVI Kenya Study; Mutua 2012^53^; Kenya; 4 months; Good | A. TDF-FTC 300/200mg (n=24); B. Intermittent TDF-FTC (n=24); C. Daily placebo (n=12); D. Intermittent placebo (n=12) | MSM and high-risk women:; Current or previous STI, multiple episodes of unprotected vaginal or anal sex, or engaging in transactional sex in the previous 3 months | [underlined: A vs. B vs. C vs. D]; Age (mean): 26 vs. 26 vs. 27 vs. 28 years; Female: 12% vs. 0% vs. 8% vs. 8%; Race: NR | 82% (MEMS)
IPERGAY; Molina 2015^52^; France, Canada; 9 months (median); Good | A. On-demand TDF-FTC 300/200mg (n=199); B. Placebo (n=201) | MSM:; Unprotected anal sex with at least two partners in the previous 6 months | [underlined: A vs. B]; Age (median): 35 vs. 34 years (IQR 29-43); Female: 0%; White: 94% vs. 89%; other races NR | 86% (plasma)
iPrEx; Grant 2010^100^; Brazil, Ecuador, Peru, Thailand, South Africa, United States; 1.2 years (median); Good | A. TDF-FTC 300/200 mg (n=1,251); B. Placebo (n=1,248) | Men who have sex with men:; Anal sex with ≥4 male partners, a diagnosis of an STI, history of transactional sex activity, condomless anal sex with an HIV-infected partner or partner of unknown infection status in the previous 6 months | [underlined: A vs. B]; Ages 18 to 24 years: 47% vs. 53%; Ages 25 to 29 years: 22% vs. 19%; Ages 30 to 39 years: 20% vs. 18%; Age ≥40 years: 11% vs. 10%; Born male: 100% vs. 100%; Black: 9% vs. 8%; White: 18% vs. 17%; Mixed race or other: 68% vs. 70%; Asian: 5% vs. 5%; Hispanic: 72% vs. 73% | 51% (plasma)
Partners PrEP; Baeten 2012^70^; Kenya, Uganda; 2 years (median); Good | A. TDF 300 mg + placebo TDF-FTC (n=1,571); B. TDF-FTC 300/200 mg + placebo TDF (n=1,565); C. Placebo TDF + placebo TDF-FTC (n=1,570) | High-risk heterosexual men and women:; ART-naive HIV-infected partner | [underlined: A vs. B vs. C]; Ages 18 to 24 years: 12% vs. 11% vs. 11%; Ages 25 to 34 years: 46% vs. 44% vs. 43%; Ages 35 to 44 years: 30% vs. 32% vs. 32%; Age ≥45 years: 13% vs. 14% vs. 13%; Male: 62% vs. 64% vs. 61%; Race: NR | 82% (plasma)
PROUD; McCormack 2016^78^; England; 1 year; Fair | A. Immediate TDF-FTC 245/200 mg (n=275); B. TDF-FTC deferred for 1 year (n=269) | Men who have sex with men:; Anal intercourse without a condom in the previous 90 days and likely to have anal intercourse without a condom in the next 90 days | [underlined: A vs. B]; Age (mean): 35 vs. 35 years; Male: 100% vs. 100%; White: 81% vs. 83%; Asian: 5% vs. 6%; Black: 4% vs. 4%; Other race: 10% vs. 8% | 100% (plasma)^‡^
Study of TDF; Peterson 2007^117^; Cameroon, Ghana, Nigeria; 6 months (mean); Good | A. TDF 300 mg (n=469); B. Placebo (n=467) | High-risk women:; Average of ≥3 coital acts per week and ≥4 sexual partners per month | [underlined: A vs. B]; Age (mean): 24 vs. 24 years; 100% female; Race: NR | 69% (pill count)
TDF2; Thigpen 2012^119^; Botswana; 1 year (median); Good | A. TDF-FTC 300/200 mg, (n=611); B. Placebo (n=608) | High-risk heterosexual men and women:; Sexually active in high-prevalence area | [underlined: A vs. B]; Ages 18 to 20 years: 2% vs. 3%; Ages 21 to 29 years: 90% vs. 87%; Ages 30 to 39 years: 8% vs. 10%; Female: 46% vs. 46%; Race: NR | 80% (plasma)
VOICE; Marrazzo 2015^76^; South Africa, Uganda, Zimbabwe; 3 years (maximum); Good | A. TDF 300 mg + placebo (n=1,007); B. TDF-FTC 300/200 mg + placebo (n=1,003); C. Placebo only (n=1,009) | High-risk women:; Sexually active in a high-prevalence area | [underlined: A vs. B vs. C]; Age (mean): 26 vs. 25 vs. 25 years; Female: 100% all groups; Race: NR | 30% (plasma)

* Primary publication; details on all included publications appear in Appendix B Table 1.

† Daily, oral dose unless specified.

‡ Sample of patients who reported that they were taking PrEP.

Abbreviations: ART=antiretroviral therapy; FTC=emtricitabine; iPrEx=Pre-Exposure Prophylaxis Initiative; NR=not reported; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; RCTs=randomized, controlled trials; STI=sexually transmitted infection; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Three trials^85,97,117^ evaluated TDF 300 mg, six trials^52–54,100,119,120^ evaluated TDF 300 mg-FTC 200 mg, one trial^78^ evaluated TDF 245 mg-FTC 200 mg, and two trials^70,76^ included arms for both TDF 300 mg alone and TDF 300 mg-FTC 200 mg. PrEP was prescribed daily in 11 trials^53,^ ^54,70,76,78,85,97,100,117,119,^ ^120^ and dosing was intermittent or event-driven in three trials (two of which also included daily dosing arms).^52–54^ In one trial (the Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs [IPERGAY] trial), event-driven PrEP consisted of two tablets of TDF-FTC 2 to 24 hours before intercourse, followed by one tablet 24 hours and 48 hours after the first dose; additional dosing parameters were provided for multiple consecutive sexual encounters and situations in which event-driven PrEP was taken within 1 week.^52^ Two other trials evaluated intermittent/event-driven PrEP (consisting of PrEP twice weekly and within 2 hours of intercourse) but either reported no HIV infections or combined results with patients randomized to daily PrEP.^53,54^ In all trials, HIV risk reduction and adherence counseling was provided to all patients. Free condoms were provided in all trials except for one, in which condom provision was not specified.^78^

Seven trials were conducted in Africa,^53,54,70,76,117,119,120^ one in Thailand,^97^ two in Europe or Canada,^52,78^ one in the United States,^85^ and one trial was international (~10% of patients from U.S. sites).^100^ The trial conducted in the United States (n=400) evaluated daily TDF versus placebo in men who have sex with men;^85^ the two trials conducted in Europe and Canada^52,78^ and the international trial^100^ also focused on men who have sex with men. All trials of persons at higher risk of HIV infection via heterosexual contact were conducted in Africa, and the only trial of persons who inject drugs was conducted in Thailand.^97^ In that trial, most patients received PrEP through directly observed therapy and patients were provided bleach with instructions on how to clean needles. Patients were not provided sterile syringes, although these were available without a prescription at pharmacies at low cost. The adherence level in each trial and method for measuring adherence are shown in Table 2. All trials reported funding from government agencies or nonprofit organizations. One trial also reported industry funding,^78^ three trials reported that study medications were donated by industry,^53,54,120^ and one trial noted that two investigators received royalties or funding from industry.^119^ One trial^78^ was rated fair quality because of unclear allocation concealment methods and open-label design (Appendix B Table 4). The remaining trials were rated good quality.

#### HIV Infection

Results of analyses on effects of PrEP versus placebo or no PrEP on risk of HIV infection are summarized in Table 3. Among 12 trials of PrEP versus placebo or no PrEP^52–54,70,76,78,85,97,100,117,^ ^119,120^ one small (n=72) trial^54^ reported no cases of HIV infection with either PrEP or placebo. In the other 11 trials, the proportion of patients with new HIV infection ranged from 0 to 5.6 percent among those randomized to PrEP and from 1.4 to 7.0 percent among those randomized to placebo or no PrEP (Appendix B Table 1). PrEP was associated with reduced risk of HIV infection versus placebo or no PrEP (RR, 0.46 [95% CI, 0.33 to 0.66]) (Figure 2), but statistical heterogeneity was present (I^2^=67%). The ARR was −2.0 percent (95% CI, −2.8% to −1.2%; I^2^=58%) after 4 months to 4 years. Funnel plot asymmetry was present and the test for small sample effects was statistically significant (Egger test p-value=0.03) (Appendix C Figure 1). Excluding the single fair-quality study^78^ from the analysis had little effect on the pooled estimate (RR, 0.50 [95% CI, 0.36 to 0.70]) and did not reduce statistical heterogeneity (I^2^=65%). Results were similar using the profile likelihood method (pooled RR, 0.45 [95% CI, 0.26 to 0.65]) and when FDA data on HIV incidence was used instead of the data reported in the journal publication for the Pre-Exposure Prophylaxis Initiative (iPrEx) trial.^89,100^

Table 3 Risk of HIV Infection in RCTs of PrEP Versus Placebo/No PrEP

Study characteristics | Subgroups | Number of trials | RR (95% CI) | I^2^
All trials | - | 11^52,53,70,76,78,85,97,100,117,119,120^ | 0.46 (0.33 to 0.66) | 67%
Study quality | Restricted to good-quality trials | 10^52,53,70,76,85,97,100,117,119,120^ | 0.48 (0.33 to 0.71) | 71%
PrEP drug regimen; (p=0.79 for interaction) | TDF | 5^70,76,85,97,117^ | 0.49 (0.28 to 0.84) | 58%
PrEP drug regimen; (p=0.79 for interaction) | TDF-FTC | 8^52,53,70,76,78,100,117,120^ | 0.44 (0.27 to 0.72) | 67%
Adherence; (p<0.00001 for interaction) | Adherence ≥70% | 6^52,53,70,78,85,119^ | 0.27 (0.19 to 0.39) | 0%
Adherence; (p<0.00001 for interaction) | Adherence >40% to <70% | 3^97,100,117^ | 0.51 (0.38 to 0.70) | 0%
Adherence; (p<0.00001 for interaction) | Adherence ≤40% | 2^76,120^ | 0.93 (0.72 to 1.20) | 0%
HIV risk category; (p=0.43 for interaction) | Heterosexual men and women | 5^70,76,117,119,120^ | 0.54 (0.31 to 0.97) | 82%
HIV risk category; (p=0.43 for interaction) | Men who have sex with men | 4^52,78,85,100^ | 0.23 (0.08 to 0.62) | 64%
HIV risk category; (p=0.43 for interaction) | Persons who inject drugs | 1^97^ | 0.52 (0.29 to 0.92) | Not applicable
Dosing schedule; (p=0.13 for interaction) | Daily dosing | 9^53,70,76,78,85,97,100,117,119,120^ | 0.47 (0.32 to 0.71) | 75%
Dosing schedule; (p=0.13 for interaction) | On-demand dosing | 1^52^ | 0.14 (0.03 to 0.63) | Not applicable
Followup duration; (p=0.35 for interaction) | Duration of followup <1 year | 3^52,53,117^ | 0.21 (0.07 to 0.58) | 0%
Followup duration; (p=0.35 for interaction) | Duration of followup ≥1 to 2 years | 4^78,100,119,120^ | 0.48 (0.28 to 0.84) | 70%
Followup duration; (p=0.35 for interaction) | Duration of followup ≥2 years | 4^70,76,85,97^ | 0.47 (0.22 to 1.00) | 86%
Industry support; (p=0.38 for interaction) | Study reported industry support | 3^53,119,120^ | 0.58 (0.27 to 1.22) | 54%
Industry support; (p=0.38 for interaction) | Study reported government or nonprofit funding only | 8^52,70,76,78,85,97,100,117^ | 0.39 (0.23 to 0.64) | 77%
Country setting; (p=0.004 for interaction) | U.S. or other high-income countries | 3^52,78,85^ | 0.13 (0.05 to 0.32) | 0%
Country setting; (p=0.004 for interaction) | Africa, Asia, or international trial | 8^53,70,76,97,100,117,119,120^ | 0.54 (0.37 to 0.79) | 72%

Abbreviations: CI=confidence interval; FTC=emtricitabine; PrEP=pre-exposure prophylaxis; RCT=randomized, controlled trial; RR=relative risk; TDF=tenofovir disoproxil fumarate; U.S.=United States.

Figure 2 Meta-Analysis: HIV Infection Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 2 is a forest plot of HIV infection stratified by study drug with two subgroups. The risk ratio for 5 studies in the TDF subgroup is 0.49 (95% confidence interval 0.28 to 0.84) with an I-squared value of 58%. The risk ratio for 8 studies in the FTC-TDF subgroup is 0.44 (95% confidence interval 0.27 to 0.72) with an I-squared value of 74%. The risk ratio for all studies is 0.46 (95% confidence interval 0.33 to 0.66) with I-squared value of 67%.

Two African trials (the Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women [FEM PrEP] trial and the Vaginal and Oral Interventions to Control the Epidemic [VOICE] trial)^76,120^ of women at risk of HIV infection via heterosexual contact found PrEP to be substantially less effective (RR, 0.89 [95% CI, 0.55 to 1.44] and RR, 0.95 [95% CI, 0.70 to 1.28]) than the other 10 trials (RR estimates ranged from 0.07 to 0.53). In FEM PrEP and VOICE, adherence to PrEP was low, with 30 to 40 percent of patients randomized to PrEP having detectable plasma levels of tenofovir. A stratified analysis found a strong interaction (p<0.00001) between level of adherence and effectiveness of PrEP (adherence ≥70%: 6 trials; RR, 0.27 [95% CI, 0.19 to 0.39]; I^2^=0%;^52,53,70,78,85,119^ adherence >40% to <70%: 3 trials; RR, 0.51 [95% CI, 0.38 to 0.70]; I^2^=0%;^97,100,117^ and adherence ≤40%: 2 trials; RR, 0.93 [95% CI, 0.72 to 1.20]; I^2^=0%^76,120^) and stratification eliminated statistical heterogeneity (Table 3; Figure 3).^52,53,70,76,78,85,97,100,117,119,120^

Figure 3 Meta-Analysis:– HIV Infection Stratified by Adherence

Note: Based on plasma testing, unless otherwise noted.

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 3 is a forest plot of HIV infection stratified by adherence with three subgroups. The risk ratio for 7 studies in the adherence greater than or equal to 70% subgroup is 0.27 (95% confidence interval 0.19 to 0.39) with an I-squared value of 0%. The risk ratio for 3 studies in the adherence greater than 40% and less than 70% subgroup is 0.51 (95% confidence interval 0.38 to 0.70) with an I-squared value of 0%. The risk ratio for 2 studies in the adherence less than 40% subgroup is 0.93 (95% confidence interval 0.72 to 1.20) with an I-squared value of 0%. The overall risk ratio for all studies is 0.44 (95% confidence interval 0.29 to 0.65) with an I-squared value of 72%.

There was also a strong association between adherence and effectiveness when adherence was analyzed as a continuous variable in a meta-regression (p<0.0005) (Figure 4). In the meta-regression, the level of adherence accounted for all of the between-study heterogeneity. For every 10 percent increase in adherence, there was a 21 percent relative reduction in the relative risk. Meta-regression findings were similar when analyses were restricted to trials that evaluated adherence based on plasma levels or when trials were stratified according to whether they used TDF or TDF-FTC. Issues related to adherence are further addressed in Key Questions 3 and 4 and Contextual Question 1.

Figure 4 Meta-Regression: PrEP Efficacy Versus Adherence

*U.S, Canada, or Europe.

Abbreviations: FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 4 is a meta-regression of PrEP efficacy versus adherence. The X-axis indicates adherence in each trial as measured by (in order of preference) presence of detectable tenofovir on drug level testing, MEMS data, pill counts, or self-report, and the Y-axis represents the logRR from each trial for PrEP vs. placebo or no PrEP. The size of the bubble for each study indicates the weighted sample size. The bubbles from left to right, increasing in adherence across the adherence x axis are: VOICE, FEMPrEP, iPrEx, Bangkok Tenofovir Study, Study of TDF, TDF2, IAVI Kenya, Partners PrEP, IPERGAY, CDC Safety Study, and PROUD. The bubbles from bottom to top in increasing log risk ratio are: CDC Safety Study, PROUD, IPERGAY, IAVI Kenya, Partners PrEP, Study of TDF, TDF2, Bangkok Tenofovir Study, iPrEx, FEMPrEP, and VOICE. The bubbles from smallest to largest in increasing weighted sample size are: IAVI Kenya, IPERGAY, CDC Safety Study, PROUD, Study of TDF, TDF2, FEMPrEP, iPrEX, Bangkok Tenofovir Study, VOICE, and Partners PrEP.

There was no clear difference in estimates of effectiveness of PrEP for preventing HIV infection when trials were stratified according to duration of followup (Figure 5) (p=0.35 for interaction) by less than 1 year (3 trials; RR, 0.21 [95% CI, 0.07 to 0.58]; I^2^=0%; ARR, −3.0% [95% CI, −6.0% to −1.0%]; I^2^=69%),^52,53,117^ 1 year or more to less than 2 years (4 trials; RR, 0.48 [95% CI, 0.28 to 0.84]; I^2^=70%; ARR, −3.0% [95% CI, −5.0% to −1.0%]; I^2^=76%),^78,100,119,120^ or 2 or more years (4 trials; RR, 0.47 [95% CI, 0.22 to 1.00]; I^2^=86%; ARR, −2.0% [95% CI, −3.0% to −1.0%; I^2^=54%),^70,76,85,97^ or whether trials reported receipt of industry support (3 trials; RR, 0.58 [95% CI, 0.27 to 1.22]; I^2^=54%)^53,119,120^ versus only reporting governmental or nonprofit funding (8 trials; RR, 0.39 [95% CI, 0.23 to 0.64]; I^2^=77%)^52,70,76,78,85,97,100,117^ (Table 3). PrEP was more effective at preventing HIV infection in trials conducted in the United States, Europe, or Canada (3 trials; RR, 0.13 [95% CI, 0.05 to 0.32]; I^2^=0%)^52,78,85^ than in trials conducted in Africa, Asia, or internationally (8 trials; RR, 0.54 [95% CI, 0.37 to 0.79]; I^2^=72%; p=0.004 for interaction) (Figure 6).^53,54,70,76,97,100,117,119,120^ All three trials conducted in the United States, Europe, or Canada reported high adherence and enrolled men who have sex with men.

Figure 5 Meta-Analysis: HIV Infection Stratified by Study Duration

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 5 is a forest plot of HIV infection stratified by study duration with three subgroups. The risk ratio for 4 studies in the duration greater than or equal to 1 year, but less than 2 years subgroup is 0.48 (95% confidence interval 0.28 to 0.84) with an I-squared value of 70%. The risk ratio for 4 studies in the duration less than 1 year subgroup is 0.21 (95% confidence interval 0.07 to 0.58) with an I-squared value of 0%. The risk ratios for 4 studies for the duration greater than or equal to 2 years subgroup is 0.47 (95% confidence interval 0.22 to 1.00) with an I-squared value of 86%. The overall risk ratio for all studies is 0.44 (95% confidence interval 0.29 to 0.65) with an I-squared value of 72%.

Figure 6 Meta-Analysis: HIV Infection Stratified by Geographic Setting

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 6 is a forest plot of HIV infection stratified by geographic setting with two subgroups. The risk ratio for 3 studies in the U.S./Canada/Europe subgroup is 0.13 (95% confidence interval 0.05 to 0.32) with an I-squared value of 0%. The risk ratio for 9 studies in the Africa/Asia/multinational subgroup is 0.54 (95% confidence interval 0.37 to 0.79) with an I-squared value of 72%. The overall risk ratio for all studies is 0.44 (95% confidence interval 0.29 to 0.65) with an I-squared value of 72%.

#### Mortality

Nine trials^70,76,78,85,97,100,117,119,120^ of PrEP versus placebo or no PrEP reported mortality; one other trial reported no deaths with or without PrEP,^52^ and two small, short-term trials (n=72 each; followup 4 months) did not report mortality.^53,54^ PrEP was associated with a modestly decreased risk of mortality that was not statistically significant (9 trials; RR, 0.81 [95% CI, 0.59 to 1.11]; I^2^=0%); risk estimates from individual trials were imprecise (Figure 7). There was no funnel plot asymmetry (Appendix C Figure 2). Results were similar when trials were stratified according to geographic setting and when the profile likelihood method was used for pooling (RR, 0.82 [95% CI, 0.54 to 1.14]).

Figure 7 Meta-Analysis: Mortality Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis trial for HIV Prevention Among African Women; FTC=emtricitabine; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate Or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 7 is a forest plot of mortality stratified by study drug with two subgroups. The risk ratio for 5 studies in the TDF subgroup is 0.83 (95% confidence interval 0.59 to 1.18) with an I-squared value of 0%. The risk ratio for 6 studies in the FTC-TDF subgroup is 0.69 (95% confidence interval 0.31 to 1.52) with an I-squared value of 0%. The overall risk ratio for all studies is 0.81 (95% confidence interval 0.59 to 1.11) with an I-squared value of 0%.

#### Quality of Life

No trial reported effects of PrEP versus placebo on quality of life.

## Key Question 1a How Do the Benefits of PrEP Differ by Population Subgroups?

### HIV Infection

PrEP was effective across population subgroups defined by HIV risk category (Table 4). There were no clear differences in estimates of effectiveness for PrEP versus placebo or no PrEP in risk of HIV infection when trials were stratified according to whether they enrolled men and women at increased risk of HIV infection via heterosexual contact (5 trials; RR, 0.54 [95% CI, 0.31 to 0.97]; I^2^=82%),^54,70,76,117,119,120^ men who have sex with men or transgender women (4 trials; RR, 0.23 [95% CI, 0.08 to 0.62]; I^2^=64%),^52,78,85,100^ or persons who inject drugs (1 trial; RR, 0.52 [95% CI, 0.29 to 0.92]; p=0.43 for interaction) (Figure 8),^97^ although evidence of effectiveness in persons who inject drugs was limited to one trial conducted in Asia. As noted above, the two trials (FEM-PrEP and VOICE) which found PrEP to be ineffective were conducted in African women at high risk of HIV infection in whom adherence was low.^76,120^

Table 4 Effect of PrEP Versus Placebo on HIV Infection in Population Subgroups

Study | Age | Sex/Gender | Race/Ethnicity | Risk behaviors
Bangkok; Tenofovir Study; Choopanya, 2013^97^ | [underlined: Efficacy]; 20–29 years: 33.6% (95% CI, −40.1 to 69.8); 30–39 years: 29.2% (95% CI, −121.7 to 79.1); ≥40 years: 88.9% (95% CI, 41.1 to 99.4); p=NR | [underlined: Efficacy]; Female: 78.6% (95% CI, 16.8 to 96.7); Male: 37.6% (95% CI, −17.8 to 67.9); p=NR | NR | [underlined: Efficacy]; Shared needles; Yes: 54.7% (95% CI, −44.0 to 87.9); No: 47.6% (95% CI, −2.5 to 74); p=NR; Injected during 12 weeks before enrollment; Yes: 44.3% (95% CI, −12.5 to 72.4); No: 57.4% (95% CI, −17.0 to 86.6); p=NR
FEM-PrEP; Van Damme 2012^120^ | ≥25 years: RR, 0.91 (95% CI, 0.41 to 2.05); <25 years: RR, 0.97 (95% CI, 0.55 to 1.72); p=0.91 for interaction | NA | NR | NR
iPrEx; Grant 2010^100^ | <25 years: HR, 0.67 (95% CI, 0.40 to 1.14); ≥25 years: HR, 0.41 (95% CI, 0.24 to 0.87; p=0.36 for interaction | Transgender women: HR, 1.1 (95% CI, 0.5 to 2.7); Male (MSM): HR, 0.50 (95% CI, 0.34 to 0.75); p=0.09 for interaction | Non-Hispanic: HR, 0.48 (95% CI, 0.14 to 1.60); Hispanic: HR, 0.57 (95% CI, 0.37 to 0.89); p=0.79 for interaction | Unprotected receptive anal intercourse; Yes: HR, 0.42 (95% CI, 0.26 to 0.68); No: HR, 1.59 (95% CI, 0.66 to 3.84); p=0.01 for interaction
Partners PrEP; Baeten 2012^70^ | TDF vs. placebo; <25 years: HR, 0.28 (95% CI, 0.01 to 1.01); ≥25 years: HR, 0.34 (95% CI, 0.18 to 0.61); p=0.79 for interaction; TDF-FTC vs. placebo; <25 years: HR, 0.59 (95% CI, 0.21 to 1.61); ≥25 years: HR, 0.17 (95% CI, 0.07 to 0.37); p=0.06 for interaction | TDF vs. placebo; Female: HR, 0.29 (95% CI, 0.13 to 0.63); Male: HR, 0.37 (95% CI, 0.17 to 0.80); p=0.65 for interaction; TDF-FTC vs. placebo; Female: HR, 0.34 (95% CI, 0.16 to 0.72); Male: HR, 0.16 (95% CI, 0.06 to 0.46); p=0.24 for interaction | NR | TDF vs. placebo, unprotected sex with study partner; Yes: HR, 0.47 (95% CI, 0.25 to 0.89); No: HR, 0.13 (95% CI, 0.04 to 0.44); p=0.05 for interaction; TDF-FTC vs. placebo, unprotected sex with study partner; Yes: HR, 0.27 (95% CI, 0.12 to 0.58); No: HR, 0.22 (95% CI, 0.08 to 0.58); p=0.77 for interaction
TDF2; Thigpen 2012^119^ | NR | Female: RR, 0.49 (95% CI, 0.02 to 1.21); Male: RR, 0.20 (95% CI, 0.4 to 0.91); p=0.31 for interaction | NR | NR

Abbreviations: CI=confidence interval; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; HR=hazard ratio; iPrEx=Pre-Exposure Prophylaxis Initiative; MSM=men who have sex with men; NR=not reported; PrEP=pre-exposure prophylaxis; RR=relative risk; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study.

Figure 8 Meta-Analysis: HIV Infection Stratified by HIV Risk Category

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 8 is a forest plot of HIV infection stratified by HIV Risk Category with four subgroups. The risk ratio for 6 studies in the heterosexual men and women category is 0.54 (95% confidence interval 0.31 to 0.97) with an I-squared value of 82%. The risk ratio for 4 studies in the MSM or transgender women category is 0.23 (95% confidence interval 0.08 to 0.62) with an I-squared value of 64%. The risk ratio for 1 study in the mixed population category is 0.17 (95% confidence interval 0.01 to 4.03). The risk ratio for 1 study in the PWID category is 0.52 (95% confidence interval 0.29 to 0.92). The overall risk ratio for all studies is 0.44 (95% confidence interval 0.29 to 0.65) with an I-squared value of 72%.

Five trials performed within-study subgroup analyses of PrEP effectiveness (Table 4).^70,97,100,119,^ ^120^ Four trials^70,97,100,120^ found no clear differences in PrEP effectiveness in subgroups defined according to age, and three trials^70,97,119^ found no clear differences between males and females. A post-hoc analysis of the iPrEx trial^100^ found that PrEP was effective in men who have sex with men (hazard ratio [HR], 0.50 [95% CI, 0.34 to 0.75]) but not in transgender women (HR, 1.1 [95% CI, 0.5 to 2.7]), although the interaction was not statistically significant (p=0.09).^98^ No other trial compared how results for transgender women differed from other risk groups. Evidence on how effects of PrEP vary by race/ethnicity was limited to iPrEx, which found similar effectiveness in Hispanic and non-Hispanic persons.^100^ Among three trials conducted in the United States, Europe, or Canada, the proportion of participants who were white ranged from 73 to 91 percent.^52,78,85^

Data were limited regarding effects of risk behaviors on effectiveness of PrEP. One trial found PrEP was effective in transgender women and men who have sex with men who reported receptive anal intercourse (HR, 0.42 [95% CI, 0.26 to 0.68]) but not in those who did not report receptive anal intercourse (HR, 1.59 [95% CI, 0.66 to 3.84]; p=0.01 for interaction).^100^ One trial (Partners PrEP) found PrEP to be effective in men and women at risk of HIV infection through heterosexual contact regardless of whether they did or did not report sex without condoms.^70^ This trial also found both TDF and TDF-FTC associated with similar effectiveness when analyzed according to sexual risk behaviors and viral load (Appendix B Table 1).^115^ A trial of persons who inject drugs (the Bangkok Tenofovir Study) found no association between drug injection or needle sharing in the 12 weeks before enrollment and effectiveness of PrEP.^97^

### Mortality

When stratified according to patient population, pooled estimates for effects of PrEP versus placebo or no PrEP on mortality were similar (p=0.90 for interaction) in trials of women and men at increased risk of HIV infection via heterosexual contact (4 trials; RR, 0.71 [95% CI, 0.36 to 1.42]; I^2^=0%),^70,76,119,120^ men who have sex with men or transgender women (4 trials; RR, 0.87 [95% CI, 0.22 to 3.41]; I^2^=0%),^78,85,100,117^ and persons who inject drugs (1 trial; RR, 0.85 [95% CI, 0.58 to 1.23]) (Figure 9).^97^

Figure 9 Meta-Analysis: Mortality Stratified by HIV Risk Category

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; PWID=persons who inject drugs; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Study of Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 9 is a forest plot of mortality stratified by HIV risk category with three subgroups. The risk ratio for 4 studies in the heterosexual men and women category is 0.71 (95% confidence interval 0.36 to 1.42) with an I-squared value of 0%. The risk ratio for 4 studies in the MSM or transgender women category is 0.87 (95% confidence interval 0.22 to 3.41) with an I-squared value of 0%. The risk ratio for 1 study in the PWID category is 0.85 (95% confidence interval 0.58 to 1.23). The overall risk ratio for all studies is 0.82 (95% confidence interval 0.59 to 1.12) with an I-squared value of 0%.

## Key Question 1b How Do the Benefits of PrEP Differ by Dosing Strategy or Regimen?

### HIV Infection

Estimates of effectiveness of PrEP versus placebo or no PrEP on risk of HIV infection were very similar when analyses were stratified according to use of TDF (5 trials; RR, 0.49 [95% CI, 0.28 to 0.84]; I^2^=58%)^70,76,85,97,117^ or TDF-FTC (8 trials; RR, 0.44 [95% CI, 0.27 to 0.72]; I^2^=74%; p=0.79 for interaction) (Table 3; Figure 2).^52,53,70,76,78,100,119,120^ Among the trials that used intermittent or event-driven dosing, one trial^54^ reported no HIV events and one trial^53^ combined results for intermittent/event-driven and daily dosing of PrEP arms. The third trial (IPERGAY)^52^ found event-driven PrEP associated with a lower risk of HIV infection than placebo in men who have sex with men (RR, 0.14 [95% CI, 0.03 to 0.63]). Although the estimate was stronger than that among trials that used daily dosing (9 trials; RR, 0.47 [95% CI, 0.32 to 0.71]; I^2^=75%) (Table 3; Figure 10),^70,76,78,85,97,100,117,119,120^ the interaction was not statistically significant (p=0.13). The estimate from IPERGAY was similar to the pooled estimate for trials of daily dosing that reported high adherence (5 trials; RR, 0.28 [95% CI, 0.20 to 0.41]).^53,70,78,85,^ ^119^ In IPERGAY, men randomized to PrEP took an average of about four doses of PrEP per week (15 doses per month) and had an average of 10 episodes of sexual intercourse per month.

Figure 10 Meta-Analysis: HIV Infection Stratified by Dosing Strategy

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 10 is a forest plot of HIV infection by dosing strategy with two subgroups. The risk ratio for 9 studies in the daily dosing subgroup is 0.47 (95% confidence interval 0.32 to 0.71) with an I-squared value of 75%. The risk ratio for 1 study in the intermittent/on-demand dosing subgroup is 0.14 (95% confidence interval 0.03 to 0.63). The overall risk ratio for all studies is 0.44 (95% confidence interval 0.29 to 0.67) with an I-squared value of 75%.

The open-label HIV Prevention Trials Network 067/Alternative Dosing to Augment PrEP pill Taking (HPTN 067/ADAPT) trial compared daily with intermittent (twice a week, plus a dose after sex) or event-driven (dosing before and after sex) PrEP with TDF-FTC in men who have sex with men or transgender women^123^ (n=357) and heterosexual African women^122^ (n=178) (Appendix B Table 1), but was not powered to evaluate effects of dosing on HIV infection risk (five total postrandomization cases across all risk groups and dosing regimens).

Data on the effects of use of postexposure prophylaxis on efficacy of PrEP was limited. In the open-label Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred (PROUD) trial, PrEP was more effective than no PrEP at reducing risk of HIV infection in men who have sex with men (RR, 0.14 [95% CI, 0.03 to 0.63]), despite much less frequent use of postexposure prophylaxis (4.4% vs. 32%) and an increased rate of receptive anal sex without a condom with 10 or more partners (21% vs. 12%) in persons randomized to PrEP.^78^ No other trial reported the proportion of patients who used postexposure prophylaxis, although three trials described postexposure prophylaxis as an HIV prevention intervention offered to all patients;^52,70,100^ PrEP was effective in all three trials (RR, 0.14 to 0.53).

### Mortality

Estimates of effectiveness of PrEP versus placebo or no PrEP on mortality were similar when trials were stratified according to whether they used TDF or TDF-FTC (p=0.65 for interaction) (Figure 7).

## Key Question 2 What Is the Diagnostic Accuracy of Provider or Patient Risk Assessment Tools in Identifying Persons at Increased Risk of HIV Acquisition Who Are Candidates for PrEP?

### Summary

- Three studies of different instruments for predicting incident HIV infection in men who have sex with men reported moderate discrimination (area under the receiver operating characteristic curve [AUROC], 0.66 to 0.72); a study of a fourth instrument reported better goodness of fit than with two instruments evaluated in other studies (AUROC not reported).^129–132^ Two studies found poorer discrimination of risk prediction instruments in black men who have sex with men (AUROC, 0.49 to 0.63).^134,135^ All studies had methodological limitations and all prediction instruments require further validation.
- One study that retrospectively applied a 10-item instrument for predicting incident HIV infection in persons who inject drugs reported an AUROC of 0.72, but had methodological limitations and required validation.^133^
- No study evaluated a U.S.-applicable instrument for predicting incident HIV infection in women or men at risk of HIV infection via heterosexual contact.
- No study evaluated an instrument for predicting incident HIV infection in persons not preidentified as belonging to an HIV risk category.

### Evidence

Seven studies evaluated instruments developed and validated in U.S. cohorts for predicting incident HIV infection^129–135^ (Appendix B Tables 5 and 6). Six studies evaluated risk prediction instruments in men who have sex with men^129–132,134,135^ and one study in persons who inject drugs.^133^ Samples sizes (including development and validation cohorts) ranged from 300 to 9,481 patients (total N=32,311). For men who have sex with men, studies evaluated the predictive utility of four different instruments (number of criteria ranged from 4 to 10), as well as CDC criteria for PrEP and recommendations from the TDF-FTC package insert. In the cohorts used to develop risk assessment instruments for men who have sex with men, black participants comprised 6 and 7.8 percent of the population in two studies;^129,130^ one study reported that 23 percent of the population was nonwhite, Asian, or Pacific Islander;^131^ and one study reported a nonwhite proportion of 14 percent.^132^ Two studies evaluated the performance of previously developed risk assessment in men who have sex with men cohorts in which 46 percent^135^ or all participants^134^ were black. The instrument for predicting risk in persons who inject drugs had seven items and was developed using a cohort of primarily (93%) black participants. In the cohorts used to develop and validate the risk prediction instruments, the incidence of HIV infection ranged from 2.4 to 11 percent in men who have sex with men; HIV incidence was 11 percent in the study in persons who inject drugs.

All studies had methodological shortcomings (Appendix B Table 7). In all studies, risk assessment instruments were applied to previously collected data; in some cases, the criteria had to be modified based on the data available. In six studies, new HIV infections were identified in the study sample by repeat testing using a longitudinal (cohort) design. In the other study, which evaluated a risk prediction instrument for men who have sex with men, new HIV infections were identified based on a single test for markers for acute or early HIV infection.^130^ Three studies used cohorts that included persons who had HIV testing before the year 2000.^131–133^ In five studies, the predictive utility of risk assessment instruments was tested (validated) in cohorts independent from the one used to develop the instrument.^130–132,134,135^ In two studies, accuracy was only reported for the cohort used to develop the instrument.^129,133^ Cutoffs to define a positive test were predefined in two studies.^134,135^

Although three studies evaluated instruments for predicting risk of incident HIV infection in heterosexual women or men, including pregnant and postpartum women, all were developed and validated in African cohorts and have not been tested in the United States or U.S.-applicable settings.^136–138^ No study evaluated instruments for predicting risk of HIV infection in persons not preidentified as having an HIV risk factor (e.g., men who have sex with men, injection drug use, or high-risk heterosexual behaviors). One study evaluated patients attending a clinic for lesbian, gay, bisexual, and transgender persons^129^ and one study evaluated patients attending an STI clinic;^131^ the other studies evaluated persons enrolled in research studies.

### Men Who Have Sex With Men

Six studies evaluated risk prediction instruments in men who have sex with men.^129–132,134,135^ Items assessed in all of the risk instruments were presence of STIs, sex without a condom (particularly receptive anal sex), and number of sexual partners (Appendix B Tables 5 and 6). Age, race/ethnicity, and illicit drug use were included in some instruments but not others. None of the instruments include an item on plasma HIV viral load or use of ART in an HIV-infected sexual partner.

For three instruments, discrimination was similar, with AUROCs in the original validation cohorts ranging from 0.66 to 0.72.^130–132^ A fourth study^129^ found that a 10-item instrument developed using data from the Los Angeles Lesbian Gay Bisexual and Transgender (LGBT) Center was associated with better goodness of fit based on the Akaike Information Criterion score than instruments developed in two other studies^131,132^ or criteria from the 2014 CDC guidelines for offering PrEP in men who have sex with men.^60^ However, the instrument was not validated using a separate (nondevelopment) sample. In addition, some of the items used in the other risk prediction instruments were not identical to variables available in the Los Angeles LGBT Center database, necessitating use of alternative variables for goodness of fit testing. Two studies reported poorer discrimination of various risk assessments instruments in black men who have sex with men, with AUROCs ranging from 0.49 to 0.63.^134,135^

The six-item Assessing the Risk of Contracting HIV in Men Who Have Sex With Men (ARCH-MSM) instrument was included in the CDC PrEP guideline as a potential tool to identify eligible candidates.^132^ ARCH-MSM was developed using a cohort of patients enrolled in an (ineffective) HIV vaccine trial and validated in a cohort of patients enrolled in an (ineffective) behavioral intervention trial. Based on a suggested post-hoc cutoff of 10 or greater (range, 0 to 48), 62.4 percent of men in the validation cohort met the threshold, with a sensitivity for future HIV infection of 81.2 percent and specificity of 37.7 percent, and an AUROC of 0.72. The cohorts used to validate and develop the ARCH-MSM instrument were older (1998–1999 and 1999–2001, respectively) and had a high prevalence of inhaled nitrite and amphetamine use, both of which are included as items in the instrument.

A four-item instrument by Menza et al (score range, 0 to 19) was validated using the same validation cohort as ARCH-MSM.^131^ A cutoff score of 3 or greater with this instrument provided comparable sensitivity (76%) and specificity (43%) to ARCH-MSM at a cutoff of 10 or greater, with 64 percent of the sample meeting this threshold. Discrimination was slightly lower with this instrument (0.66 [95% CI, 0.61 to 0.71]) than with ARCH-MSM (0.72 [CI not reported]). Methamphetamine and inhaled nitrite use were included as a single item in the Menza instrument.

The four-item San Diego Early Test (SDET) (score range, 0 to 10 points) was developed using a more contemporary (2008–2014) cohort.^130^ As noted earlier, HIV incidence was estimated based on markers for acute or early HIV infection on a single test. A cutoff score of 1 or greater resulted in a sensitivity (73%) and specificity (48%) most comparable to ARCH-MSM at a cutoff of 10 or greater. The proportion of the sample meeting this threshold was not reported. Discrimination of the SDET score was very similar to ARCH-MSM (0.70 [95% CI, 0.62 to 0.78] vs. 0.72 [CI not reported]). The SDET does not include items on drug use.

A 10-item instrument by Beymer et al was also developed using a more contemporary cohort (Los Angeles LGBT Center 2009–2014).^129^ The instrument includes items on race/ethnicity, partner age and race/ethnicity, and intimate partner violence, as well as illicit drug use. As noted above, a methodological limitation is that this instrument has only been evaluated in the cohort used to develop the instrument. In addition, methods for scoring the instrument (e.g., points assigned for individual items) were unclear. Using a cutoff score of 5 or greater, 51 percent of the cohort met this threshold, with a sensitivity of 74.6 percent and specificity of 50.2 percent. The AUROC was not reported. Goodness of fit testing based on the Akaike Information Criterion and Schwarz Bayesian Criteria was slightly better with this instrument than with the ARCH-MSM and similar to the Menza instrument, but this finding is difficult to interpret because goodness of fit was evaluated using data from the same cohort used to develop this instrument, and the other instruments included items that were not an exact match with data available in this database.

The 2014 CDC guideline includes recommended indications for PrEP in men who have sex with men (any anal sex without condoms in past 6 months, any STI diagnosed or reported in past 6 months, or ongoing sexual relationship with an HIV-infected partner).^60^ In the study by Beymer et al, goodness of fit was slightly better with the Los Angeles LGBT Center instrument than the CDC criteria.^129^

Two studies found that risk prediction instruments performed more poorly in black men who have sex with men. In one study of men who have sex with men, the AUROC for the ARCH-MSM, SDET, and Menza instruments ranged from 0.51 to 0.62 overall, from 0.49 to 0.63 in the subgroup of black men who have sex with men, and from 0.60 to 0.67 in white men who have sex with men.^135^ In the other study, the AUROC for the ARCH-MSM was 0.57 in black men who have sex with men, and similar using criteria derived from the CDC recommendations (AUROC, 0.51) or the PrEP package insert (AUROC, 0.54).^134^

### Persons Who Inject Drugs

The seven-item Assessing the Risk of Contracting HIV in Injection Drug Users (ARCH-IDUs) instrument (score range, 0 to 100 points) was developed using a cohort (1988–2008) of current and former persons who inject drugs in Baltimore.^133^ The instrument includes items on age, enrollment in a methadone maintenance program, and drug use behaviors. In the sample used to develop the instrument, the sensitivity was 86 percent and specificity was 42 percent at a cutoff of 46 or greater, with 58 percent of the cohort meeting this threshold. The AUROC was 0.72 (CI not reported). ARCH-IDU has not been evaluated in a separate validation cohort.

The 2014 CDC guideline includes recommended indications for PrEP in persons who inject drugs (any sharing of injection or drug preparation equipment in past 6 months, been in a methadone or buprenorphine treatment program in past 6 months, or risk of sexual acquisition); we did not identify any formal assessment of the CDC criteria.^60^

### Men and Women at Increased Risk of HIV Infection Via Heterosexual Contact

Three studies evaluated instruments for predicting risk of HIV infection in men and women at increased risk of HIV infection via heterosexual contact but did not meet inclusion criteria because they were developed using data from African cohorts. One instrument focused on serodiscordant couples,^137^ one in women,^138^ and one in pregnant women.^136^ The 2014 CDC guideline includes recommended indications for PrEP in men and women at increased risk of HIV infection via heterosexual contact (men who have sex with both women and men, infrequent use of condoms during sex with one or more partners of unknown HIV status who are known to be at substantial risk of HIV infection, or being in an ongoing sexual relationship with an HIV-infected partner), but we did not identify any formal assessment of these criteria.^60^

## Key Question 3 What Are Rates of Adherence to PrEP in U.S. Primary Care–Applicable Settings?

### Summary

- Three observational studies of U.S. men who have sex with men (mean age, 34 to 36 years) found adherence to PrEP of 66 to 90 percent, based on a tenofovir-diphosphate (TFV-DP) level of 700 fmol/punch or greater on dried blood spot samples (consistent with ≥4 doses/week).^81,126,127^
- Two observational studies of younger U.S. men who have sex with men (mean age, 16 to 20 years) found adherence to PrEP of approximately 50 percent at 12 weeks and 22 to 34 percent at 48 weeks, based on a TFV-DP level of 700 fmol/punch or greater on dried blood spot samples (consistent with ≥4 doses/week).^92,93^ The proportion with a TFV-DP level of 350 fmol/punch or greater (consistent with ≥2 doses/week) was 49 and 26 percent at 48 weeks.
- An RCT of U.S. men who have sex with men found adherence was higher with daily (48%) than intermittent (31%) or event-driven (17%) PrEP during weeks in which sex was reported, based on a TFV-DP level of 326 fmol/punch or greater on dried blood spot samples (consistent with ≥2 doses/week).^123^
- In two studies of U.S. men who have sex with men, adherence based on self-report was highly correlated with adherence based on drug levels on dried blood spot samples.^85,124^
- No study evaluated rates of adherence to PrEP in U.S. persons who inject drugs or women and men at increased risk of HIV infection via heterosexual contact.

### Evidence

Ten studies evaluated rates of adherence to PrEP in U.S. primary care and primary care–applicable settings (Table 5).^81,85,92–94,123,124,126–128^ Three studies were RCTs (Appendix B Tables 1-3)^85,94,^ ^123^ and seven were observational studies (Appendix B Tables 8–10).^81,92,93,124,126–128^ Six studies assessed adherence based on drug levels from dried blood spot samples,^81,92,93,123,126,127^ one used plasma drug levels,^94^ three used self-report,^81,124,127^ two used a medication event monitoring system,^85,123^ one used pill counts,^85^ and one used prescription refill data.^128^ In the RCTs, the number of participants randomized to PrEP ranged from 20 to 373 (total N=572),^85,94,123^ and in the observational studies, the number of participants on PrEP ranged from 35 to 1,086 (total N=2,605).^81,92–94,124,126,127^ Two RCTs evaluated daily TDF-FTC in men who have sex with men^85,94^ and one RCT evaluated daily, intermittent, or event-driven TDF-FTC in men who have sex with men (97%) and transgender women (1.1%).^123^ The observational studies all evaluated TDF-FTC. The largest observational study (n=1,086) did not report HIV risk behaviors or indications for PrEP.^128^ In the other observational studies, all or nearly all (≥89%) of the population was men who have sex with men. One large (n=557) observational study, the Demo Project, enrolled men who have sex with men (98%) and transgender women (1.4%);^81^ two smaller studies enrolled a small proportion of heterosexual men and women.^124,127^ Two observational studies reported injection drug use in 1.6 to 3 percent of participants,^81,126^ one reported no patients with a history of injection drug use,^127^ and the other studies did not report injection drug use status. The duration of PrEP use ranged from 6 months to 2 years. One RCT was rated good quality and the other fair quality.^85,94^ Methodological shortcomings in the fair-quality RCT included unclear randomization and allocation concealment methods; in addition, it was unclear if outcomes assessors were blinded.^93,94^ The observational studies were all rated fair quality. Methodological shortcomings included unclear enrollment of a consecutive or random sample, failure to describe blinding of data analysts, and high attrition (Appendix Tables 4 and 11).^81,92,93,124,126,127^

Table 5 Rates of Adherence to PrEP in U.S. Primary Care Settings

Study, year | Study design | N | Population | Years PrEP administered | Drug levels | Self report | Other method of assessing adherence
Chan, 2016^124^ | Treatment series | 267 | MSM (89%), MSF (5.2%), FSM (6.7%); Mean age: 32 years; White: 44%; Black/African American: 41%; Asian: 2.8%; Other: 13%; Hispanic or Latino: 12% | 2014 | NR | ≥4 pills in last week: 92% (106/115) at 3 months, 92% (73/79) at 6 months 100% adherence in last week: 72% (83/115) at 3 months, 79% (64/81) at 6 months 100% adherence in last month: 49% (56/115) at 3 months, 56% (44/79) at 6 months | NR
CDC Safety Study; Grohskopf, 2013^85^ | RCT | 373 | MSM; Median age: 38 years; White: 80%; African American: 11%; Asian/Pacific Islander: 5.0%; Other race: 5.0%; Hispanic ethnicity: 8.0% | 2005–2007 | NR | NR | Medication event monitoring system: 79% (range, 60% to 92%); Pill count: 93% (range, 81% to 98%)
Grant 2018^123^ | RCT | 179 | MSM (97%), transgender women (2%), gender queer (1%); Mean age NR; 30% ages 18–24 years; 18% ages 25–29 years; 21% ages 30–39 years; 32% age ≥40 years; 70% Black; 13% white; 3% Asian; 3% Native American; 21% other; 25% Hispanic (participants could self-identify in more than one category) | 2012–2014 | TFV-DP ≥326 fmol/punch (consistent with ≥2 doses/week) on visits when sex was reported in the prior week, daily PrEP: 48%; time-driven PrEP: 31%; event-driven PrEP 17% | NR | Medication event monitoring system, daily PrEP: 62%; time-driven PrEP: 47%; event-driven PrEP: 41%; Proportion with ≥90% adherence, daily PrEP: 25%; time-based PrEP: 0%; event-driven PrEP: 2%
Hosek, 2017^93^; Project PrEPare, ATN 110 | Treatment series | 200 | MSM; Mean age: 20 years; Latino: 26%; Non-Latino black/African American: 66%; Non-Latino white: 29%; Non-Latino other race: 5% | 2013 | Dried blood spot samples with TFV-DP level ≥700 fmol/punch; Week 4: 56%; Week 8: 58%; Week 12: 53%; Week 24: 47%; Week 36: 41%; Week 48: 34%; Any TFV-DP level detected: 92% at week 4, 69% at week 48; TFV-DP level ≥350 fmol/punch; Week 4: 78%; Week 8: 77%; Week 12: 72%; Week 24: 57%; week 36: 58%; Week 48: 49% | NR | NR
Hosek, 2017^92^; Project PrEPare, ATN 113 | Treatment series | 72 | MSM; Mean age: 16 years; White: 14%; Black/African American: 29%; White Hispanic: 21%; Other race/ethnicity: 33% | 2013–2014 | Dried blood spot samples with TFV-DP level ≥700 fmol/punch; Week 4: 54%; Week 8: 47%; Week 12: 49%; Week 24: 28%; Week 36: 17%; Week 48: 22%; TFV-DP level ≥350 fmol/punch; Week 4: 69%; Week 8: 66%; Week 12: 59%; Week 24: 36%; Week 36: 28%; Week 48: 26% | NR | NR
Hosek, 2013^94^; Project PrEPare, ATN 082 | Double-blind medication pilot RCT with third nonmedication control group | 58 | MSM, ages 18–22 years, at least 2 episodes of unprotected anal sex in past 12 months; Male: 100%; Black: 50% vs. 63% vs. 47%; Other/mixed race: 40% vs. 32% vs. 42%; Hispanic ethnicity: 35% vs. 32% vs. 53%; Unprotected anal sex with a man in past 30 days: 45% vs. 37% vs. 42% | NR | TDF-FTC arm only Proportion of patients with detectable plasma TDF:; Week 4: 63%; Week 24: 20% | TDF-FTC arm only Mean adherence: 62% (range, 43% to 83%) | NR
Landovitz, 2017^126^; PATH-PrEP | Treatment series | 301 | MSM and transgender women; Median age: 36 years; White: 50%; Hispanic: 28%; Black: 11%; Asian/Pacific Islander:6%; Other race: 5% | 2013–2016 | Dried bloodspot samples with TFV-DP ≥700 fmol/punch:; Week 4: 83.1%; Week 12: 83.4%; Week 24: 75.7%; Week 36: 71.6%; Week 48: 65.5% | NR | NR
Liu, 2016^81^; The Demo Project | Treatment series | 557 | MSM (98%) and transgender women (1.4%); Mean age: 35 years; White: 48%; Latino: 34%; Black: 7.2%; Asian: 4.7% | 2012–2015 | Dried blood spot samples with TFV-DP level ≥700 fmol/punch; Week 4: 86%; Week 12: 85%; Week 24: 82%; Week 36: 85%; Week 48: 80%; ≥2 dried blood spot samples meeting threshold: 62.5% (170/272); TFV-DP level ≥350 fmol/punch, ≥2 dried blood spot samples meeting threshold: 97% (264/272) | Adherence self-rated “very good” or “excellent” at 87% (1,959/2,242) of visits | Pill count: 81.6%; Medication ratio (number of dispensed pills/the number of days between visits): 85.9%
Montgomery, 2016^127^ | Treatment series | 50 | MSM (95%); Mean age: 34 years; Non-Hispanic white: 58%; Non-Hispanic black: 26%; Hispanic or Latino: 26%; Other race: 8% | 2013–2014 | Dried blood spot samples with TFV-DP level ≥700 fmol/punch at mean of 4.4 months: 90% (19/21); TFV-DP level ≥350 fmol/punch: 95% (20/21) | Mean proportion of doses taken in last 7 days, at 3 months: 89% (6.2/7); Mean proportion of doses taken in last 30 days, at 6 months: 89% (26.8/30) | NR
Van Epps 2018^128^ | Retrospective cohort | 1,086 | Indication for PrEP NR; Mean age NR; 39% age; <35 years; 35% ages; 35–49 years; 21% ages; 50–64 years; 6% ages; 65–79 years; 4% female; 22% Black; 67% white; 6% other | 2012–2016 | NR | NR | Median proportion of days/year covered by PrEP prescription: 74% (IQR, 40% to 92%)

Abbreviations: CDC=Centers for Disease Control and Prevention; FSM=females who have sex with males; IQR=interquartile range; MSM=men who have sex with men; MSF=men who have sex with females; NR=not reported; PrEP=pre-exposure prophylaxis; RCT=randomized, controlled trial; TVF-DP=tenofovir disoproxil fumarate-diphosphate; TDF-FTC=tenofovir disoproxil fumarate-emtricitabine; U.S.=United States.

Six studies assessed PrEP drug levels based on intracellular drug concentrations of TFV-DP, the active moiety of tenofovir, in dried blood spot samples, which reflect longer-term cumulative drug exposure than tenofovir plasma levels.^81,92,93,123,126,127^ In five observational studies of primarily men who have sex with men, based on presence of TFV-DP levels of 700 fmol/punch or greater (consistent with an average of ≥4 pills/week over the last 1 to 2 months, associated with an estimated reduction in risk of HIV acquisition of >95%^139–141^ [see Key Question 4]), adherence rates ranged from 22 to more than 90 percent.^81,92,93,126,127^ One study (n=557) found that the proportion of patients meeting the adherence threshold ranged from 80 to 86 percent from week 4 to 48 (proportion meeting the adherence threshold on all samples, 62 percent),^81^ and another study (n=301) found that adherence was 83 percent at week 4 and 66 percent at week 48.^126^ A smaller study (n=50) found that 90 percent (19/21) of patients met the drug level adherence threshold at a mean PrEP duration of 4.4 months.^127^ In two studies, adherence rates based on self-report were similar to rates based on dried blood spot testing.^81,127^ The adherence rates in these studies were higher than in the iPrEx open-label extension study (52% met the drug level adherence threshold at 4 weeks), which enrolled patients from the United States (<20% of study population), South Africa, Thailand, and South America.^142^

Two of the five observational studies (n=200 and n=72) that assessed adherence based on dried blood spot sample testing reported lower adherence rates.^92,93^ Both focused on younger men who have sex with men (mean ages 20 and 16 years) than in the studies described above (mean age >30 years). The proportion of patients meeting the adherence threshold for 4 or more doses/week was around 50 percent at week 12, decreasing to 34 and 22 percent at week 48. The proportion of patients with levels of 350 fmol/punch or greater (consistent with ≥2 doses/week) was 72 and 59 percent at week 12, decreasing to 49 and 26 percent at week 48. Other measures of adherence (e.g., self-report, pill counts, or medication electronic monitoring systems) were not reported.

An RCT of men who have sex with men and transgender women enrolled at a U.S. site compared adherence with daily, intermittent, and event-driven PrEP, based on TFV-DP levels of 326 fmol/punch or greater (consistent with ≥2 doses/week; 2 doses per week associated with an estimated reduction in risk of HIV acquisition of 76%^141^ [see Key Question 4]^123^). During weeks in which sex was reported, adherence was higher for daily (49%) than intermittent (31%) or event-driven (17%) PrEP. Adherence was also higher for daily PrEP than intermittent or event-driven PrEP based on event monitoring system data (65% vs. 46% vs. 41% of tablets used/recommended, respectively).

An RCT of young men who have sex with men (n=20 randomized to PrEP) evaluated adherence based on plasma TFV levels.^94^ Plasma levels measure free TFV and reflect more recent dosing (detectability consistent with dosing within the last week) than the intracellular levels measured with dried blood spot sample testing. Results were consistent with the observational studies of young men who have sex with men, with tenofovir detected in 63 percent of men randomized to PrEP at week 4, decreasing to 20 percent at week 24. Patients in this trial also received a group-based behavioral HIV prevention intervention.

For comparative purposes, the proportion of patients with detectable plasma TFV levels was approximately 80 percent in the Partners PrEP trial (persons at risk via heterosexual contact in Africa)^99^ and 86 percent in the IPERGAY trial (men who have sex with men in Europe and Canada).^52^ Both trials found PrEP to be effective. In Partners PrEP, the proportion of patients with plasma TDF levels greater than 40 ng/mL (consistent with dosing within the last 2 days) was about 70 percent,^99^ and in the IPERGAY (event-driven dosing) trial,^52^ TDF or FTC was detectable in plasma in 82 to 86 percent of participants. Although another trial (iPrEx) measured TFV-DP levels using dried blood spot samples in a subgroup of patients, the proportion meeting specified adherence thresholds was unclear.^141^

Three U.S.-based studies reported adherence using methods other than drug levels.^85,124,128^ A U.S.-based RCT of men who have sex with men (n=373)^85^ reported adherence based on medication event monitoring system data of 79 percent of doses taken and based on a pill count of 93 percent. A large observational study (n=1,086, indication for PrEP not reported), which assessed adherence based on prescription refill data, found the median proportion of days covered in the first year was 0.74 (interquartile range, 0.40 to 0.92).^128^ An observational study of primarily men who have sex with men (n=267)^124^ found that 92 percent of patients reported taking four or more pills in the last week at 3 and 6 months. Some U.S. and non-U.S. RCTs have shown lower levels of adherence based on drug levels than by self-report or pill counts,^76,94,95,143,^ ^144^ although other RCTs have shown greater concordance.^78^ Some discrepancies between drug levels and self-reported adherence or pill counts could be related to use of financial incentives for trial participation (patients in such a trial might have concerns about trial dismissal and loss of financial compensation as a result of low adherence) or social desirability bias (patients might overreport adherence to avoid disappointing study personnel with whom they have developed relationships).^145^

No study evaluated adherence to PrEP in U.S. persons who inject drugs or women and men at increased risk of HIV infection via heterosexual contact.

## Key Question 4 What Is the Association Between Adherence to PrEP and Effectiveness for Preventing HIV Acquisition?

### Summary

- Three randomized trials that performed subgroup analyses based on level of adherence found higher adherence to PrEP based on pill counts or daily diaries associated with greater effectiveness compared with placebo for reducing risk of HIV infection.
- Four of five randomized trials found that among participants randomized to PrEP, presence of tenofovir in plasma samples was associated with decreased likelihood of HIV infection compared with no detectable tenofovir (odds ratio [OR] ranged from 0.10 to 0.54).^70,76,97,99,109,119,120^
- One RCT and three observational studies found that all seroconverters on PrEP had undetectable levels of TDF or plasma levels consistent with low adherence, but the number of seroconverters in each study ranged from 1 to 4.

### Evidence

This section focuses on within-study analyses on effects of adherence; analyses based on between-study estimates of adherence are reported in Key Question 1. Seven randomized trials^52,^ ^70,76,95,97,99,100,109,117,120^ (Appendix B Tables 1-3) and five observational studies^81,92,93,125,126^ (Appendix B Tables 8–10) evaluated the association between degree of adherence to PrEP using oral TDF or TDF-FTC and effectiveness for preventing HIV infection (Table 6). The number of patients on PrEP in the RCTs ranged from 199 to 3,136 (total N=9,473) and from 78 to 1,345 (total N=2,006) in the observational studies. Three of the observational studies were conducted in the United States;^81,92,93,146^ the other studies were conducted in Asia or Africa or were international studies. One RCT focused on persons who inject drugs,^108^ four RCTs on women and men at increased risk via heterosexual contact,^70,76,119,120^ and three on men who have sex with men and transgender women.^52,78,100^

Table 6 Association Between Adherence to PrEP and Effectiveness for Preventing HIV Acquisition

Study name; Author, year; Study design | Number of patients on PrEP | Overall effectiveness, PrEP vs. placebo | Effectiveness, PrEP vs. placebo, according to level of adherence | On PrEP, seroconverters vs. non-seroconverters, according to PrEP drug levels
Bangkok Tenofovir Study; Choopanya, 2013^97,*^ and Martin 2015^109^; RCT | 1,204 | RR, 0.52 (95% CI, 0.29 to 0.92) | "Adherent" (drug taken 71% of days and no more than 2 consecutive days missed, based on daily diary): HR, 0.44 (95% CI, 0.14 to 1.19); ≥60% adherence: HR, 0.51; ≥75% adherence: HR, 0.42; ≥97.5% adherence: HR, 0.16 | Quantifiable tenofovir plasma concentration: 39% (5/13) of cases and 67% (93/138) of controls; OR, 0.30 (95% CI, 0.09 to 0.98)
FEM-PrEP; Van Damme, 2012^120,*^ and Agot 2015^95^; RCT | 1,062 | HR, 0.94 (95% CI, 0.59 to 1.52) | NR | Plasma TDF >10 ng/mL: 15% (4/27) of cases and 24% (19/78) of controls; OR, 0.54 (95% CI, 0.17 to 1.76)
IPERGAY; Molina 2015^52^; RCT | 199 | RR, 0.14 (95% CI, 0.03 to 0.63) | NR | Study drugs not detected in plasma of 2 seroconverters
iPrEx; Grant 2010^100,*^; RCT | 1,251 | HR, 0.53 (95% CI, 0.36 to 0.78) | ≥50% pill use: HR, 0.50 (95% CI, 0.30 to 0.82); <50% pill use: HR, 0.68 (95% CI, 0.33 to 1.41); p=0.48 for interaction; ≥90% pill use: HR, 0.27 (95% CI, 0.12 to 0.59); <90% pill use: HR, 0.79 (95% CI, 0.48 to 1.31); p=0.02 for interaction | NR
Partners PrEP; Baeten 2012a^70,*^ and Donnell 2014^99^; RCT | 3,136 | RR, 0.29 (95% CI, 0.19 to 0.45) | >80% pill count coverage: OR, 0.08 (95% CI, 0.04 to 0.19) | Tenofovir >0.3 ng/mL in plasma: 41% (9/29) of cases vs. 83% (772/945 samples) of controls; OR, 0.10 (95% CI, 0.05 to 0.23); Tenofovir >10 ng/mL in plasma: 41% (9/29) of cases vs. 79% (730/945 samples) of controls; OR, 0.13 (95% CI, 0.06 to 0.30); Tenofovir >40 ng/mL in plasma: 24% (6/29) of cases vs. 72% (670/945 samples) of controls; OR, 0.11 (95% CI, 0.04 to 0.27); Tenofovir detected in plasma: 41% (9/29) of cases vs. 83% (772/945) of controls; OR, 0.10 (95% CI, 0.05 to 0.23)
TDF2; Thigpen, 2012^119,*^; RCT | 611 | RR, 0.39 (95% CI, 0.19 to 0.81) | NR | Detectable tenofovir plasma level: 50% (2/4) of cases vs. 80% (55/69) of controls; OR, 0.25 (95% CI, 0.03 to 1.97); Detectable FTC plasma level: 50% (2/4) of cases vs. 81% (56/69) of controls; OR, 0.23 (95% CI, 0.03 to 1.80)
VOICE; Marrazzo 2015^76,*^; RCT | 2,010 | RR, 0.87 (95% CI, 0.61 to 1.25) for TDF and RR, 1.02 (95% CI, 0.72 to 1.44) for TDF- FTC | NR | Tenofovir ever detected in plasma; TDF: 26% (14/54) of cases and 44% (68/156) of controls; aRR, 0.55 (95% CI, 0.26 to 1.14); TDF-FTC: 39% (24/61) of cases and 52% (77/148) of controls; aRR, 0.83 (95% CI, 0.39 to 1.76)
Hosek, 2017^93^; Project PrEPare, ATN 110; Observational | 200 | -- | NR | TDF plasma level not detectable in 4 seroconverters
Hosek 2017 ^92^; Project PrEPare, ATN 113; Observational | 78 | -- | NR | TDF plasma levels consistent with <2 doses of PrEP/week in 3 seroconverters
iPrEx-OLE; Grant, 2014^125^; Observational | 1,345 | -- | NR | TDF level quantifiable on dried blood spot testing: HR, 0.80 (95% CI, 0.38 to 1.67); <350 fmol/punch (~<2 tablets/week): HR, 0.56 (95% CI, 0.23 to 1.31); 350–699 fmol/punch (~2 to 3 tablets/week): HR, 0.16 (95% CI, 0.01 to 0.79); 700–1,249 fmol/punch (~4 to 6 tablets/week): HR, 0.00 (95% CI, 0.00 to 0.21)
PATH-PrEP; Landovitz, 2017^126^; Observational | 278 | -- | NR | TDF plasma level consistent with <2 doses of PrEP/week in 1 seroconverter
U.S. PrEP Demonstration Project; Liu, 2016^81^ and Cohen, 2015^146^; Observational | 383 | -- | NR | TDF plasma levels consistent with poor adherence in 2 seroconverters

* Main study publication.

Abbreviations: aRR=adjusted relative risk; CI=confidence interval; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; HR=hazard ratio; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; NR=not reported; OR=odds ratio; PrEP=pre-exposure prophylaxis; RCT=randomized, controlled trial; RR=relative risk; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Three RCTs that performed subgroup analyses based on level of adherence found higher adherence to PrEP based on pill counts or daily diaries associated with greater effectiveness compared with placebo for reducing risk of HIV infection (Table 6).^70,97,99,100,109^ All of the trials evaluated daily dosing. A trial of persons who inject drugs (the Bangkok Tenofovir Study), in which patients could choose between daily directly observed therapy or monthly visits without directly observed therapy, found an HR of 0.51 in patients with 60 percent or greater adherence and an HR of 0.16 in those with 97.5 percent or greater adherence.^97,109^ Similarly, a trial of men who have sex with men and transgender women (iPrEx) found greater effectiveness at 90 percent or greater adherence based on pill counts (HR, 0.27 [95% CI, 0.12 to 0.59]) than with 50 percent or greater adherence (HR, 0.50 [95% CI, 0.30 to 0.82]).^100^ There was a statistically significant interaction in iPrEx when patients were stratified according to greater or less than 90 percent pill use (HR, 0.27 [95% CI, 0.12 to 0.59] vs. HR, 0.79 [95% CI, 0.48 to 1.31]; p=0.02 for interaction). A third trial of heterosexual men and women (Partners PrEP) found adherence greater than 80 percent based on pill count associated with an OR for prevention of HIV infection of 0.08 (95% CI, 0.04 to 0.19).^70^

Five RCTs evaluated the association between plasma tenofovir levels among participants randomized to PrEP and likelihood of HIV seroconversion (Table 6).^70,76,97,99,109,119,120^ All of the trials evaluated daily dosing. In four trials, higher TDF plasma levels were associated with decreased likelihood of HIV infection (ORs ranged from 0.10 to 0.54).^70,97,99,109,119,120^ One of the trials was the FEM-PrEP trial, which failed to demonstrate a benefit overall from PrEP versus placebo in heterosexual women (HR, 0.94 [95% CI, 0.59 to 1.52]).^120^ In this study, having a plasma TDF concentration greater than 10 ng/mL was associated with decreased risk of seroconversion (OR, 0.54 [95% CI, 0.17 to 1.76]). The fifth trial (VOICE) also failed to demonstrate an effect from PrEP in heterosexual women (RR, 0.87 [95% CI, 0.61 to 1.25] for TDF and RR, 1.02 [95% CI, 0.72 to 1.44] for TDF-FTC).^76^ Unlike FEM-PrEP and the other three studies, it found no clear association between ever having a detectable TDF plasma level and risk of seroconversion (adjusted RR, 0.55 [95% CI, 0.26 to 1.14] for TDF and adjusted RR, 0.83 [95% CI, 0.39 to 1.76] for TDF-FTC), although there was a trend in that direction. One trial (Partners PrEP) reported PrEP to be highly effective across a range of tenofovir plasma levels (OR, 0.10 to 0.11 for tenofovir levels >0.3 to >40 ng/mL).^70,99^

The iPrEx RCT found reductions in risk of HIV acquisition of 50, 90, and 99 percent associated with TFV-DP concentrations of 3 (95% CI <1 to 7), 16 (95% CI, 3 to 28), and 33 (95% CI, 6 to 60) fmol/10^6^ peripheral blood mononuclear cells, respectively.^141^ A modeling analysis based on the iPrEx RCT and a dose-ranging study of directly observed PrEP (the STRAND dose-ranging study) estimated an efficacy of PrEP of 76 percent (95% CI, 56% to 96%) at two doses per week, 96 percent (95% CI, 90% to >99%) at four doses per week, and 99 percent (95% CI, 96 to >99%) at seven doses per week.^141^

The iPrEx Open Label Extension (iPrEx-OLE) study was an observational study of patients previously enrolled in three RCTs who did not seroconvert and were offered daily PrEP following completion of the RCTs.^125^ It found that effectiveness of PrEP increased at higher concentrations of TFV-DP using dried blood spot samples. The HR for seroconversion, compared with no PrEP, was 0.56 (95% CI, 0.23 to 1.31) at less than 350 fmol/punch (equivalent to ≤2 tablets/week) and 0.16 (95% CI, 0.01 to 0.79) at 350 to 699 fmol/punch (equivalent to 2 to 3 tablets/week). There were no cases of seroconversion at 700 fmol/punch or greater (equivalent to ≥4 tablets/week).

One other RCT^52^ and four observational studies^81,92,93,126^ found that all seroconverters on PrEP had undetectable plasma levels of tenofovir or plasma levels consistent with low adherence (Table 6). However, the number of seroconverters in each study was small (1 to 4 patients per study).

## Key Question 5 What Are the Harms of PrEP Versus Placebo or No PrEP When Used for the Prevention of HIV Infection?

### Summary

- There was no difference between PrEP versus placebo or no PrEP in risk of serious adverse events (12 trials; RR, 0.93 [95% CI, 0.77 to 1.12]; I^2^=56%).^52–54,70,76,78,85,97,100,117,^ ^119,120^
- PrEP was associated with a trend toward increased risk of withdrawals due to adverse events versus no PrEP or placebo that was not statistically significant (4 trials; RR, 1.25 [95% CI, 0.99 to 1.59]; I^2^=0%).^52,70,100,117,120^
- PrEP was associated with increased risk of renal adverse events (primarily ≥grade 1 creatinine elevation) (12 trials; RR, 1.43 [95% CI, 1.18 to 1.75]; I^2^=0%; absolute risk difference [ARD], 0.56% [95% CI, 0.09% to 1.04%]) versus no PrEP or placebo.^52–54,70,76,^ ^78,85,97,^ ^100,117,119,120^ Renal abnormalities generally resolved following PrEP cessation.
- PrEP was associated with increased risk of gastrointestinal adverse events (12 trials; RR, 1.63 [95% CI, 1.26 to 2.11]; I^2^=43%; ARD, 1.95% [95% CI, 0.48% to 3.43%]) versus placebo or no PrEP;^52–54,70,76,78,85,97,100,117,119,120^ gastrointestinal events were generally not serious and diminished over time.
- PrEP was associated with a trend toward increased risk of fracture that was not statistically significant (7 trials; RR, 1.23 [95% CI, 0.97 to 1.56]; I^2^=0%).^52,70,76,85,97,^ ^100,119^
- There were no differences between PrEP versus placebo in risk of syphilis (4 trials; RR, 1.08 [95% CI, 0.98 to 1.18]; I^2^=0%), gonorrhea (5 trials; RR, 1.07 [95% CI, 0.82 to 1.39]; I^2^=49%), chlamydia (5 trials; RR, 0.97 [95% CI, 0.80 to 1.18]; I^2^=59%) or combined bacterial STIs (2 trials; RR, 1.14 [95% CI, 0.97 to 1.34], I^2^=16%).^70,78,100,119,^ ^120^
- There was no difference between PrEP versus placebo in risk of HSV (3 trials; RR, 0.86 [95% CI, 0.64 to 1.16]; I^2^=48%) or hepatitis C virus infection (2 trials; RR, 0.73 [95% CI, 0.25 to 2.10]; I^2^=0%).^52,78,80,107,119^
- Among women who became pregnant in PrEP trials, PrEP was not associated with increased risk of spontaneous abortion (3 trials; RR, 1.09 [95% CI, 0.79 to 1.50]; I^2^=0%).^54,112,120^ One trial found no differences between PrEP versus placebo in pregnancy rate, risk of preterm birth, birth anomalies, or postpartum infant mortality.^112^

### Evidence

#### Serious Adverse Events

There was no difference between PrEP versus placebo in risk of serious adverse events (12 trials; RR, 0.93 [95% CI, 0.77 to 1.12]; I^2^=56%) (Table 7; Figure 11).^52–54,70,76,78,85,97,100,117,119,120^ Results using the profile likelihood method were similar (RR, 0.95 [95% CI, 0.78 to 1.23]) and there was no funnel plot asymmetry (Egger test p-value=0.53) (Appendix C Figure 3). Nine trials evaluated daily PrEP and two trials combined data for daily and intermittent/event-driven PrEP;^53,54^ one trial of event-driven PrEP (IPERGAY) reported a risk of serious adverse events (RR, 1.07 [95% CI, 0.58 to 1.98]) that was similar to the pooled estimate from trials of daily PrEP (11 trials; RR, 0.92 [95% CI, 0.76 to 1.12]; I^2^=59%).^52^ There were also no differences between PrEP versus placebo in risk of serious adverse events when trials were stratified according to whether they used TDF (5 trials; RR, 0.79 [95% CI, 0.56 to 1.12]; I^2^=72%)^70,76,85,97,^ ^117^ or TDF-FTC (9 trials; RR, 1.02 [95% CI, 0.81 to 1.30]; I^2^=46%; p=0.23 for interaction) (Figure 11).^52–54,70,76,78,100,119,120^ One trial (PROUD) found TDF-FTC associated with a greater risk of serious adverse events than placebo (7.6% [21/375] vs. 2.2% [6/269]; RR, 3.42 [95% CI, 1.40 to 8.35]).^78^ It differed from other trials in that it used an open-label design. Serious adverse events reported by more than one patient on TDF-FTC in PROUD included gastrointestinal events, fractures, and psychiatric events.

Table 7 Adverse Events in Trials of PrEP Versus Placebo/No PrEP

Outcome | Number of trials^*^ | RR (95% CI) | I^2^
Serious adverse events; PrEP drug regimen (p=0.23 for interaction) | 12^52–54,70,76,78,85,97,100,117,^ ^119,120^ | 0.93 (0.77 to 1.12) | 56%
TDF | 5^70,76,85,97,117^ | 0.79 (0.56 to 1.12) | 72%
TDF-FTC | 9^52–54,70,76,78,100,119,120^ | 1.02 (0.81 to 1.30) | 46%
Withdrawal due to adverse events; PrEP drug regimen (p=0.67 for interaction) | 4^52,70,100,120^ | 1.25 (0.99 to 1.59) | 0%
TDF | 1^70^ | 1.00 (0.34 to 2.92) | Not applicable
TDF-FTC | 4^52,70,100,120^ | 1.27 (1.00 to 1.59) | 0%
Fracture; PrEP drug regimen (p=0.50 for interaction) | 8^52,70,76,78,85,97,100,119^ | 1.23 (0.97 to 1.56) | 0%
TDF | 4^70,76,85,97^ | 1.29 (0.98 to 1.70) | 0%
TDF-FTC | 6^52,70,76,78,100,119^ | 1.06 (0.66 to 1.72) | 0%
Renal adverse events; PrEP drug regimen (p=0.31 for interaction) | 12^52–54,70,76,78,85,97,100,^ ^117,^ ^119,120^ | 1.43 (1.18 to 1.75) | 0%
TDF | 5^70,76,85,97,117^ | 1.24 (0.87 to 1.76) | 0%
TDF-FTC | 9^52–54,70,76,78,100,119,120^ | 1.54 (1.21 to 1.96) | 0%
Gastrointestinal adverse events; PrEP drug regimen (p=0.30 for interaction) | 12^52–54,70,76,78,85,97,100,^ ^117,119,120^ | 1.63 (1.26 to 2.11) | 43%
TDF | 5^70,76,85,97,117^ | 1.45 (1.13 to 1.85) | 0%
TDF-FTC | 9^52–54,70,76,78,100,119,120^ | 1.84 (1.26 to 2.70) | 49%

* Two trials included both TDF and TDF-FTC arms and one trial included both TDF and TDF-FTC arms.

Abbreviations: CI=confidence interval; FTC=emtricitabine; PrEP=pre-exposure prophylaxis; RR=relative risk; TDF=tenofovir disoproxil fumarate.

Figure 11 Meta-Analysis: Serious Adverse Events Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 11 is a forest plot of serious adverse events stratified by study drug with two subgroups. The risk ratio for 5 studies in the TDF subgroup is 0.79 (95% confidence interval 0.56 to 1.12) with an I-squared value of 72%. The risk ratio for 9 studies in the FTC-TDF subgroup is 1.02 (95% confidence interval 0.81 to 1.30) with an I-squared value of 46%. The overall risk ratio for all studies is 0.93 (95% confidence interval 0.77 to 1.12) with an I-squared value of 56%.

#### Withdrawals Due to Adverse Events

Withdrawals due to adverse events were reported in five trials (Table 7).^52,70,100,117,120^ One trial^117^ reported no withdrawals with either PrEP or placebo. In the other trials, PrEP was associated with a trend toward increased risk of withdrawal due to adverse events with PrEP versus placebo that was not statistically significant (4 trials; RR, 1.25 [95% CI, 0.99 to 1.59]; I^2^=0%). One trial evaluated TDF (RR, 1.00 [95% CI, 0.34 to 2.92]) and four evaluated TDF-FTC (RR, 1.27 [95% CI, 1.00 to 1.62]; p=0.67 for interaction) (Figure 12). The only trial to report a statistically significant increase in risk of withdrawals (either temporary or permanent) due to adverse events was the FEM-PrEP trial, which evaluated TDF-FTC (RR, 1.68 [95% CI, 1.10 to 2.56]).^120^ The majority (~90%) of withdrawals in this trial were the result of laboratory abnormalities (grade 2 or higher). In FEM-PrEP, there was no difference in risk of withdrawal due to clinical adverse events, although the estimate was imprecise (RR, 3.53 [95% CI, 0.73 to 17]).

Figure 12 Meta-Analysis: Withdrawals Due to Adverse Events Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; M-H=Mantel-Haenszel test; iPrEx=Pre-Exposure Prophylaxis Initiative; PrEP=pre-exposure prophylaxis; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF=tenofovir disoproxil fumarate; U.S.=United States.

Figure 12 is a forest plot of withdrawals due to adverse events stratified by study drug with two subgroups. The risk ratio for 2 studies in the TDF subgroup is 1.00 (95% confidence interval 0.34 to 2.92). The risk ratio for 4 studies in the TDF-FTC subgroup is 1.27 (95% confidence interval 1.00 to 1.62) with an I-squared value of 0%. The overall risk ratio for all studies is 1.25 (95% confidence interval 0.99 to 1.59) with an I-squared value of 0%.

#### Fracture

Tenofovir exposure is associated with bone loss,^104,114,119,147^ which could result in increased fracture risk. PrEP was associated with a trend toward increased risk of fracture versus placebo that was not statistically significant (7 trials; RR, 1.23 [95% CI, 0.97 to 1.56]; I^2^=0%; ARD, 0.21% [95% CI, −0.21% to 0.62%]) (Table 7; Figure 13).^52,70,76,85,97,100,119^ The meta-analysis was heavily weighted (64%) by the Bangkok Tenofovir Study of persons who inject drugs, which reported a relatively high fracture rate (7.8% vs. 6.0%; RR, 1.29 [95% CI, 0.96 to 1.74]).^97^ There was no statistically significant interaction between the PrEP regimen and fracture risk (p=0.50) (Figure 13). One trial of event-driven dosing (IPERGAY) did not find PrEP associated with an increased risk of fracture, but the estimate was imprecise (RR, 0.51 [95% CI, 0.13 to 1.99]).^52^ Patients averaged 15 doses per month in IPERGAY; effects of intermittent/event-driven dosing with less frequent exposure to PrEP on fracture risk are not available. In trials for which details were available regarding the mechanism of fracture, all or almost all fractures were traumatic.^89^

Figure 13 Meta-Analysis: Fracture Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FTC=emtricitabine; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 13 is a forest plot of fractures stratified by study drug with two subgroups. The risk ratio for 4 studies in the TDF subgroup is 1.29 (95% confidence interval 0.98 to 1.70) with an I-squared value of 0%. The risk ratio for 6 studies in the FTC-TDF subgroup is 1.06 (95% confidence interval 0.66 to 1.72) with an I-squared value of 0%. The overall risk ratio for all studies is 1.23 (95% confidence interval 0.97 to 1.56) with an I-squared value of 0%.

Results were similar when the profile likelihood method was used for pooling (RR, 1.23 [95% CI, 0.92 to 1.58]). There were discrepancies between the number of fractures reported in journal reports of three trials (the CDC Safety Study,^85^ iPrEx,^100^ and Partners PrEP^70^) and the FDA review^89^ of these trials (Appendix B Tables 1-3). However, the pooled estimate was similar when the FDA data were used in the meta-analysis in place of data reported in the journal articles (RR, 1.20 [95% CI, 0.96 to 1.52]) (Figure 14).

Figure 14 Meta-Analysis: Fracture Using FDA Data (iPrEx, Partners PrEP, CDC Safety Study)

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval, df=degrees of freedom; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test, PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 14 is a forest plot of fracture using FDA data (iPrEx, Partners PrEP, CDC Safety Study). The risk ratio for 8 studies is 1.20 (95% confidence interval 0.96 to 1.52) with an I-squared value of 0%.

#### Renal Adverse Events

PrEP was associated with increased risk of renal adverse events (primarily ≥grade 1 serum creatinine elevation) versus placebo (12 trials; RR, 1.43 [95% CI, 1.18 to 1.75]; I^2^=0%; ARD, 0.56% [95% CI, 0.09% to 1.04%]) (Table 7; Figure 15).^52–54,70,76,78,85,97,100,117,119,120^ Results were similar with the profile likelihood method (RR, 1.44 [95% CI, 1.12 to 1.79]) and no funnel plot asymmetry was present (Egger test p-value=0.29) (Appendix C Figure 4). A trial of event-driven PrEP (IPERGAY) reported an increased risk of renal adverse events (RR, 1.77 [95% CI, 1.06 to 2.95]) consistent with the pooled estimate from trials of daily PrEP (11 trials; RR, 1.38 [95% CI, 1.11 to 1.72]; I^2^=0%).^52^ There was no clear difference in risk of renal adverse events when trials were stratified according to use of TDF or TDF-FTC (p=0.31 for interaction). Serious renal events were rare and no trial reported a difference between PrEP and placebo in risk of serious renal events or withdrawals due to renal events (Appendix B Tables 1-3).

Figure 15 Meta-Analysis: Renal Adverse Events Stratified by Study Drug

Note: Defined as ≥grade 1 serum creatinine elevation unless otherwise noted.

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 15 is a forest plot of renal adverse events stratified by study drug with two subgroups. The risk ratio for 5 studies in the TDF subgroup is 1.24 (95% confidence interval 0.87 to 1.76) with an I-squared value of 0%. The risk ratio for 9 studies in the FTC-TDF subgroup is 1.54 (95% confidence interval 1.21 to 1.96) with an I-squared value of 0%. The overall risk ratio for all studies is 1.43 (95% confidence interval 1.18 to 1.75) with an I-squared value of 0%.

Six trials^53,54,70,106,108,118^ evaluated whether renal adverse events while on PrEP were persistent (Appendix B Tables 1-3). Three studies^70,106,118^ reported a return to normal serum creatinine levels after cessation of PrEP and two others^53,54^ reported normalization of creatinine level without PrEP cessation.^113^ In one other trial, the Bangkok Tenofovir Study of persons who inject drugs, among 7 cases of grade 2 or worse creatinine elevation, all but 1 case resolved following PrEP cessation.^108^

#### Gastrointestinal Adverse Events

PrEP was associated with increased risk of gastrointestinal adverse events (primarily nausea) versus placebo (12 trials; RR, 1.63 [95% CI, 1.26 to 2.11]; I^2^=43%; ARD, 1.95% [95% CI, 0.48% to 3.43%]) (Table 7; Figure 16).^52–54,70,76,78,85,97,100,117,119,120^ Results were similar using the profile likelihood method (RR, 1.67 [95% CI, 1.26 to 2.25]) and there was no funnel plot asymmetry (Egger test p-value=0.81) (Appendix C Figure 5). The risk of gastrointestinal adverse events was highest in one trial of intermittent PrEP, but the estimate was imprecise (8.0% vs. 1.0%; RR, 8.08 [95% CI, 1.88 to 34.68]).^52^ The HPTN 067/ADAPT trial, which compared different PrEP dosing strategies (daily, time-based, or event-driven), found no difference in risk of gastrointestinal events between daily and intermittent PrEP (Appendix B Tables 1-3).^122^ When stratified according to the PrEP regimen used, the risk of gastrointestinal adverse events was increased for both TDF (5 trials; RR, 1.45 [95% CI, 1.13 to 1.85]; I^2^=0%)^70,76,85,97,117^ and TDF-FTC (9 trials; RR, 1.84 [95% CI, 1.26 to 2.70]; I^2^=49%),^52–54,70,76,78,100,119,120^ with no statistically significant interaction (p=0.30) (Figure 16). Among studies that reported rates of diarrhea^52,70,76,78,85,119,120^ or vomiting^76,120^ separately, none reported a significant difference between PrEP and placebo (Appendix B Tables 1-3). Three trials reported that the risk of gastrointestinal events diminished over time.^97,100,119^ Serious gastrointestinal events were rare in the trials that reported this outcome, with no differences between PrEP and placebo (Appendix B Tables 1-3).^76,78,100,117,119,120^

Figure 16 Meta-Analysis: Gastrointestinal Adverse Events Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF=tenofovir disoproxil fumarate; TDF2= Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 16 is a forest plot of gastrointestinal adverse events stratified by study drug with two subgroups. The risk ratio for 5 studies in the TDF subgroup is 1.45 (95% confidence interval 1.13 to 1.85) with an I-squared value of 0%. The risk ratios for 9 studies in the FTC-TDF subgroup is 1.84 (95% confidence interval 1.26 to 2.70) with an I-squared value of 49%. The overall risk ratio for all studies is 1.63 (95% confidence interval 1.26 to 2.11) with an I-squared value of 43%.

#### STIs

There were no differences between PrEP versus placebo or no PrEP in risk of syphilis (4 trials; RR, 1.08 [95% CI, 0.98 to 1.18]; I^2^=0%) (Figure 17), gonorrhea (5 trials; RR, 1.07 [95% CI, 0.82 to 1.39]; I^2^=49%) (Figure 18), chlamydia (5 trials; RR, 0.97 [95% CI, 0.80 to 1.18]; I^2^=59%) (Figure 19), or combined bacterial STIs (2 trials; RR, 1.14 [95% CI, 0.97 to 1.34]; I^2^=16%) (Figure 20; Table 8).^70,78,100,119,120^ Combined STIs were defined as gonorrhea, chlamydia, or trichomoniasis in one trial^70^ and gonorrhea, chlamydia, or syphilis in the other.^78^ When trials were stratified according to the PrEP regimen, TDF was associated with lower risk of chlamydia or gonorrhea versus placebo than TDF-FTC, but neither regimen was associated with increased risk, and only one trial evaluated TDF. All of the trials except for one were blinded. This could affect risk of STIs if participants who do not know if they are taking PrEP or placebo behave differently than those who know whether or not they are taking PrEP. The open-label PROUD trial, which enrolled men who have sex with men, found no statistically significant association between PrEP versus no PrEP and risk of syphilis (RR, 1.28 [95% CI, 0.76 to 2.16]), gonorrhea (RR, 1.07 [95% CI, 0.86 to 1.34]), or chlamydia (RR, 1.32 [95% CI, 0.98 to 1.79]), although estimates generally indicated trends toward increased risk. Although the unadjusted estimate for risk of combined STIs in PROUD was statistically significant (RR, 1.20 [95% CI, 1.01 to 1.42]), the difference was no longer statistically significant after adjustment for the number of screenings (adjusted OR, 1.07 [95% CI, 0.78 to 1.46]). This is consistent with a higher rate in PROUD of condomless receptive anal intercourse with 10 or more partners among men randomized to PrEP (20%) versus deferred PrEP (12%).^78^ In the nonrandomized Demo Project (PrEP demonstration project in men who have sex with men), 26 percent of participants had an STI at baseline and approximately 50 percent had an STI while on PrEP.^81^

Table 8 Risk of STI in Trials and PrEP Versus Placebo/No PrEP

Outcome | Number of trials^*^ | RR (95% CI) | I^2^
Any bacterial sexually transmitted infection; PrEP drug regimen (p=0.60 for interaction); HIV risk category (p=0.38 for interaction) | 2^70,78^ | 1.14 (0.97 to 1.34) | 16%
TDF | 1^70^ | 1.21 (0.86 to 1.72) | Not applicable
TDF-FTC | 2^70,78^ | 1.07 (0.80 to 1.44) | 58%
Heterosexual men and women | 1^70^ | 1.05 (0.82 to 1.35) | Not applicable
MSM | 1^78^ | 1.20 (1.01 to 1.42) | Not applicable
Syphilis; PrEP drug regimen (p=0.86 for interaction); HIV risk category (p=0.90 for interaction) | 4^70,76,78,100^ | 1.08 (0.98 to 1.18) | 0%
TDF | 2^70,76^ | 1.13 (0.66 to 1.93) | 0%
TDF-FTC | 4^70,76,78,100^ | 1.07 (0.98 to 1.18) | 0%
Heterosexual men and women | 2^70,76^ | 1.05 (0.71 to 1.54) | 0%
MSM | 2^78,100^ | 1.08 (0.98 to 1.18) | 0%
Gonorrhea; PrEP drug regimen (p=0.02 for interaction); HIV risk category (p=0.59 for interaction) | 5^76,78,100,119,120^ | 1.07 (0.82 to 1.39) | 49%
TDF | 1^76^ | 0.57 (0.33 to 0.98) | Not applicable
TDF-FTC | 5^76,78,100,119,120^ | 1.15 (0.97 to 1.37) | 2%
Heterosexual men and women | 3^76,119,120^ | 1.20 (0.76 to 1.92) | 69%
MSM | 2^78,100^ | 1.05 (0.85 to 1.30) | 0%
Chlamydia; PrEP drug regimen (p=0.004 for interaction); HIV risk category (p=0.46 for interaction) | 5^76,78,100,119,120^ | 0.97 (0.80 to 1.18) | 59%
TDF | 1^76^ | 0.68 (0.52 to 0.90) | Not applicable
TDF-FTC | 5^76,78,100,119,120^ | 1.07 (0.94 to 1.22) | 0%
Heterosexual men and women | 3^76,119,120^ | 0.81 (0.47 to 1.41) | 93%
MSM | 2^78,100^ | 1.09 (0.62 to 1.92) | 50%
Herpes simplex virus infection; PrEP drug regimen (p=0.67 for interaction); HIV risk category (p=0.06 for interaction) | 3^80,107,119^ | 0.85 (0.67 to 1.07) | 19%
TDF | 1^80^ | 0.76 (0.48 to 1.21) | Not applicable
TDF-FTC | 3^80,107,119^ | 0.86 (0.62 to 1.18) | 40%
Heterosexual men and women | 2 ^80,119^ | 0.73 (0.56 to 0.96) | 0%
MSM | 1^107^ | 1.12 (0.80 to 1.56) | Not applicable
Hepatitis C virus infection ^†^ | 2^52,78^ | 0.73 (0.25 to 2.10) | 0%

* Two trials included both TDF and TDF-FTC arms.

† Both trials evaluated TDF-FTC in MSM.

Abbreviations: CI=confidence interval; FTC=emtricitabine; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; RR=relative risk; TDF=tenofovir disoproxil fumarate.

Figure 17 Meta-Analysis: Syphilis Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FTC=emtricitabine; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 17 is a forest plot of syphilis stratified by study drug with two subgroups. The risk ratio for 2 studies in the TDF subgroup is 1.13 (95% confidence interval 0.66 to 1.93) with an I-squared value of 0%. The risk ratio for 4 studies in the FTC-TDF subgroup is 1.07 (95% confidence interval 0.98 to 1.18) with I-squared value of 0%. The overall risk ratio for all studies is 1.08 (95% confidence interval 0.98 to 1.18) with an I-squared value of 0%.

Figure 18 Meta-Analysis: Gonorrhea Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; TDF2= Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 18 is a forest plot of gonorrhea stratified by study drug with two subgroups. The risk ratio for 1 study in the TDF subgroup is 0.57 (95% confidence interval 0.33 to 0.98). The risk ratio for 5 studies in the FTC-TDF subgroup is 1.15 (95% confidence interval 0.97 to 1.37) with an I-squared value of 2%. The overall risk ratio for all studies is 1.07 (95% confidence interval 0.82 to 1.39) with an I-squared value of 49%.

Figure 19 Meta-Analysis: Chlamydia Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; TDF2= Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 19 is a forest plot of chlamydia stratified by study drug with two subgroups. The risk ratio for 1 study in the TDF subgroup is 0.68 (95% confidence interval 0.52 to 0.90). The risk ratio for 5 studies in the FTC-TDF subgroup is 1.07 (95% confidence interval 0.94 to 1.22) with an I-squared value of 0%. The overall risk ratio for all studies is 0.97 (95% confidence interval 0.80 to 1.18) with an I-squared value of 59%.

Figure 20 Meta-Analysis: Combined Bacterial STIs Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FTC=emtricitabine; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; U.S.=United States.

Figure 20 is a forest plot of combined bacterial STIs stratified by study drug with two subgroups. The risk ratio for 1 study in the TDF subgroup is 1.21 (95% confidence interval 0.86 to 1.72). The risk ratio for 2 studies in the FTC-TDF subgroup is 1.07 (95% confidence interval 0.80 to 1.44) with an I-squared value of 58%. The overall risk ratio for all studies is 1.14 (95% confidence interval 0.97 to 1.34) with an I-squared value of 16%.

PrEP was not associated with increased risk of bacterial STIs when trials (open-label or blinded) were stratified according to whether they evaluated men who have sex with men or persons at risk of HIV infection via heterosexual contact (Table 8; Figures 21–24). The only trial conducted in persons who inject drugs did not report risk of STI.^97^ Results for bacterial STIs were similar when data were pooled using the profile likelihood method.

Figure 21 Meta-Analysis: Syphilis Stratified by HIV Risk Category

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenzel test; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 21 is a forest plot of syphilis stratified by HIV risk category with two subgroups. The risk ratio for 2 studies in the heterosexual men and women category is 1.05 (95% confidence interval 0.71 to 1.54) with an I-squared value of 0%. The risk ratio for 2 studies in the MSM category is 1.08 (95% confidence interval 0.98 to 1.18) with an I-squared value of 0%. The overall risk ratio for all studies is 1.08 (95% confidence interval 0.98 to 1.18) with an I-squared value of 0%.

Figure 22 Meta-Analysis: Gonorrhea Stratified by HIV Risk Category

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF2=Tenofovir Disoproxil Fumarate Study 2; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 22 is a forest plot of gonorrhea stratified by HIV risk category with two subgroups. The risk ratio for 3 studies in the heterosexual category is 1.20 (95% confidence interval 0.76 to 1.92) with an I-squared value of 69%. The risk ratio for 2 studies in the MSM category is 1.05 (95% confidence interval 0.85 to 1.30) with an I-squared value of 0%. The overall risk ratio for all studies is 1.10 (95% confidence interval 0.86 to 1.40) with an I-squared value of 43%.

Figure 23 Meta-Analysis: Chlamydia Stratified by HIV Risk Category

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 23 is a forest plot of chlamydia stratified by HIV risk category with two subgroups. The risk ratio for 3 studies in the heterosexual category is 0.81 (95% confidence interval 0.47 to 1.41) with an I-squared value of 93%. The risk ratio for 2 studies in the MSM category is 1.09 (95% confidence interval 0.62 to 1.92) with an I-squared value of 50%. The overall risk ratio for all studies is 0.89 (95% confidence interval 0.58 to 1.36) with an I-squared value of 90%.

Figure 24 Meta-Analysis – Any STI Stratified by HIV Risk Category

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; M-H=Mantel-Haenszel test; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; U.S.=United States.

Figure 24 is a forest plot of any STI stratified by HIV risk category with two subgroups. The risk ratio for 1 study in the heterosexual category is 1.05 (95% confidence interval 0.82 to 1.35). The risk ratio for 1 study in the MSM category is 1.20 (95% confidence interval 1.01 to 1.42). The overall risk ratio for all studies is 1.15 (95% confidence interval 1.00 to 1.32) with an I-squared value of 0%.

There was no difference between PrEP versus placebo in risk of HSV infection (3 trials; RR, 0.85 [95% CI, 0.67 to 1.07]; I^2^=19%) (Figure 25).^80,107,119^ Two trials evaluated the risk of HSV infection based on serology in participants who were seronegative for HSV at baseline;^80,107^ the other trial did not report the method for diagnosing HSV infection.^119^ When stratified according to HIV risk category, PrEP was associated with decreased risk of HSV infection versus placebo in two trials of persons at risk via heterosexual contact (RR, 0.73 [95% CI, 0.56 to 0.96]; I^2^=0%)^70^ but not in one trial of men who have sex with men (RR, 1.12 [95% CI, 0.80 to 1.56])^107^ (Table 8). However, this analysis was based on few trials, and the test for a subgroup difference was not statistically significant (p=0.06). In the trial of men who have sex with men, PrEP was not associated with decreased risk of a serological diagnosis of HSV infection, but was associated with lower risk of incident HSV infection with an ulcer (5.9% vs. 2.9%; p<0.05).^107^

Figure 25 Meta-Analysis: Herpes Simplex Virus Infection Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FTC=emtricitabine; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States

Figure 25 is a forest plot of herpes simplex virus infection stratified by study drug with two subgroups. The risk ratio for 1 study in the TDF subgroup is 0.76 (95% confidence interval 0.48 to 1.21). The risk ratio for 2 studies in the FTC-TDF subgroup is 0.86 (95% confidence interval 0.62 to 1.18) with an I-squared value of 40%. The overall risk ratio for all studies was 0.85 (95% confidence interval 0.67 to 1.07) with an I-squared value of 19%.

#### Hepatitis C Virus Infection

There was no difference between PrEP versus placebo or no PrEP in risk of hepatitis C virus infection, but only two trials reported this outcome, and the estimate was imprecise (RR, 0.73 [95% CI, 0.25 to 2.10]; I^2^=0%)^52,78^ (Figure 26). Both trials (PROUD and IPERGAY) evaluated PrEP with TDF-FTC in men who have sex with men. There were 6 cases of hepatitis C virus infection in one trial^78^ and 8 cases in the other.^52^

Figure 26 Meta-Analysis: Hepatitis C Virus Infection

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; U.S.=United States.

Figure 26 is a forest plot of hepatitis C infection. The risk ratio for 2 studies is 0.73 (95% confidence interval 0.25 to 2.10) with an I-squared value of 0%.

#### Pregnancy-Related Outcomes

No trial of PrEP enrolled pregnant women, and women who became pregnant during the course of the trial were withdrawn from participation. Three trials reported on pregnancy outcomes in women who were withdrawn from PrEP because of pregnancy.^54,112,120^ In one trial, only one pregnancy occurred among women randomized to PrEP;^54^ in the other two trials, 74 and 192 pregnancies occurred.^70,120^ All of the trials were conducted in Africa and evaluated women at increased risk of HIV infection via heterosexual activity. Among women who became pregnant in the trials, PrEP was not associated with increased risk of spontaneous abortion (RR, 1.09 [95% CI, 0.79 to 1.50]; I^2^=0%) (Appendix B Tables 1-3; Figure 27). When stratified according to the PrEP regimen used, TDF was not associated with increased risk, but was only evaluated in one trial (RR, 0.83 [95% CI, 0.50 to 1.37]).^112^ TDF-FTC was associated with a trend toward increased risk of spontaneous abortion that was not statistically significant (RR, 1.32 [95% CI, 0.86 to 2.01]; I^2^=0%).^54,112,120^ There was no statistically significant interaction between the PrEP regimen and risk of spontaneous abortion (p=0.17). The Partners PrEP trial found no differences between PrEP versus placebo in pregnancy rate, risk of preterm birth, birth anomalies, or postpartum infant mortality, and the FEM-PrEP trial found no difference in risk of any adverse pregnancy outcome (Appendix B Tables 1-3).^112^

Figure 27 Meta-Analysis: Spontaneous Abortion Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; IAVI=International AIDS Vaccine Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; TDF=tenofovir disoproxil fumarate; U.S.=United States.

Figure 27 is a forest plot of spontaneous abortion stratified by study drug with two subgroups. The risk ratio for 1 study in the TDF subgroup is 0.83 (95% confidence interval 0.50 to 1.37). The risk ratio for 3 studies in the FTC-TDF subgroup is 1.32 (95% confidence interval 0.86 to 2.01) with an I-squared value of 0%. The overall risk ratio for all studies was 1.09 (95% confidence interval 0.79 to 1.50) with an I-squared value of 0%.

## Contextual Question 1 What Factors Are Associated With Increased or Decreased Adherence to PrEP?

Data on factors associated with decreased or increased adherence to PrEP in U.S. primary care–applicable settings are limited. The only randomized trial conducted in the United States did not report factors associated with adherence.^85^ Implementation studies conducted in U.S. populations indicate differences in adherence related to race/ethnicity, socioeconomic status, and presence of higher-risk behaviors, as well as some geographic/site differences in adherence not explained by these factors.

The largest (n=557) U.S. PrEP implementation study to date is the previously described Demo Project.^81^ It enrolled men who have sex with men (98%) and transgender women (1.4%) in three cities (mean age, 34 to 35 years) and evaluated factors associated with adherence, defined by presence of protective TFV-DP levels in dried blood spot samples. In multivariate analysis, African American race was associated with lower adherence compared with white race (adjusted OR, 0.28 [95% CI, 0.12 to 0.64]). Although Latino, Asian, and “other” race/ethnicity were also associated with decreased likelihood of adherence, differences were not statistically significant. Factors associated with increased adherence were having stable housing (renting or owning housing) versus less stable housing (living with friends or family, public housing, or homeless) (adjusted OR, 2.02 [95% CI, 1.14 to 3.55]), or having condomless receptive anal sex with two or more partners (vs. 0 or 1 partner) in the past 3 months (adjusted OR, 1.82 [95% CI, 1.14 to 2.89]). There was no clear association between age, educational level, PrEP awareness, income level, health insurance status, depression, and alcohol or drug use and adherence to PrEP. Participants at the Miami site were less likely to be adherent to PrEP (vs. the San Francisco site; adjusted OR, 0.32 [95% CI, 0.17 to 0.60]), with no difference between the San Francisco and Washington, D.C., sites.

Another U.S.-based PrEP implementation study by Chan et al (n=267; mean age 32 years) evaluated factors associated with retention in care (a potential marker for adherence) after initiation of PrEP.^124^ The population was primarily (~90%) men who have sex with men, with smaller proportions of heterosexual men and women (~10%) and transgender women (~1%). At 6 months, it found no clear association between age, race/ethnicity, educational level, being a man who has sex with men, income, or insurance status and likelihood of retention in care.

A study of younger (ages 18 to 22 years) men who have sex with men (n=200), in whom overall adherence was lower than in studies of older men who have sex with men (see Key Question 3), found that those who reported engaging in recent sex without condoms had higher TFV-DP levels than those who did not report this behavior (p=0.01).^93^ There was a similar but statistically nonsignificant trend toward higher TFV-DP levels among participants who reported condomless receptive anal sex with their last sexual partner. Patients who did not like taking pills were more likely to be nonadherent (p=0.02). The study did not report the association between factors such as race/ethnicity, age, socioeconomic status, insurance status, or drug use behaviors and adherence.

A large (n=1,086) database study of veterans prescribed PrEP found older age (ages 50 to 64 vs. <35 years; adjusted OR, 2.00 [95% CI, 1.37 to 2.92]), male sex (vs. female sex; adjusted OR, 3.39 [95% CI, 1.37 to 8.42]) and white race (vs. black race; adjusted OR, 2.02 [95% CI, 1.43 to 2.87]) associated with increased adherence.^128^ Other factors, including comorbid substance abuse or depression, low socioeconomic status, rural living, and region of the United States, were not significant predictors of adherence. This study used prescribing (refill) data to measure adherence and did not include information on HIV risk factors or indication for PrEP.

Data on factors associated with higher or lower adherence to PrEP in U.S populations of persons who inject drugs are lacking. In an open-label extension to the Bangkok Tenofovir Study RCT, which focused on persons who inject drugs who could elect to receive directly observed therapy, persons who injected midazolam or were in prison during open-label followup were more likely to be greater than 90 percent adherent than those who did not inject midazolam (OR, 2.2 [95% CI, 1.2 to 4.3]) or were not in prison (OR, 4.7 [95% CI, 3.1 to 7.2]). Persons who injected heroin or had been in prison were more likely to choose PrEP than persons without those characteristics (OR, 1.5 [95% CI, 1.1 to 2.1] and OR, 1.7 [95% CI, 1.3 to 2.1], respectively) and more likely to return for followup (OR, 3.0 [95% CI, 1.3 to 7.3] and OR, 2.3 [95% CI, 1.4 to 3.7], respectively).^148^

Data on factors associated with higher or lower adherence to PrEP in U.S. populations of women and men at increased risk of HIV infection via heterosexual contact are not available. In the Partners PrEP trial, which enrolled African men and women, factors associated with increased likelihood of low (<80%) adherence based on unannounced pill counts were younger age (adjusted OR, 1.4 per 10-year age increment [95% CI, 1.0 to 2.0]), no sex in the past month (adjusted OR, 4.2 [95% CI, 1.9 to 9.4] vs. having sex with condoms with a primary partner), and heavy alcohol use (adjusted OR, 2.8 [95% CI, 1.4 to 5.5]).^101^ Male sex, HIV-infected partner CD4 count, education level, socioeconomic status, number of side effects, and time on PrEP were not associated with likelihood of low adherence. Women in the Partners PrEP trial who reported intimate partner violence were more likely to report low adherence based on pill count (adjusted RR, 1.49 [95% CI, 1.17 to 1.89])^149^ or plasma tenofovir levels.^99,149^ The VOICE trial, which enrolled heterosexual African women, reported low overall adherence based on plasma tenofovir levels.^76^ Factors associated with presence of detectable plasma tenofovir in VOICE were being older than age 25 years (adjusted OR, 1.62 [95% CI, 1.12 to 2.34]), being married (adjusted OR, 2.24 [95% CI, 1.12 to 4.49]), having an independent income (adjusted OR, 1.42 [95% CI, 0.98 to 2.07), and being multiparous (adjusted OR, 1.84 [95% CI 1.26 to 2.69]).

## Contextual Question 2 What Is the Risk of Infection With Antiretroviral Drug–Resistant HIV in Persons Treated With PrEP, and What Is the Effect of Infection With PrEP-Related, Antiretroviral Drug–Resistant HIV on Treatment Outcomes?

Ten RCTs reported rates of antiretroviral drug resistance in persons randomized to PrEP (N=8,661) (Table 9).^52,70,76,78,85,97,100,117,119,120^ One trial evaluated event-driven PrEP^52^ and the other nine trials evaluated daily PrEP. Five trials evaluated PrEP with TDF alone^70,76,85,97,117^ and seven trials evaluated TDF-FTC;^52,70,100,120^ two trials^70,76^ evaluated both regimens. The most commonly reported mutations were the tenofovir resistance mutations K65R and K70E and the emtricitabine mutations M184I and M184V.

Table 9 Rates of Antiretroviral Drug Resistance in Patients Taking PrEP

Study; Author, year; Study design | PrEP regimen | Resistance mutations among persons with newly diagnosed HIV infection | Resistance mutations among persons randomized to PrEP
Bangkok Tenofovir Study; Choopanya 2013^97^; RCT | A: TDF daily (n=1,204) | TDF vs. placebo^*^; K65R, K70E: 0% (0/17) vs. 0% (0/35) | 0% (0/1204)
FEM-PrEP; Van Damme 2012^120^; RCT | A: TDF-FTC daily (n=1,024) | TDF-FTC vs. placebo^†^; K65R, K70E: 0% (0/33) vs. 0% (0/35); M184V mutation: 9.1% (3/33) vs. 2.9% (1/35); M184I mutation: 3.0% (1/33) vs. 0% (0/35) | 0.4% (4/1024)
Grohskopf, 2013^85^; RCT | A: TDF daily (n=201) | TDF vs. placebo; K65R: 0% (0/0) vs. 0% (0/7) | 0% (0/201)
IPERGAY; Molina 2015^52^; RCT | A: TDF-FTC on demand (n=199) | TDF-FTC (n=2) vs. placebo (n=14); No resistance mutations identified | 0% (0/199)
iPrEx; Grant 2010^100^; RCT | A: TDF-FTC daily (n=1,251) | TDF-FTC vs. placebo^‡^; M184V alone: 2.6% (1/38) vs. 0% (0/72); M184I: 2.6% (1/38) vs. 0% (0/72); Multidrug resistance (M184V, T215Y, and K103N): 0% (0/38) vs. 1.4% (1/72) | 0.2% (2/1,251)
Partners PrEP; Baeten 2012^70^; RCT | A: TDF daily (n=1,572); B: TDF-FTC daily (n=1,568) | TDF vs. TDF-FTC vs. placebo^§^; K65R: 5.0% (1/20) vs. 0% (0/15) vs. 0% (0/57); K70E: 0% (0/20) vs. 0% (0/15) vs. 0% (0/57); K65N: 5.0% (1/20) vs. 0% (0/15) vs. 0% (0/57); M184I: 0% (0/20) vs. 0% (0/15) vs. 0% (0/57); M184V: 0% (0/20) vs. 6.7% (1/15) vs. 0% (0/57) | 0.1% (3/3,140) overall; 0.1% (2/1,572) TDF; 0.06% (1/1,568) TDF-FTC
PROUD; McCormack, 2016^78^; RCT | A: TDF-FTC daily (n=268) | TDF-FTC vs. deferred PrEP^║^; K65R or K70G: 0% (0/5) vs. NR; M184I or M184V: 40% (2/5) vs. NR | 0.7% (2/268)
Study of TDF; Peterson 2007^117^; RCT | A: TDF daily (n=427) | TDF vs. placebo^¶^; No drug resistance mutations identified in 1 patient randomized to TDF (no resistance testing performed in 1 other patient randomized to TDF who became infected) | NR
TDF2; Thigpen 2012^119^; RCT | A: TDF-FTC daily (n=601) | TDF-FTC vs. placebo; Multidrug resistance (M184V, K65R, and A62V): 10% (1/10)^#^ vs. 0% (0/26); K65R alone: 0% (0/10) vs. 3.8% (1/26) | 0.2% (1/601)
VOICE; Marrazzo 2015^76^; RCT | A: TDF daily (n=172); B: TDF-FTC daily (n=174) | TDF vs. TDF-FTC vs. placebo^**^; K65R: 0% (0/70) vs. 0% (0/71) vs. 0% (0/69); K70E: 0% (0/70) vs. 0% (0/71) vs. 0% (0/69); M184V: 0% (0/70) vs. 4.2% (3/71) vs. 0% (0/69); M184I: 0% (0/70) vs. 1.4% (1/71) vs. 0% (0/69) | 1.2% (4/346) overall; 0% (0/172) TDF; 2.3% (4/174) TDF-FTC
iPrEx-OLE; Grant 2014^125^; Observational | A: TDF-FTC daily (n=1225) | M184V: 3.6% (1/28) | 0.1% (1/1,225)
Hosek 2017^93^; Project PrEPare, ATN 110; Observational | A: TDF-FTC daily (n=200) | Antiretroviral drug resistance (not specified): 0% (0/4) | 0% (0/200)
Hosek 2017^92^; Project PrEPare, ATN 113; Observational | A: TDF-FTC daily (n=78) | Antiretroviral drug resistance to TDF or FTC: 0% (0/3) | 0% (0/78)
Liu 2016^81^; Observational | A: TDF-FTC daily (n=383) | Antiretroviral drug resistance to TDF or FTC: 0% (0/2) | 0% (0/383)
Montgomery 2016^127^; Observational | A: TDF-FTC daily (n=35) | M184V, D67N, T215S, and K219Q: 100% (1/1) | 2.0% (1/50)

* Includes two persons in placebo group who were HIV-infected at enrollment.

† Excludes one person on PrEP and four persons in placebo group who were HIV-infected at enrollment.

‡ Includes 2 persons in TDF-FTC and 8 persons in placebo group who were HIV-infected at enrollment; all cases of resistance occurred in persons who were HIV-infected at enrollment.

§ Includes 5 persons on TDF, 3 persons on FTC-TDF, and 6 persons on placebo who had HIV infection at enrollment; K65R and M184V mutations occurred in persons with HIV infection at randomization.

║ Includes 2 persons in TDF group who were HIV-infected at enrollment or at 4-week visit; both mutations occurred in both persons.

¶ Includes 1 person in TDF-FTC group and 2 persons in placebo group who were HIV-infected at enrollment.

# HIV-infected at enrollment.

** Includes 5 patients randomized to TDF, 9 patients randomized to TDF-FTC, and 1 patient randomized to placebo who were HIV-infected at time of enrollment; two cases of M184V mutations and 1 case of M184I mutation occurred in persons who were HIV infected at time of enrollment.

Abbreviations: FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; NR=not reported; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; iPrEx-OLE=Pre-Exposure Prophylaxis Initiative–Open Label Extension; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Resistance rates were low with either TDF or TDF-FTC, based on a denominator of the total number of patients randomized to PrEP. In four trials of TDF, two patients had resistance mutations (0.06% [2/3,149]).^70,76,85,97^ In seven trials of TDF-FTC, 14 patients had resistance mutations (0.3% [14/5,085]).^52,70,76,78,100,119,120^ Data were insufficient to determine how rates of antiretroviral resistance differed for daily versus event-driven PrEP. The only trial of event-driven PrEP reported 2 cases of HIV infection among patients randomized to PrEP, with no resistance mutation identified.^52^

The trials also reported the rate of resistance mutations, based on a denominator of patients randomized to PrEP with newly diagnosed HIV infection. In nine trials of patients randomized to TDF or TDF-FTC, 1.1 percent (3/282) of patients with newly diagnosed HIV infection on PrEP were diagnosed with tenofovir resistance mutations.^52,70,76,78,97,100,117,119,120^ In seven of the trials, there were no cases of tenofovir resistance mutations (n=198),^52,76,78,97,100,120^ and two trials reported 1 or 2 cases (n=10^119^ and n=35^70^). Two of the 3 cases of tenofovir resistance were infected with HIV upon trial enrollment, presumably as a result of undiagnosed acute infection. Both involved the K65R mutation (including 1 case of multiple resistance mutations to K65R, M184V, and A62V).^70,119^ No other case of multidrug resistance was identified in patients randomized to PrEP. The third case of tenofovir resistance, which was not infected with HIV upon trial enrollment, had the K65N mutation.^70^

In six trials of PrEP with TDF-FTC, 8 percent (14/174) of patients diagnosed with HIV infection after initiating PrEP were diagnosed with emtricitabine resistance mutations (M184I or M184V).^52,70,76,78,100,119,120^ The number of cases of emtricitabine resistance in each trial ranged from 0 to 4. Nine of the 14 cases of emtricitabine resistance occurred in persons who were infected with HIV upon trial enrollment, including 1 case of multiple resistance mutations described above.

Data on drug resistance mutations were also available from the iPrEX-OLE observational study,^125^ which enrolled patients (n=1,225) from the United States, South Africa, South America, and Thailand, and four U.S.-based observational studies (total N=696) (Table 9).^81,92,93,127^ All of the observational studies evaluated PrEP with daily TDF-FTC. Among a total of 1,936 patients receiving PrEP across the observational studies, two were diagnosed with an antiretroviral drug resistance mutation (0.1%). In iPrEx-OLE, one of 28 patients (3.6%) diagnosed with HIV infection had the M184V mutation.^125^ Among the four U.S.-based studies, one of 10 patients diagnosed with HIV infection while on PrEP was found to have multiple antiretroviral drug mutations.^127^

No study was designed to evaluate the effects of antiretroviral drug resistance while receiving PrEP on clinical outcomes. However, the number of cases of HIV infections prevented by PrEP in clinical trials appears to greatly outnumber the cases of antiretroviral drug resistance. For example, based on data from the Partners PrEP trial, there were an estimated 123 cases of HIV infection averted, compared with 5 cases of drug resistance.^103^ The Partners PrEP trial also found that PrEP-selected mutations were no longer detectable by 6 months after discontinuation of PrEP and remained undetectable through 12 and 24 months.^150^ No study evaluated whether PrEP-selected mutations that become undetectable following cessation of PrEP reappear upon re-exposure to ART.