# Chapter 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^69^ the USPSTF and the Agency for Healthcare Research and Quality determined the scope and Key Questions for this review. Investigators created an analytic framework with the Key Questions and the patient populations, interventions, and outcomes reviewed (Figure 1). Key informants were surveyed for input, and the draft research plan was posted for public comment before finalization.

Figure 1 Analytic Framework

Note: The numbers on the analytic framework correspond to the numbers of the key questions.

*Harms also include renal insufficiency, fractures, pregnancy-related outcomes, infection with antiretroviral drug–resistant HIV, gastrointestinal harms, headaches, and discontinuation due to adverse events.

Abbreviations: PrEP=pre-exposure prophylaxis; STI=sexually transmitted infection.

The analytic framework depicts the relationship between the population, intervention, outcomes, and harms of pre-exposure prophylaxis (PrEP) for the prevention of HIV infection. The far left of the framework describes the target population as persons without pre-existing HIV infection. To the right of the population is an arrow which represents assessment of patients for use of PrEP (key question 2) which leads to boxes representing candidate for PrEP or not a candidate for PrEP. From the candidate for PrEP population box, an arrow representing the use of PrEP to reduce risk for HIV infection leads to the effects of PrEP on the clinical outcomes of HIV infection, quality of life, and mortality (key question 1; and also key questions 1a and 1b for whether population subgroups and dosing strategy or regimen affect effectiveness), and the assessment of any potential harms of PrEP (key question 5), which include other STIs, renal insufficiency, fractures, pregnancy-related outcomes, infection with antiretroviral drug–resistant HIV, gastrointestinal harms, headaches, and discontinuation due to adverse events. Adherence is represented in the center of the figure, as key questions 3 and 4 address the rates of adherence in U.S.-relevant populations and the association between adherence and effectiveness, respectively.

### Key Questions

1. What are the benefits of PrEP in persons without pre-existing HIV infection versus placebo or no PrEP (including deferred PrEP) on the prevention of HIV infection and quality of life?
  a. How do the benefits of PrEP differ by population subgroups?
  b. How do the benefits of PrEP differ by dosing strategy or regimen?
2. What is the diagnostic accuracy of provider or patient risk assessment tools in identifying persons at increased risk of HIV acquisition who are candidates for PrEP?
3. What are rates of adherence to PrEP in U.S. primary care–applicable settings?
4. What is the association between adherence to PrEP and effectiveness for preventing HIV acquisition?
5. What are the harms of PrEP versus placebo or no PrEP when used for the prevention of HIV infection?

### Contextual Questions

Two Contextual Questions were requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology.

1. What factors are associated with increased or decreased adherence to PrEP?
2. What is the risk of infection with antiretroviral drug–resistant HIV in persons treated with PrEP, and what is the effect of infection with PrEP-related, antiretroviral drug–resistant HIV on treatment outcomes?

## Search Strategies

We searched MEDLINE, the Cochrane Database of Systematic Reviews, the Cochrane Central Register of Controlled Trials, and Embase from inception through June 2018. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles.

After June 2018, we conducted surveillance through article alerts and targeted searches of high-impact journals to identify major studies that may affect conclusions. The last surveillance was conducted on January 25, 2019. Surveillance identified no primary research meeting inclusion criteria for this review.

## Study Selection

All titles and abstracts identified through searches were independently reviewed by two members of the research team for eligibility against predefined inclusion and exclusion criteria, as specified using the PICOTS (population, intervention, comparator, outcome, timing, study design) framework (Appendix A2). Studies marked for possible inclusion by any reviewer underwent full-text review. All results were tracked in an EndNote^®^ database (Thomson Reuters, New York, NY). We excluded non-English–language articles and studies published only as conference abstracts.

Each full-text article was independently reviewed by two members of the research team for inclusion or exclusion on the basis of the eligibility criteria. If the reviewers disagreed, conflicts were resolved by discussion and consensus or by consulting another member of the review team. Results of the full-text review were also tracked in the EndNote database, including the reason for exclusion for full-text publications. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists the included studies, and Appendix A5 lists the excluded studies with reasons for exclusion.

## Scope of Review

The PrEP interventions addressed in this report are oral daily TDF-FTC, the only antiretroviral regimen currently approved by the FDA for PrEP, as well as alternative TDF-FTC dosing schedules (e.g., event-driven [on-demand]^52^ or intermittent dosing^53,54^), which are not approved by the FDA but have been evaluated in randomized, controlled trials (RCTs) and adopted in some countries. Oral TDF monotherapy was also included, even though it is not approved by the FDA for PrEP, since it has been evaluated in several randomized trials, a large trial found no clear difference between TDF and TDF-FTC in effects on risk of HIV acquisition,^70^ and it is an option for PrEP in persons who inject drugs and heterosexual men and women in the 2017 United States Public Health Service guideline.^60^ We conducted stratified analyses for all outcomes according to the regimen used (TDF-FTC or TDF) as well as the dosing regimen (daily or event-driven/intermittent). We did not include other oral PrEP regimens (e.g., regimens with tenofovir alafenamide or containing maraviroc^71^) or delivery methods (e.g., long-acting injectables,^55^ intravaginal ring,^72–74^ or vaginal gel^75–77^), which are not approved by the FDA or recommended in other countries. The main comparison was PrEP versus placebo; one trial compared PrEP with no (delayed) PrEP.^78^ To address effects of dosing method on effectiveness, we also included randomized trials of daily versus nondaily (intermittent or event-driven) PrEP.

The population of interest for PrEP was HIV-uninfected persons at higher risk of HIV acquisition. The review assessed evidence on PrEP in adults, including HIV-uninfected pregnant women and HIV-uninfected women seeking to become pregnant with an HIV-infected partner, as well as adolescents (defined as ages 13 to <18 years). Patient subgroups of interest were based on demographic characteristics (age, sex, race/ethnicity, and pregnancy status) and HIV risk category. For the Key Question on risk assessment, we included studies on the diagnostic accuracy of provider or patient assessment instruments to predict HIV acquisition, to identify potential candidates for PrEP.

The primary outcome was the rate of HIV infection; other outcomes were mortality, quality of life, and harms, including rates of non-HIV STIs (gonorrhea, syphilis, chlamydia, herpes simplex virus [HSV] infection, or any STI), hepatitis C virus infection, renal insufficiency, fractures, gastrointestinal adverse events, and pregnancy-related outcomes. HSV infection is addressed as a potential harm because of possible effects of behavioral risk compensation, although tenofovir may have antiviral effects that decrease risk of HSV transmission.^79,80^ We also addressed the association between adherence and effectiveness of PrEP and rates of adherence to PrEP in U.S. primary care–applicable settings. Methods for measuring adherence include patient diaries and self-report, pill counts, adherence monitoring devices, drug levels (e.g., plasma or dried blood spots), and prescription fill data. A Contextual Question addresses factors (e.g., demographic factors or sexual or drug use behaviors) associated with increased or decreased adherence to PrEP.^81^ Condom use was not included as an outcome because effects on rates of HIV and other STIs are directly addressed. A Contextual Question addresses the association between use of PrEP and presence of antiretroviral drug resistance, as well as effects of infection with antiretroviral drug–resistant HIV infection on clinical outcomes. This is not addressed as a Key Question because antiretroviral resistance due to PrEP appears to be uncommon, effects of antiretroviral resistance on clinical outcomes depend on a variety of factors (e.g., type of resistance mutation, availability of alternative antiviral regimens, and adherence to alternative regimens), and evidence on effects of resistance due to PrEP on clinical outcomes appears to be very limited.^82^

To assess applicability, we abstracted data regarding the countries in which studies were performed, the demographic characteristics of the patients enrolled, the PrEP interventions used, and rates of HIV acquisition, adherence, and use of postexposure prophylaxis.

We included randomized trials of PrEP versus placebo or no PrEP. For evaluation of adherence, we also included longitudinal U.S.-based PrEP implementation studies.^83,84^

## Data Abstraction and Quality Rating

For studies meeting inclusion criteria, we created data abstraction forms to summarize characteristics of study populations, interventions, comparators, adherence, and method for assessing adherence, outcomes, study designs, settings, and methods. One investigator conducted data abstraction, which was reviewed for completeness and accuracy by another team member. For one trial that reported total numbers of adverse events, we contacted the study funding agency for per-person adverse event rates.^85^

Predefined criteria were used to assess the quality of individual controlled trials, systematic reviews, and observational studies by using criteria developed by the USPSTF; studies were rated as “good,” “fair,” or “poor” based on the seriousness of methodological shortcomings (Appendix A6).^69^ We evaluated the credibility of subgroup analyses based on whether the subgroups were predefined, whether subgroup characteristics were measured at baseline, whether the analyses were across or within studies, whether within-study comparisons were randomized, whether statistical tests for interaction were significant, the precision of estimates, the consistency of subgroup effects across studies, and whether results are biologically plausible.^86^ For each study, quality assessment was performed by two team members. Any disagreements were resolved by consensus.

## Data Synthesis

We conducted meta-analyses to calculate risk ratios for effects of PrEP on HIV infection, mortality, and harms using the DerSimonian and Laird random-effects model with Review Manager Version 5.3 software (The Cochrane Collaboration Nordic Cochrane Centre, Copenhagen, Denmark). Statistical heterogeneity was assessed using the I^2^ statistic.^87^ When the I^2^ was greater than 30 percent, sensitivity analysis was performed with the profile likelihood method using Stata/IC Version 13.1 (StataCorp, College Station, TX), as the DerSimonian and Laird model can result in overly narrow confidence intervals (CIs) in this situation.^88^ We conducted additional sensitivity and stratified analyses based on study quality, PrEP drug regimen (TDF or TDF-FTC), HIV risk category (men who have sex with men, persons who inject drugs, and men and women at increased risk via heterosexual contact), dosing schedule (daily or event-driven/intermittent), study duration (<1 year, ≥1 to <2 years, or ≥2 years), and country (United States and other high-income countries or low-/middle-income countries and international studies). We also conducted sensitivity analyses using data from the FDA medical review of PrEP on HIV incidence and fracture rates, in place of data reported in journal articles for these outcomes.^89^ We analyzed effects of study-level adherence as a categorical variable in a stratified analysis (≥70%, >40% to <70%, or ≤40%)^90^ and as a continuous variable through meta-regression, and constructed a plot of adherence against effectiveness (log RR). Adherence was based on, in order of preference, 1) the proportion of all PrEP patients (or a random sample) with detectable plasma tenofovir levels; 2) the proportion of PrEP nonseroconverters with detectable plasma tenofovir levels, based on a random or matched (to seroconverters) sample, or the mean proportion of PrEP doses taken; 3) medication electronic monitoring system data; 4) pill counts; or 5) self-report. We performed sensitivity analysis restricted to studies that assessed adherence based on drug levels. For analyses with at least 10 trials, we constructed funnel plots and performed the Egger test to detect small sample effects (a marker for potential publication bias).^91^

For all Key Questions, the overall quality of evidence was determined using the approach described in the USPSTF Procedure Manual.^69^ Evidence was rated “good,” “fair,” or “poor” based on the number, quality and size of studies, consistency of results between studies, and directness of evidence.^69^

## External Review

The draft report was reviewed by content experts (Appendix A7), USPSTF members, Agency for Healthcare Research and Quality Project Officers, and collaborative partners, and posted for public comment. The report was revised in response to comments before finalization.

## Response to Public Comments

The draft report was posted for public comment from November 20, 2018 to December 26, 2018, and few comments were received. In response to the comments, we added a reference to the WHO implementation tool,^62^ clarified that STI testing in persons taking PrEP is every 3 to 6 months, and for studies of PrEP in adolescents,^92–94^ corrected the trial names in the evidence tables and clarified funding sources.