# Chapter 1 Introduction and Background

## Purpose

Effective prevention strategies for HIV infection are an important public health priority. Pre-exposure prophylaxis (PrEP) involves use of antiretroviral therapy (ART) regularly (e.g., daily) or before and after HIV exposure events (known as “on-demand” or “event-driven” PrEP) to decrease the risk of acquiring HIV infection. The purpose of this report is to synthesize evidence on effects of PrEP on risk of HIV acquisition, mortality, harms, and other clinical outcomes; effects of adherence on PrEP-associated outcomes; and accuracy of methods for identifying potential candidates for PrEP. It will be used by the U.S. Preventive Services Task Force (USPSTF) to develop a new recommendation on PrEP for the prevention of HIV infection, focusing on provision of PrEP in primary care settings.

## Condition Background

### Condition Definition

HIV is a ribonucleic acid retrovirus that infects immune cells in humans—in particular, CD4+ T helper cells (referred to as CD4 count in this report). Untreated, HIV infection results in progressive immunodeficiency and AIDS in more than 90 percent of patients. AIDS is a potentially life-threatening condition that occurs when HIV becomes severe, as defined by a CD4 count of 200 cells/mm^3^ or one or more AIDS-defining neoplastic conditions or opportunistic infections.^1^ HIV-1 infection is the most common variant in the United States. HIV-2 infection is rare in the United States, less clinically severe, and endemic in parts of West Africa.^2^

### Prevalence and Burden of Disease/Illness

Since the first cases of AIDS were reported in 1981, more than 700,000 persons diagnosed with AIDS in the United States have died.^3^ The Centers for Disease Control and Prevention (CDC) estimates that approximately 1.1 million persons in the United States were living with HIV infection in 2015,^3^ including 15 percent who were unaware of their infection.^4^ This represents a decrease since 2008, when approximately 20 percent of infected persons were estimated to be unaware of their HIV-infected status.^5–7^ The number of new HIV infections annually in the United States has decreased slightly in recent years, from about 42,000 infections in 2011 to 40,000 each year from 2013 to 2016.^3^ Approximately 530,000 persons were living with AIDS in 2015.

Groups more affected by HIV infection in the United States include men who have sex with men and black and Hispanic/Latino persons. Between 2006 and 2009, there was a 21 percent increase in HIV incidence among persons ages 13 to 29 years, driven largely by a 34 percent increase among men who have sex with men, the only risk group to experience a significant increase in incidence during this period (p<0.001).^8^ In 2016, of total HIV diagnoses, 32,131 (81%) were among adult and adolescent males (age 13 years or older), 7,529 (19%) were among adult and adolescent females, and 122 (0.3%) were among children younger than age 13 years.^3^ Persons ages 20 to 34 years accounted for half of the new diagnoses and had the highest incidence of HIV infection (26.2 to 34.8 cases per 100,000 persons). Among adolescents, the incidence of HIV infection rose sharply from ages 13 to 14 years (0.3 cases per 100,000 persons) to ages 15 to 19 years (7.8 cases per 100,000 persons). By race/ethnicity, 44 percent of new diagnoses occurred among black persons, 26 percent among white persons, and 25 percent among Hispanic/Latino persons.^3^ Among men, having sex with men is the most common transmission method (83%), followed by heterosexual contact (9.4%), injection drug use (4.0%), and having sex with men and injection drug use together (3.7%). Among females, heterosexual contact is the most common transmission method (87%), followed by injection drug use (12%).

### Etiology and Natural History

HIV infection is acquired through mucosal or intravenous exposure to infected bodily fluids such as blood, semen, and genital tract secretions. Factors facilitating sexual transmission include the presence of sexually transmitted infections (STIs), certain sexual practices (e.g., penile-anal or penile-vaginal intercourse without a condom, sex with multiple partners, sex with persons with HIV or at high risk of HIV infection), and high viral load in the infected partner.^9,10^ In persons who inject drugs, factors associated with HIV infection include increased frequency or duration of injection behaviors, sharing needles, and backloading (injecting drugs from one syringe into the back of another opened syringe).^11^

The primary HIV infection syndrome usually develops 2 to 4 weeks following initial exposure to HIV.^12^ Acute infection is often associated with a clinical syndrome resembling infectious mononucleosis.^13,14^ Very early after acute infection, there is rapid virus production that then declines to a set point (which varies between individuals) as the host immune system responds, although continuous rapid virus production and clearance occurs at all stages of infection.^15–20^

Although a small proportion of untreated HIV-infected persons remain asymptomatic and show little evidence of progressive immune suppression after 10 or more years of infection, more than 90 percent of untreated patients eventually develop AIDS.^1^ In the era before highly active antiretroviral therapy (HAART) was available, the median time from seroconversion to the development of AIDS was 7.7 to 11.0 years, and median survival was 7.5 to 12 years.^21,22^

The primary mechanism through which chronic HIV infection causes immune deficiency is via a decrease in the level and functioning of CD4 cells. In untreated HIV infection, the CD4 count declines an average of 50 to 75 cells/mm^3^ per year.^23^ Most patients with CD4 counts over 200 cells/mm^3^ are either asymptomatic or have mild disease,^24^ although research indicates an increased risk of AIDS or death even in patients with CD4 counts over 500 cells/mm^3^.^25^ Patients with CD4 counts less than 200 cells/mm^3^ have advanced immunodeficiency and are at markedly increased risk of AIDS-related opportunistic infections, other AIDS-related complications, and AIDS-associated mortality.^26–28^

A higher HIV viral load is a strong independent predictor of more rapid progression to AIDS.^26–31^ Other predictors of more rapid progression include older age at the time of infection,^21,22,26,27,30,32,^ ^33^ more severe symptoms at the time of primary HIV infection,^34^ and other clinical and genetic factors. A factor associated with slow progression is the cysteine-cysteine chemokine receptor 5 delta32 genotype.^35–39^

### Risk Factors

Persons at increased risk of HIV infection include men who have sex with men; men and women who have condomless vaginal or anal intercourse with more than one partner; men and women who exchange sex for drugs or money; persons with a history of or current injection drug use; persons seeking treatment for other STIs; persons with a history of blood transfusion between 1978 and 1985; persons whose past or current sexual partners are HIV-infected, bisexual, or persons who inject drugs; transgender persons; and persons who do not report one of these risk factors but who request HIV testing.^40–42^ Settings in which the prevalence of HIV infection is often more than 1 percent include STI clinics, correctional facilities, homeless shelters, tuberculosis clinics, clinics specialized in the care of sexual and gender minorities, and clinics caring for an adolescent community with a high prevalence of STIs.^43^

### Rationale for Screening/Screening Strategies/Prevention

HIV infection remains incurable and can have important health consequences. Therefore, preventing HIV infection is an important public health and clinical priority. In the absence of an effective vaccine, HIV prevention strategies include screening, as recommended by the USPSTF^44^ and others, to identify infected persons; treatment with ART in HIV-infected persons to reduce risk of transmission;^45^ and behavioral counseling to reduce high-risk sexual and drug use behaviors.

For persons at substantial risk of HIV infection who are not infected, another promising preventive strategy is PrEP with ART in combination with risk behavior counseling, to reduce risk of acquiring HIV infection.^46^ PrEP involves use of ART on an ongoing, regular (e.g., daily) basis or before and after HIV exposure events to lower the likelihood of acquiring HIV infection. It differs from nonoccupational postexposure prophylaxis, which involves use of ART for 28 days after a single high-risk exposure.^47^

### Intervention/Treatment

The most commonly studied antiretroviral regimen for PrEP is a daily oral fixed-dose combination of tenofovir disoproxil fumarate (TDF), a prodrug of tenofovir, and emtricitabine (FTC). This combination was selected because of its effectiveness as part of ART for HIV infection, favorable safety profile, relatively high genetic barrier to resistance, and achievement of high concentrations in rectal tissue (TDF) and female genital tissue (FTC).^48^ In 2012, the U.S. Food and Drug Administration (FDA) approved daily oral TDF-FTC for PrEP in adults at risk of sexual acquisition.^49^ In 2018, the FDA expanded the indication for PrEP to include adolescents weighing at least 35 kg (77 lb).^50^ Because effectiveness of PrEP depends on adherence,^51^ there is also interest in nondaily oral regimens that may enhance adherence while maintaining effectiveness of PrEP, such as on-demand or event-driven^52^ (taken before and after an anticipated HIV exposure event) or intermittent (scheduled, nondaily) dosing of TDF-FTC.^53,54^ Research is also ongoing on alternative, nonoral modes of PrEP administration that require infrequent dosing (e.g., long-acting injectables^55^ or an intravaginal ring^56^).

Factors that may affect the balance of benefits and harms in persons prescribed PrEP include adverse drug-related events, the potential for antiretroviral resistance in persons who acquire HIV while taking PrEP, and the potential for behavioral risk compensation. Behavioral risk compensation refers to an increase in behaviors associated with HIV transmission (e.g., sex without a condom or multiple sexual partners). Because PrEP does not protect against STIs such as syphilis, chlamydia, and gonorrhea, behavioral risk compensation could increase the rate of STIs, in addition to attenuating HIV prevention benefits. PrEP could induce antiretroviral resistance as a result of inadequate treatment in HIV-infected persons who inadvertently receive PrEP or in HIV-uninfected persons who acquire infection while on PrEP. Adverse effects of TDF include negative effects on bone mass and kidney function.^57–59^

### Current Clinical Practice

In 2014, the United States Public Health Service issued a guideline recommending PrEP with TDF-FTC in adults at high risk of infection, including men who have sex with men with a high number of sexual partners or inconsistent condom use, men who have sex with men and heterosexual persons in HIV-serodiscordant relationships, other high-risk heterosexual persons, and persons who inject drugs and share injection equipment; the guideline was updated in 2017.^60^ The guideline also includes TDF alone as an option for PrEP in persons who inject drugs and heterosexual men and women. Criteria for PrEP in different HIV risk categories are shown in Table 1. The guideline recommends that providers engage in shared decisionmaking with pregnant women who are beginning or continuing PrEP during pregnancy.^60^ Although FDA labeling information and perinatal antiretroviral treatment guidelines permit use of TDF-FTC during pregnancy, the guideline notes that data on safety of PrEP use during pregnancy are limited. The guideline states that data on the efficacy and safety of PrEP in adolescents are insufficient, but were developed before expansion of FDA approval of TDF-FTC for PrEP in adolescents weighing at least 35 kg.

Table 1 Summary of U.S. Public Health Service Guidance on Use of PrEP

Guidance for | Details
Detecting substantial risk of acquiring HIV infection | Men who have sex with men:; - HIV-infected sexual partner; - Recent bacterial STI^*^; - High number of sexual partners; - History of inconsistent or no condom use; - Commercial sex work; Heterosexual women and men:; - HIV-infected sexual partner; - Recent bacterial STI^†^; - High number of sexual partners; - History of inconsistent or no condom use; - Commercial sex work; - In high-prevalence area or network; Persons who inject drugs:; - HIV-positive drug injection partner; - Sharing injection equipment
Clinically eligible | - Documented negative HIV test result before prescribing PrEP; - No signs/symptoms of acute HIV infection; - Normal renal function; no contraindicated medications; - Documented hepatitis B virus infection and vaccination status
Prescription | Daily, continuing, oral doses of TDF-FTC (Truvada®), ≤90-day supply
Other services | - Followup visits at least every 3 months to provide the following: HIV test, medication adherence counseling, behavioral risk reduction support, side effect assessment, and STI symptom assessment; - At 3 months and every 6 months thereafter, assess renal function; - Every 3 to 6 months, test for bacterial STIs; Men who have sex with men: Oral/rectal STI testing; Heterosexual women and men: For women, assess pregnancy intent; pregnancy test every 3 months; Persons who inject drugs: Access to clean needles/syringes and drug treatment services

Source: U.S. Public Health Service, Centers for Disease Control and Prevention, 2017.^60^

* Gonorrhea, chlamydia, and syphilis for men who have sex with men, including those who inject drugs.

† Gonorrhea and syphilis for heterosexual women and men, including those who inject drugs.

Abbreviations: PrEP=pre-exposure prophylaxis; STI=sexually transmitted infection; TDF-FTC=tenofovir disoproxil fumarate-emtricitabine.

A 2012 World Health Organization guideline recommends PrEP in persons at high risk of sexual acquisition of HIV infection.^61^ The World Health Organization has also issued an implementation tool for PrEP.^62^

Recent data indicate that implementation of PrEP in the United States remains limited. The CDC estimated approximately 1.2 million persons were eligible for PrEP in 2015 (492,000 men who have sex with men, 115,000 persons who inject drugs, and 624,000 heterosexually active adults), but only an estimated 125,000 had active PrEP prescriptions.^63,64^ Evidence from clinicians in the United States, particularly among primary care providers, indicate gaps in knowledge and uptake of PrEP.^65^ A survey of more than 500 providers in 10 U.S. cities during 2014 to 2015 found that compared with HIV providers, primary care providers were less likely to have heard of PrEP (76% vs. 98%), feel familiar with prescribing PrEP (28% vs. 76%), or had prescribed it (17% vs. 64%).^66^ Primary care providers were also less comfortable than HIV providers with discussing sexual activities (75% vs. 98%). Barriers to prescribing by primary care providers included limited knowledge about PrEP and concerns about insurance coverage. A 2015 survey of academic primary care providers (n=266) found that 93 percent were familiar with PrEP; of those, about one-third reported adoption of PrEP.^67^ Adopters were more likely to provide care to more than 50 HIV-infected patients, report good or excellent knowledge of PrEP, perceive PrEP as safe, and not perceive PrEP as increasing risky behaviors. Another survey of 280 primary care providers from high HIV incidence areas in 10 U.S. cities found that one-third had discussed PrEP and 17 percent had prescribed PrEP.^68^ Prescribing was associated with greater knowledge about PrEP, positive attitudes toward PrEP, and confidence in prescribing PrEP.