# Appendix C Figures

Appendix C Figure 1 Funnel Plot: HIV Infection

Abbreviation: s.e.=standard error.

Appendix C1 is a funnel plot of HIV infection. There are circular symbols representing individual studies, plotted on an x-axis of logRR (from −4 to 4) and a y-axis of the standard error of the logRR (from 1.5 to 0). Funnel plot asymmetry was present and the test for small sample effects was statistically significant (Egger test p value=0.03).

Appendix C Figure 2 Funnel Plot: Mortality

Abbreviations: FTC=emtricitabine; RR=relative risk; SE=standard error; TDF=tenofovir disoproxil.

Appendix C2 is a funnel plot of mortality. There are circular symbols representing individual TDF studies, and square symbols representing individual FTC-TDF studies. All are plotted on an x-axis of RR (from 0.01 to 100) and a y-axis of the standard error of the logRR (from 2 to 0). There was no funnel plot asymmetry.

Appendix C Figure 3 Funnel Plot: Serious Adverse Events

Abbreviation: s.e.=standard error.

Appendix C3 is a funnel plot of serious adverse events. There are circular symbols representing individual studies, plotted on an x-axis of logRR (from −4 to 4) and a y-axis of the standard error of the logRR (from 1.5 to 0). There was no funnel plot asymmetry.

Appendix C Figure 4 Funnel Plot: Renal Adverse Events

Abbreviation: s.e.=standard error.

Appendix C4 is a funnel plot of renal adverse events. There are circular symbols representing individual studies, plotted on an x-axis of logRR (from −4 to 4) and a y-axis of the standard error of the logRR (from 2 to 0). There was no funnel plot asymmetry.

Appendix C Figure 5 Funnel Plot: Gastrointestinal Adverse Events

Abbreviation: s.e.=standard error.

Appendix C5 is a funnel plot of gastrointestinal adverse events. There are circular symbols representing individual studies, plotted on an x-axis of logRR (from −2 to 4) and a y-axis of the standard error of the logRR (from 1.5 to 0). There was no funnel plot asymmetry.