# Appendix B Evidence Tables and Quality Tables

Appendix B Table 1 HIV Pre-Exposure Prophylaxis Randomized, Controlled Trials: Study Characteristics

Appendix B Table 2 HIV Pre-Exposure Prophylaxis Randomized, Controlled Trials: Results

Appendix B Table 3 HIV Pre-Exposure Prophylaxis Randomized, Controlled Trials: Additional Information on Adherence and Subgroups

Appendix B Table 4 HIV Pre-Exposure Prophylaxis Randomized, Controlled Trials: Quality Assessment

Appendix B Table 5 Diagnostic Accuracy of HIV Risk Assessment Tools: Study Characteristics

Appendix B Table 6 Diagnostic Accuracy of HIV Risk Assessment Tools: Results

Appendix B Table 7 Diagnostic Accuracy of HIV Risk Assessment Tools: Quality Assessment

Appendix B Table 8 HIV Pre-Exposure Prophylaxis Cohort Studies: Study Characteristics

Appendix B Table 9 HIV Pre-Exposure Prophylaxis Cohort Studies: Results

Appendix B Table 10 HIV Pre-Exposure Prophylaxis Cohort Studies: Adherence

Appendix B Table 11 HIV Pre-Exposure Prophylaxis Cohort Studies: Quality Assessment