# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Key Questions 1, 3-5

#### Database: Ovid MEDLINE(R) without Revisions

1. exp Pre-Exposure Prophylaxis/
2. (preexposure prophylaxis or prep).ti,ab.
3. Anti-HIV Agents/
4. (hiv or “human immunodeficiency virus”).ti,ab.
5. (1 or 2) and (3 or 4)
6. limit 5 to english language

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Pre-Exposure Prophylaxis/
2. (preexposure prophylaxis or prep).ti,ab.
3. Anti-HIV Agents/
4. (hiv or “human immunodeficiency virus”).ti,ab.
5. (1 or 2) and (3 or 4)
6. limit 5 to english language

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. (preexposure prophylaxis or prep).mp.
2. (hiv or “human immunodeficiency virus”).mp.
3. 1 and 2

#### Database: Elsevier Embase

‘pre-exposure prophylaxis’/exp OR ‘pre-exposure prophylaxis’ AND ‘human immunodeficiency virus’/exp AND [embase]/lim NOT [medline]/lim AND (‘article’/it OR ‘article in press’/it OR ‘conference paper’/it OR ‘conference review’/it OR ‘editorial’/it OR ‘letter’/it OR ‘review’/it OR ‘short survey’/it)

### Key Question 2

#### Database: Ovid MEDLINE(R) without Revisions

1. exp HIV Infections/
2. (hiv or “human immunodeficiency virus”).mp.
3. exp Risk/
4. (“risk assessment” or “risk factors”).mp.
5. exp “Sensitivity and Specificity”/
6. (sensitivity or specificity or “diagnostic accuracy”).mp.
7. (1 or 2) and (3 or 4) and (5 or 6)
8. limit 7 to yr="2005 - 2018"

## Appendix A2 Inclusion and Exclusion Criteria

| Included | Excluded
Populations | Adolescents (ages 13 to <18 years) and adults (age ≥18 years) without pre-existing HIV infection at increased risk of HIV acquisition^*^ | Persons living with HIV, children
Interventions | Daily or on-demand/intermittent oral antiretroviral therapy with TDF-FTC or TDF | Other PrEP regimens
Comparisons | Placebo or no PrEP (including deferred PrEP) | One PrEP regimen vs. another
Outcomes | Risk of HIV acquisition, quality of life, risk of other sexually transmitted infections, risk of hepatitis C virus infection, renal insufficiency, fracture, pregnancy-related outcomes, and adherence^†^ to PrEP regimen | Outcomes not listed, including condom use
Setting | All KQs: Settings in which PrEP is delivered in ways applicable to U.S. primary care settings; KQ 3: United States or U.S.-relevant countries | Inpatient settings
Study design | Randomized, controlled trials for effectiveness and harms; controlled observational studies for harms^‡^ if randomized, controlled trials are not available; diagnostic accuracy studies for risk assessment; and longitudinal studies (randomized, controlled trials and controlled or uncontrolled cohort studies) for adherence

* Including pregnant women.

† Measures of adherence include patient diaries or self-report, pill counts, adherence monitoring devices, biochemical measures (e.g., serum drug levels), and prescription fill data.

‡ Study must perform statistical adjustment for potential confounders to be included.

Abbreviations: KQ=key question; PrEP=pre-exposure prophylaxis; TDF=tenofovir disoproxil fumarate; TDF-FTC=emtricitabine/tenofovir disoproxil fumarate; U.S.=United States.

## Appendix A3 Literature Flow Diagram

*Other sources include reference lists of relevant articles, studies, and systematic reviews; suggestions from reviewers; and includes background articles.

^†^Some papers are included in multiple Key Questions.

^‡^22 articles also addressed the Contextual Questions, of which 19 overlap with the articles that addressed Key Questions.

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows that 3,865 citations were identified through literature database searches and 89 citations were identified through other sources. Three thousand one hundred and sixteen citations were screened after duplicates were removed, and 308 articles were reviewed at the full-text level after excluding 2,808 citations based on review of title and abstract. Two hundred and fifty two total full-text articles were excluded for the following reasons: wrong population (11), wrong intervention (19), wrong outcome (67), wrong comparator (6), wrong study design for key question (52), not a study (75), inadequate duration (3), systematic review or meta-analysis used as a source document only to identify individual studies (14), or wrong country (5). Twenty-nine studies (in 56 articles) were included that provide evidence for the key questions, as follows: 12 trials (in 33 articles) for Key Question 1, 7 studies for Key Question 2, 3 trials and 7 observational studies for Key Question 3, 7 trials (in 10 articles) and 5 observational studies for Key Question 4, and 12 trials (in 21 articles) for Key Question 5. A footnote indicates that 22 articles were used to address a Contextual Question, of which 19 overlap with the articles that addressed Key Questions.

## Appendix A4 Included Studies List

Agot K, Taylor D, Corneli AL, . Accuracy of self-report and pill-count measures of adherence in the FEM-PrEP clinical trial: implications for future HIV-prevention trials. AIDS Behav. 2015;19(5):743–51. doi: 10.1007/s10461-014-0859-z. PMID: 25100053.25100053
Baeten JM, Donnell D, Ndase P, . Antiretroviral prophylaxis for HIV-1 prevention in heterosexual men and women. N Engl J Med. 2012;367(5):399–410. doi: 10.1056/NEJMoa1108524. PMID: 22784037.22784037
Bekker LG, Roux S, Sebastien E, . Daily and non-daily pre-exposure prophylaxis in African women (HPTN 067/ADAPT Cape Town trial): a randomised, open-label, phase 2 trial. Lancet HIV. 2018;5(2):e68–e78. doi: 10.1016/S2352-3018(17)30156-X. PMID: 28986029.28986029
Beymer MR, Weiss RE, Sugar CA, . Are Centers for Disease Control and Prevention guidelines for preexposure prophylaxis specific enough? Formulation of a personalized HIV risk score for pre-exposure prophylaxis initiation. Sex Transm Dis. 2017;44(1):48–56. doi: 10.1097/olq.0000000000000535. PMID: 27898570.27898570
Celum C, Morrow RA, Donnell D, . Daily oral tenofovir and emtricitabine-tenofovir preexposure prophylaxis reduces herpes simplex virus type 2 acquisition among heterosexual HIV-1-uninfected men and women: a subgroup analysis of a randomized trial. Ann Intern Med. 2014;161(1):11–9. doi: 10.7326/M13-2471. PMID: 24979446.24979446
Chan PA, Mena L, Patel R, . Retention in care outcomes for HIV pre-exposure prophylaxis implementation programmes among men who have sex with men in three US cities. J Int AIDS Soc. 2016;19(1):20903. doi: 10.7448/IAS.19.1.20903. PMID: 27302837.27302837
Chirwa LI, Johnson JA, Niska RW, . CD4(+) cell count, viral load, and drug resistance patterns among heterosexual breakthrough HIV infections in a study of oral preexposure prophylaxis. AIDS. 2014;28(2):223–6. doi: 10.1097/QAD.0000000000000102. PMID: 24361682.24361682
Choopanya K, Martin M, Suntharasamai P, . Antiretroviral prophylaxis for HIV infection in injecting drug users in Bangkok, Thailand (the Bangkok tenofovir study): a randomised, double-blind, placebo-controlled phase 3 trial. Lancet. 2013;381(9883):2083–90. doi: 10.1016/S0140-6736(13)61127-7. PMID: 23769234.23769234
Cohen SE, Vittinghoff E, Bacon O, . High interest in preexposure prophylaxis among men who have sex with men at risk for HIV infection: baseline data from the US PrEP demonstration project. J Acquir Immune Defic Syndr. 2015;68(4):439–48. doi: 10.1097/QAI.0000000000000479. PMID: 25501614.25501614
Deutsch MB, Glidden DV, Sevelius J, . HIV pre-exposure prophylaxis in transgender women: a subgroup analysis of the iPrEx trial. Lancet HIV. 2015;2(12):e512–9. doi: 10.1016/S2352-3018(15)00206-4. PMID: 26614965.26614965
Donnell D, Baeten JM, Bumpus NN, . HIV protective efficacy and correlates of tenofovir blood concentrations in a clinical trial of PrEP for HIV prevention. J Acquir Immune Defic Syndr. 2014;66(3):340–8. doi: 10.1097/QAI.0000000000000172. PMID: 24784763.24784763
Grant RM, Anderson PL, McMahan V, . Uptake of pre-exposure prophylaxis, sexual practices, and HIV incidence in men and transgender women who have sex with men: a cohort study. Lancet Infect Dis. 2014;14(9):820–9. doi: 10.1016/S1473-3099(14)70847-3. PMID: 25065857.25065857
Grant RM, Lama JR, Anderson PL, . Preexposure chemoprophylaxis for HIV prevention in men who have sex with men. N Engl J Med. 2010;363(27):2587–99. doi: 10.1056/NEJMoa1011205. PMID: 21091279.21091279
Grant RM, Mannheimer S, Hughes JP, . Daily and nondaily oral preexposure prophylaxis in men and transgender women who have sex with men: The Human Immunodeficiency Virus Prevention Trials Network 067/ADAPT study. Clin Infect Dis. 2018;66(11):1712–21. doi: 10.1093/cid/cix1086. PMID: 29420695.29420695
Grohskopf LA, Chillag KL, Gvetadze R, . Randomized trial of clinical safety of daily oral tenofovir disoproxil fumarate among HIV-uninfected men who have sex with men in the United States. J Acquir Immune Defic Syndr. 2013;64(1):79–86. doi: 10.1097/QAI.0b013e31828ece33. PMID: 23466649.23466649
Haberer JE, Baeten JM, Campbell J, . Adherence to antiretroviral prophylaxis for HIV prevention: a substudy cohort within a clinical trial of serodiscordant couples in East Africa. PLoS Med. 2013;10(9):e1001511. doi: 10.1371/journal.pmed.1001511. PMID: 24058300.24058300
Heffron R, Mugo N, Were E, . Preexposure prophylaxis is efficacious for HIV-1 prevention among women using depot medroxyprogesterone acetate for contraception. AIDS. 2014;28(18):2771–6. doi: 10.1097/QAD.0000000000000493. PMID: 25493602.25493602
Hoenigl M, Weibel N, Mehta SR, . Development and validation of the San Diego early test score to predict acute and early HIV infection risk in men who have sex with men. Clin Infect Dis. 2015;61(3):468–75. doi: 10.1093/cid/civ335. PMID: 25904374.25904374
Hosek SG, Landovitz RJ, Kapogiannis B, . Safety and feasibility of antiretroviral preexposure prophylaxis for adolescent men who have sex with men aged 15 to 17 years in the United States. JAMA Pediatr. 2017 doi: 10.1001/jamapediatrics.2017.2007. PMID: 28873128.28873128
Hosek SG, Rudy B, Landovitz R, . An HIV preexposure prophylaxis demonstration project and safety study for young MSM. J Acquir Immune Defic Syndr. 2017;74(1):21–9. doi: 10.1097/qai.0000000000001179. PMID: 27632233.27632233
Hosek SG, Siberry G, Bell M, . The acceptability and feasibility of an HIV preexposure prophylaxis (PrEP) trial with young men who have sex with men. J Acquir Immune Defic Syndr. 2013;62(4):447–56. doi: 10.1097/QAI.0b013e3182801081. PMID: 24135734.24135734
Jones J, Hoenigl M, Siegler AJ, . Assessing the performance of 3 human immunodeficiency virus incidence risk scores in a cohort of black and white men who have sex with men in the South. Sex Transm Dis. 2017;44(5):297–302. doi: 10.1097/OLQ.0000000000000596. PMID: 28407646.28407646
Kibengo FM, Ruzagira E, Katende D, . Safety, adherence and acceptability of intermittent tenofovir/emtricitabine as HIV pre-exposure prophylaxis (PrEP) among HIV-uninfected Ugandan volunteers living in HIV-serodiscordant relationships: a randomized, clinical trial. PLoS One. 2013;8(9):e74314. doi: 10.1371/journal.pone.0074314. PMID: 24086333.24086333
Lancki N, Almirol E, Alon L, . Preexposure prophylaxis guidelines have low sensitivity for identifying seroconverters in a sample of young Black MSM in Chicago. Aids. 2018;32(3):383–92. doi: 10.1097/qad.0000000000001710. PMID: 29194116.29194116
Landovitz RJ, Beymer M, Kofron R, . Plasma tenofovir levels to support adherence to TDF/FTC preexposure prophylaxis for HIV prevention in MSM in Los Angeles, California. J Acquir Immune Defic Syndr. 2017;76(5):501–11. doi: 10.1097/QAI.0000000000001538. PMID: 28902074.28902074
Lehman DA, Baeten JM, McCoy CO, . Risk of drug resistance among persons acquiring HIV within a randomized clinical trial of single- or dual-agent preexposure prophylaxis. J Infect Dis. 2015;211(8):1211–8. doi: 10.1093/infdis/jiu677. PMID: 25587020.25587020
Liu AY, Cohen SE, Vittinghoff E, . Preexposure prophylaxis for HIV infection integrated with municipal- and community-based sexual health services. JAMA Intern Med. 2016;176(1):75–84. doi: 10.1001/jamainternmed.2015.4683. PMID: 26571482.26571482
Liu A, Glidden DV, Anderson PL, . Patterns and correlates of PrEP drug detection among MSM and transgender women in the Global iPrEx Study. J Acquir Immune Defic Syndr. 2014 Dec 2014;67(5):528–37. doi: 10.1097/QAI.0000000000000351. PMID: 25230290.25230290
Liu AY, Vittinghoff E, Sellmeyer DE, . Bone mineral density in HIV-negative men participating in a tenofovir pre-exposure prophylaxis randomized clinical trial in San Francisco. PLoS One. 2011;6(8):e23688. doi: 10.1371/journal.pone.0023688. PMID: 21897852.21897852
Mandala J, Nanda K, Wang M, . Liver and renal safety of tenofovir disoproxil fumarate in combination with emtricitabine among African women in a pre-exposure prophylaxis trial. BMC Pharmacol Toxicol. 2014;15:77. doi: 10.1186/2050-6511-15-77. PMID: 25539648.25539648
Marcus JL, Glidden DV, McMahan V, . Daily oral emtricitabine/tenofovir preexposure prophylaxis and herpes simplex virus type 2 among men who have sex with men. PLoS One. 2014;9(3):e91513. doi: 10.1371/journal.pone.0091513. PMID: 24637511.24637511
Marrazzo JM, Ramjee G, Richardson BA, . Tenofovir-based preexposure prophylaxis for HIV infection among African women. N Engl J Med. 2015;372(6):509–18. doi: 10.1056/NEJMoa1402269. PMID: 25651245.25651245
Martin M, Vanichseni S, Suntharasamai P, . Factors associated with the uptake of and adherence to HIV pre-exposure prophylaxis in people who have injected drugs: an observational, open-label extension of the Bangkok Tenofovir Study. Lancet HIV. 2017;4(2):e59–e66. doi: 10.1016/s2352-3018(16)30207-7. PMID: 27866873.27866873
Martin M, Vanichseni S, Suntharasamai P, . Renal function of participants in the Bangkok tenofovir study--Thailand, 2005-2012. Clin Infect Dis. 2014;59(5):716–24. doi: 10.1093/cid/ciu355. PMID: 24829212.24829212
Martin M, Vanichseni S, Suntharasamai P, . The impact of adherence to preexposure prophylaxis on the risk of HIV infection among people who inject drugs. AIDS. 2015;29(7):819–24. doi: 10.1097/QAD.0000000000000613. PMID: 25985403.25985403
Matthews LT, Heffron R, Mugo NR, . High medication adherence during periconception periods among HIV-1-uninfected women participating in a clinical trial of antiretroviral pre-exposure prophylaxis. J Acquir Immune Defic Syndr. 2014;67(1):91–7. doi: 10.1097/QAI.0000000000000246. PMID: 25118795.25118795
McCormack S, Dunn DT, Desai M, . Pre-exposure prophylaxis to prevent the acquisition of HIV-1 infection (PROUD): effectiveness results from the pilot phase of a pragmatic open-label randomised trial. Lancet. 2016;387(10013):53–60. doi: 10.1016/S0140-6736(15)00056-2. PMID: 26364263.26364263
Menza TW, Hughes JP, Celum CL, . Prediction of HIV acquisition among men who have sex with men. Sex Transm Dis. 2009;36(9):547–55. doi: 10.1097/OLQ.0b013e3181a9cc41. PMID: 19707108.19707108
Mirembe BG, Kelly CW, Mgodi N, . Bone mineral density changes among young, healthy African women receiving oral tenofovir for HIV preexposure prophylaxis. J Acquir Immune Defic Syndr. 2016;71(3):287–94. doi: 10.1097/QAI.0000000000000858. PMID: 26866954.26866954
Molina JM, Capitant C, Spire B, . On-demand preexposure prophylaxis in men at high risk for HIV-1 Infection. N Engl J Med. 2015;373(23):2237–46. doi: 10.1056/NEJMoa1506273. PMID: 26624850.26624850
Montgomery MC, Oldenburg CE, Nunn AS, . Adherence to pre-exposure prophylaxis for HIV prevention in a clinical setting. PLoS One. 2016;11(6):e0157742. doi: 10.1371/journal.pone.0157742. PMID: 27333000.27333000
Mugo NR, Hong T, Celum C, . Pregnancy incidence and outcomes among women receiving preexposure prophylaxis for HIV prevention: a randomized clinical trial. JAMA. 2014;312(4):362–71. doi: 10.1001/jama.2014.8735. PMID: 25038355.25038355
Mugwanya KK, Wyatt C, Celum C, . Changes in glomerular kidney function among HIV-1-uninfected men and women receiving emtricitabine-tenofovir disoproxil fumarate preexposure prophylaxis: a randomized clinical trial. JAMA Intern Med. 2015;175(2):246–54. doi: 10.1001/jamainternmed.2014.6786. PMID: 25531343.25531343
Mulligan K, Glidden DV, Anderson PL, . Effects of emtricitabine/tenofovir on bone mineral density in HIV-negative persons in a randomized, double-blind, placebo-controlled trial. Clin Infect Dis. 2015;61(4):572–80. doi: 10.1093/cid/civ324. PMID: 25908682.25908682
Murnane PM, Celum C, Mugo N, . Efficacy of preexposure prophylaxis for HIV-1 prevention among high-risk heterosexuals: subgroup analyses from a randomized trial. AIDS. 2013;27(13):2155–60. doi: 10.1097/QAD.0b013e3283629037. PMID: 24384592.24384592
Murnane PM, Brown ER, Donnell D, . Estimating efficacy in a randomized trial with product nonadherence: application of multiple methods to a trial of preexposure prophylaxis for HIV prevention. Am J Epidemiol. 2015;182(10):848–56. doi: 10.1093/aje/kwv202. PMID: 26487343.26487343
Mutua G, Sanders E, Mugo P, . Safety and adherence to intermittent pre-exposure prophylaxis (PrEP) for HIV-1 in African men who have sex with men and female sex workers. PLoS One. 2012;7(4):e33103. doi: 10.1371/journal.pone.0033103. PMID: 22511916.22511916
Peterson L, Taylor D, Roddy R, . Tenofovir disoproxil fumarate for prevention of HIV infection in women: a phase 2, double-blind, randomized, placebo-controlled trial. PLoS Clin Trials. 2007;2(5):e27. doi: 10.1371/journal.pctr.0020027. PMID: 17525796.17525796
Roberts ST, Haberer J, Celum C, . Intimate partner violence and adherence to HIV pre-exposure prophylaxis (PrEP) in African women in HIV serodiscordant relationships: A prospective cohort study. J Acquir Immune Defic Syndr. 2016;73(3):313–22. doi: 10.1097/qai.0000000000001093. PMID: 27243900.27243900
Smith DK, Pals SL, Herbst JH, . Development of a clinical screening index predictive of incident HIV infection among men who have sex with men in the United States. J Acquir Immune Defic Syndr. 2012;60(4):421–7. doi: 10.1097/QAI.0b013e318256b2f6. PMID: 22487585.22487585
Smith DK, Pan Y, Rose CE, . A brief screening tool to assess the risk of contracting HIV infection among active injection drug users. J Addict Med. 2015;9(3):226–32. doi: 10.1097/ADM.0000000000000123. PMID: 25961495.25961495
Solomon MM, Lama JR, Glidden DV, . Changes in renal function associated with oral emtricitabine/tenofovir disoproxil fumarate use for HIV pre-exposure prophylaxis. AIDS. 2014;28(6):851–9. doi: 10.1097/QAD.0000000000000156. PMID: 24499951.24499951
Thigpen MC, Kebaabetswe PM, Paxton LA, . Antiretroviral preexposure prophylaxis for heterosexual HIV transmission in Botswana. N Engl J Med. 2012;367(5):423–34. doi: 10.1056/NEJMoa1110711. PMID: 22784038.22784038
Van Damme L, Corneli A, Ahmed K, . Preexposure prophylaxis for HIV infection among African women. N Engl J Med. 2012;367(5):411–22. doi: 10.1056/NEJMoa1202614. PMID: 22784040.22784040
van Epps P, Maier M, Lund B, . Medication adherence in a nationwide cohort of veterans initiating pre-exposure prophylaxis (PrEP) to prevent HIV infection. J Acquir Immune Defic Syndr. 2018;77(3):272–8. doi: 10.1097/QAI.0000000000001598. PMID: 29210835.29210835
Were EO, Heffron R, Mugo NR, . Pre-exposure prophylaxis does not affect the fertility of HIV-1-uninfected men. AIDS. 2014;28(13):1977–82. doi: 10.1097/QAD.0000000000000313. PMID: 25259704.25259704

## Appendix A5 Excluded Studies List

Aaron E, Blum C, Seidman D, . Optimizing delivery of HIV preexposure prophylaxis for women in the United States. AIDS Patient Care STDS. 2018 Jan;32(1):16–23. doi: 10.1089/apc.2017.0201. PMID: 29323558. Excluded: not a study (letter, editorial, non-systematic review article, no original data).29323558
Abbas UL, Glaubius R, Mubayi A, . Antiretroviral therapy and pre-exposure prophylaxis: combined impact on HIV transmission and drug resistance in South Africa. J Infect Dis. 2013 Jul 2013;208(2):224–34. doi: 10.1093/infdis/jit150. PMID: 23570850. Excluded: wrong study design for Key Question.23570850
Abdool Karim Q, Abdool Karim SS, Frohlich JA, . Effectiveness and safety of tenofovir gel, an antiretroviral microbicide, for the prevention of HIV infection in women. Science. 2010 Sep 2010;329(5996):1168–74. doi: 10.1126/science.1193748. PMID: 20643915. Excluded: wrong intervention.20643915
Abdool Karim SS. HIV pre-exposure prophylaxis in injecting drug users. Lancet. 2013 Jun 2013;381(9883):2060–2. doi: 10.1016/S0140-6736(13)61140-X. PMID: 23769217. Excluded: not a study (letter, editorial, non-systematic review article, no original data).23769217
Adams LM, Balderson BH. HIV providers’ likelihood to prescribe pre-exposure prophylaxis (PrEP) for HIV prevention differs by patient type: a short report. AIDS Care. 2016 Sep;28(9):1154–8. doi: 10.1080/09540121.2016.1153595. PMID: 26915281. Excluded: wrong outcome.26915281
Alistar SS, Owens DK, Brandeau ML. Effectiveness and cost effectiveness of oral pre-exposure prophylaxis in a portfolio of prevention programs for injection drug users in mixed HIV epidemics. PLoS One. 2014;9(1):e86584. doi: 10.1371/journal.pone.0086584. PMID: 24489747. Excluded: wrong study design for Key Question.24489747
Allen E, Gordon A, Krakower D, . HIV preexposure prophylaxis for adolescents and young adults. Curr Opin Pediatr. 2017 Aug;29(4):399–406. doi: 10.1097/MOP.0000000000000512. PMID: 28598901. Excluded: wrong study design for Key Question.28598901
Aloysius I, Savage A, Zdravkov J, . InterPrEP. Internet-based pre-exposure prophylaxis with generic tenofovir DF/emtricitabine in London: an analysis of outcomes in 641 patients. J Virus Erad. 2017 Oct 2017;3(4):218–22. PMID: 29057086. Excluded: wrong study design for Key Question.29057086
Al-Tayyib AA, Thrun MW, Haukoos JS, . Knowledge of pre-exposure prophylaxis (PrEP) for HIV prevention among men who have sex with men in Denver, Colorado. AIDS Behav. 2014 Apr;18: Suppl 3:340–7. doi: 10.1007/s10461-013-0553-6. PMID: 23824227. Excluded: wrong outcome.23824227
Anderson PL, Garcia-Lerma JG, Heneine W. Nondaily preexposure prophylaxis for HIV prevention. Curr Opin HIV AIDS. 2016 Jan;11(1):94–101. doi: 10.1097/COH.0000000000000213. PMID: 26633641. Excluded: wrong study design for Key Question.26633641
Anderson PL, Glidden DV, Liu A, . Emtricitabine-tenofovir concentrations and pre-exposure prophylaxis efficacy in men who have sex with men. Sci Transl Med. 2012 Sep 2012;4(151):1–8. PMID: 22972843. Excluded: wrong outcome.22972843
Anderson PL, Reirden D, Castillo-Mancilla J. Pharmacologic considerations for preexposure prophylaxis in transgender women. J Acquir Immune Defic Syndr. 2016 Aug 2016;72 Suppl 3:S230–4. doi: 10.1097/QAI.0000000000001105. PMID: 27429188. Excluded: not a study (letter, editorial, non-systematic review article, no original data).27429188
Andersson E, Nordquist A, Esbjornsson J, . Increase in transmitted drug resistance in migrants from sub-Saharan Africa diagnosed with HIV-1 in Sweden. AIDS. 2018 Apr 2018;32(7):877–84. doi: 10.1097/QAD.0000000000001763. PMID: 29369826. Excluded: wrong outcome.29369826
Anglemyer A, Rutherford GW, Horvath T, . Antiretroviral therapy for prevention of HIV transmission in HIV-discordant couples. Cochrane Database Syst Rev. 2013;4:CD009153. doi: 10.1002/14651858.CD009153.pub3. PMID: 23633367. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.23633367
Anonymous. Pre-exposure prophylaxis effective. AIDS Patient Care STDS. 2006 Sep;20(9):660. PMID: 17036415. Excluded: not a study (letter, editorial, non-systematic review article, no original data).17036415
Anonymous. The safety of tenofovir-emtricitabine for HIV pre-exposure prophylaxis (PrEP) in individuals with active hepatitis B. J Acquir Immune Defic Syndr. 2016 Jul 2016;72(3):e82. doi: 10.1097/QAI.0000000000001100. PMID: 27309968. Excluded: not a study (letter, editorial, non-systematic review article, no original data).27309968
Antoni G. On-demand PrEP with TDF/FTC remains highly effective among MSM with infrequent sexual intercourse: a sub-study of the ANRS IPERGAY trial. 2017. http://programme.ias2017.org/Abstract/Abstract/3629. Accessed January 3, 2018. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Arnold T, Brinkley-Rubinstein L, Chan PA, . Social, structural, behavioral and clinical factors influencing retention in pre-exposure prophylaxis (PrEP) care in Mississippi. PLoS One. 2017;12(2):e0172354. doi: 10.1371/journal.pone.0172354. PMID: 28222118. Excluded: wrong outcome.28222118
Auerbach JD, Kinsky S, Brown G, . Knowledge, attitudes, and likelihood of pre-exposure prophylaxis (PrEP) use among US women at risk of acquiring HIV. AIDS Patient Care STDS. 2015 Feb;29(2):102–10. doi: 10.1089/apc.2014.0142. PMID: 25513954. Excluded: wrong outcome.25513954
Baeten J, Donnell D, Ndase P, . Single-agent TDF versus combination FTC/TDF PrEP among heterosexual men and women. Top Antivir Med. START: 2014 Mar 3 CONFERENCE END: 2014 Mar 6, 21st Conference on Retroviruses and Opportunistic Infections, CROI 2014 (21)United States;22(e-1):23. doi: 10.1371/journal.pone.0090111. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Baeten JM. Preexposure prophylaxis reduced HIV-1 spread in serodiscordant heterosexual couples. ANN Intern Med. 2012;157(10):JC5–3. doi: 10.7326/0003-4819-157-10-201211200-02003. PMID: 23165679. Excluded: not a study (letter, editorial, non-systematic review article, no original data).23165679
Baeten JM, Donnell D, Mugo NR, . Single-agent tenofovir versus combination emtricitabine plus tenofovir for pre-exposure prophylaxis for HIV-1 acquisition: an update of data from a randomised, double-blind, phase 3 trial. Lancet Infect Dis. 2014 Nov;14(11):1055–64. doi: 10.1016/S1473-3099(14)70937-5. PMID: 25300863. Excluded: wrong comparator.25300863
Baeten JM, Palanee-Phillips T, Brown ER, . Use of a vaginal ring containing dapivirine for HIV-1 prevention in women. N Engl J Med. 2016 Dec;375(22):2121–32. doi: 10.1056/NEJMoa1506110. PMID: 26900902. Excluded: wrong intervention.26900902
Baker J. Stay current with options for HIV prevention. JAAPA. 2013 Dec;26(12):14–20; quiz 5. doi: 10.1097/01.JAA.0000437820.76526.41. PMID: 24177333. Excluded: not a study (letter, editorial, non-systematic review article, no original data).24177333
Baker J, O’Hara KM. Oral preexposure prophylaxis to prevent HIV infection: clinical and public health implications. JAAPA. 2014 Dec;27(12):10–7. doi: 10.1097/01.JAA.0000456567.37724.e0. PMID: 25390822. Excluded: not a study (letter, editorial, non-systematic review article, no original data).25390822
Balkus JE, Brown E, Palanee T, . An empiric HIV risk scoring tool to predict HIV-1 acquisition in African women. J Acquir Immune Defic Syndr. 2016 Jul 2016;72(3):333–43. doi: 10.1097/QAI.0000000000000974. PMID: 26918545. Excluded: wrong country.26918545
Balkus JE, Brown ER, Palanee-Phillips T, . Performance of a validated risk score to predict HIV-1 acquisition among african women participating in a trial of the dapivirine vaginal ring. J Acquir Immune Defic Syndr. 2018 01 01;77(1):e8–e10. doi: 10.1097/QAI.0000000000001556. PMID: 28961677. Excluded: not a study (letter, editorial, non-systematic review article, no original data).28961677
Baral SD, Poteat T, Stromdahl S, . Worldwide burden of HIV in transgender women: a systematic review and meta-analysis. Lancet Infect Dis. 2013 Mar;13(3):214–22. doi: 10.1016/s1473-3099(12)70315-8. PMID: 23260128. Excluded: wrong outcome.23260128
Baral SD, Stromdahl S, Beyrer C. The potential uses of preexposure prophylaxis for HIV prevention among people who inject drugs. Curr Opin HIV AIDS. 2012 Nov;7(6):563–8. doi: 10.1097/COH.0b013e328358e49e. PMID: 23076122. Excluded: not a study (letter, editorial, non-systematic review article, no original data).23076122
Barash EA, Golden M. Awareness and use of HIV pre-exposure prophylaxis among attendees of a Seattle gay pride event and sexually transmitted disease clinic. AIDS Patient Care STDS. 2010 Nov;24(11):689–91. doi: 10.1089/apc.2010.0173. PMID: 20863247. Excluded: wrong outcome.20863247
Barreiro P. Hot news: Sexually transmitted infections on the rise in PrEP users. AIDS Rev. 2018 Jan–Mar;20(1):71. PMID: 29628512. Excluded: not a study (letter, editorial, non-systematic review article, no original data).29628512
Baxi SM, Liu A, Bacchetti P, . Measuring intermittent and daily PrEP adherence by hair levels, self-report and MEMS caps openings. Top Antivir Med. START: 2014 Mar 3 CONFERENCE END: 2014 Mar 6, 21st Conference on Retroviruses and Opportunistic Infections, CROI 2014 (21)United States;22(e-1):499–500. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Baxi SM, Vittinghoff E, Bacchetti P, . Comparing pharmacologic measures of tenofovir exposure in a U.S. pre-exposure prophylaxis randomized trial. PLoS One. 2018;13(1):e0190118. doi: 10.1371/journal.pone.0190118. PMID: 29315307. Excluded: not a study (letter, editorial, non-systematic review article, no original data).29315307
Baxter C, Abdool Karim S. Combination HIV prevention options for young women in Africa. Afr J AIDS Res. 2016 Jul;15(2):109–21. doi: 10.2989/16085906.2016.1196224. PMID: 27399041. Excluded: not a study (letter, editorial, non-systematic review article, no original data).27399041
Bazzi AR. Antiretroviral pre-exposure prophylaxis for HIV prevention is highly effective in community settings. Evid Based Med. 2016 Jun;21(3):99. doi: 10.1136/ebmed-2016-110403. PMID: 27029888. Excluded: not a study (letter, editorial, non-systematic review article, no original data).27029888
Bekker LG, Gill K, Wallace M. Pre-exposure prophylaxis for South African adolescents: What evidence? S Afr Med J. 2015 Nov;105(11):907–11. doi: 10.7196/SAMJ.2015.v105i11.10222. PMID: 26632316. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.26632316
Bekker LG, Hughes J, Amico R, . HPTN 067/ADAPT cape town: A comparison of daily and nondaily PrEP dosing in African women. Top Antivir Med. 2015;23:449–50. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Bekker LG, Johnson L, Cowan F, . Combination HIV prevention for female sex workers: what is the evidence? Lancet. 2015 Jan 2015;385(9962):72–87. doi: 10.1016/S0140-6736(14)60974-0. PMID: 25059942. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.25059942
Bekker LG, Li SS, Tolley B, . HPTN 076: TMC278 la safe, tolerable, and acceptable for HIV preexposure prophylaxis. Top Antivir Med. 2017;25(1):172s–3s. Excluded: wrong intervention.
Bini EJ, Currie SL, Shen H, . National multicenter study of HIV testing and HIV seropositivity in patients with chronic hepatitis C virus infection. J Clin Gastroenterol. 2006 Sep;40(8):732–9. PMID: 16940888. Excluded: wrong intervention.16940888
Bipath P, Levay P, Olorunju S, . A non-specific biomarker of disease activity in HIV/AIDS patients from resource-limited environments. Afr Health Sci. 2015 Jun;15(2):334–43. doi: 10.4314/ahs.v15i2.5. PMID: 26124777. Excluded: wrong outcome.26124777
Bird SM. Trial size, HIV pre-exposure prophylaxis, and breastfeeding. Lancet. 2016 May 2016;387(10033):2090–1. doi: 10.1016/S0140-6736(16)30539-6. PMID: 27301821. Excluded: wrong population.27301821
Blackwell CW. Preexposure prophylaxis: An emerging clinical approach to preventing HIV in high-risk adults. Nurse Pract. 2014 Sep 2014;39(9):50–3. doi: 10.1097/01.NPR.0000452976.92052.fa. PMID: 25140852. Excluded: not a study (letter, editorial, non-systematic review article, no original data).25140852
Blashill AJ, Ehlinger PP, Mayer KH, . Optimizing adherence to preexposure and postexposure prophylaxis: the need for an integrated biobehavioral approach. Clin Infect Dis. 2015 Jun 2015;60 Suppl 3:S187–90. doi: 10.1093/cid/civ111. PMID: 25972502. Excluded: not a study (letter, editorial, non-systematic review article, no original data).25972502
Blaylock JM, Hakre S, Decker CF, . HIV PrEP in the military: Experience at a tertiary care military medical center. Mil Med. 2018 Mar 2018;183(suppl_1):445–9. doi: 10.1093/milmed/usx143. PMID: 29635556. Excluded: wrong study design for Key Question.29635556
Boffito M, Jackson A, Asboe D. Pharmacology lessons from chemoprophylaxis studies. Clin Infect Dis. 2014 Jul;59: Suppl 1:S52–4. doi: 10.1093/cid/ciu250. PMID: 24926035. Excluded: not a study (letter, editorial, non-systematic review article, no original data).24926035
Bolland MJ, Grey A. Antiretroviral preexposure prophylaxis for HIV prevention. N Engl J Med. 2013 Jan 2013;368(1):82. doi: 10.1056/NEJMc1210464#SA1. PMID: 23281986. Excluded: not a study (letter, editorial, non-systematic review article, no original data).23281986
Bristow CC, Konda KA, Wong J, . Choosing a metric for measurement of pre-exposure prophylaxis. Lancet Infect Dis. 2014 Dec;14(12):1177–8. doi: 10.1016/S1473-3099(14)70989-2. PMID: 25455980. Excluded: not a study (letter, editorial, non-systematic review article, no original data).25455980
Brooks RA, Landovitz RJ, Kaplan RL, . Sexual risk behaviors and acceptability of HIV pre-exposure prophylaxis among HIV-negative gay and bisexual men in serodiscordant relationships: a mixed methods study. AIDS Patient Care STDS. 2012 Feb;26(2):87–94. doi: 10.1089/apc.2011.0283. PMID: 22149764. Excluded: wrong outcome.22149764
Brooks RA, Landovitz RJ, Regan R, . Perceptions of and intentions to adopt HIV pre-exposure prophylaxis among black men who have sex with men in Los Angeles. Int J STD AIDS. 2015 Dec;26(14):1040–8. doi: 10.1177/0956462415570159. PMID: 25638214. Excluded: wrong outcome.25638214
Broz D, Wejnert C, Pham HT, . HIV infection and risk, prevention, and testing behaviors among injecting drug users -- National HIV Behavioral Surveillance System, 20 U.S. cities, 2009. MMWR Surveill Summ. 2014 Jul 2014;63(6):1–51. PMID: 24990587. Excluded: wrong outcome.24990587
Buchbinder SP, Glidden DV, Liu AY, . HIV pre-exposure prophylaxis in men who have sex with men and transgender women: a secondary analysis of a phase 3 randomised controlled efficacy trial. Lancet Infect Dis. 2014 Jun;14(6):468–75. doi: 10.1016/S1473-3099(14)70025-8. PMID: 24613084. Excluded: wrong outcome.24613084
Burns DN, Grossman C, Turpin J, . Role of oral pre-exposure prophylaxis (PrEP) in current and future HIV prevention strategies. Curr HIV/AIDS Rep. 2014 Dec;11(4):393–403. doi: 10.1007/s11904-014-0234-8. PMID: 25283184. Excluded: not a study (letter, editorial, non-systematic review article, no original data).25283184
Cabral A, J MB, Ngure K, . Intimate partner violence and self-reported pre-exposure prophylaxis interruptions among HIV-negative partners in HIV serodiscordant couples in Kenya and Uganda. J Acquir Immune Defic Syndr. 2018 Feb 2018;77(2):154–9. doi: 10.1097/QAI.0000000000001574. PMID: 29076883. Excluded: wrong outcome.29076883
Cailhol J, Rouyer C, Alloui C, . Dolutegravir and neuropsychiatric adverse events: a continuing debate. AIDS. 2017 Sep 2017;31(14):2023–4. doi: 10.1097/qad.0000000000001596. PMID: 28857781. Excluded: inadequate duration.28857781
Calabrese SK, Magnus M, Mayer KH, . Putting PrEP into practice: Lessons learned from early-adopting U.S. providers’ firsthand experiences providing HIV pre-exposure prophylaxis and associated care. PLoS One. 2016;11(6):e0157324. doi: 10.1371/journal.pone.0157324. PMID: 27304883. Excluded: wrong outcome.27304883
Calabrese SK, Underhill K, Earnshaw VA, . Framing HIV pre-exposure prophylaxis (PrEP) for the general public: How inclusive messaging may prevent prejudice from diminishing public support. AIDS Behav. 2016 Jul;20(7):1499–513. doi: 10.1007/s10461-016-1318-9. PMID: 26891840. Excluded: wrong outcome.26891840
Callahan R, Nanda K, Kapiga S, . Pregnancy and contraceptive use among women participating in the FEM-PrEP trial. J Acquir Immune Defic Syndr. 2015 Feb 2015;68(2):196–203. doi: 10.1097/QAI.0000000000000413. PMID: 25590272. Excluded: wrong outcome.25590272
Cambiano V, Miners A, Dunn D, . Cost-effectiveness of pre-exposure prophylaxis for HIV prevention in men who have sex with men in the UK: a modelling study and health economic evaluation. Lancet Infect Dis. 2018 Jan;18(1):85–94. doi: 10.1016/S1473-3099(17)30540-6. PMID: 29054789. Excluded: wrong study design for Key Question.29054789
Carballo-Dieguez A, Balan IC, Brown W, 3rd, . High levels of adherence to a rectal microbicide gel and to oral Pre-Exposure Prophylaxis (PrEP) achieved in MTN-017 among men who have sex with men (MSM) and transgender women. PLoS One. 2017;12(7):e0181607. doi: 10.1371/journal.pone.0181607. PMID: 28750059. Excluded: wrong population.28750059
Carballo-Dieguez A, Giguere R, Dolezal C, . Preference of oral tenofovir disoproxil fumarate/emtricitabine versus rectal tenofovir reduced-glycerin 1% gel regimens for HIV prevention among cisgender men and transgender women who engage in receptive anal intercourse with men. AIDS Behav. 2017 Dec;21(12):3336–45. doi: 10.1007/s10461-017-1969-1. PMID: 29119473. Excluded: wrong comparator.29119473
Carnegie NB, Goodreau SM, Liu A, . Targeting pre-exposure prophylaxis among men who have sex with men in the United States and Peru: partnership types, contact rates, and sexual role. J Acquir Immune Defic Syndr. 2015 May 2015;69(1):119–25. doi: 10.1097/QAI.0000000000000555. PMID: 25942463. Excluded: wrong study design for Key Question.25942463
Carney EF. Clinical trials. Renal safety of TDF as pre-exposure prophylaxis for HIV-1 infection. Nat Rev Nephrol. 2015 Mar;11(3):127. doi: 10.1038/nrneph.2015.1. PMID: 25599622. Excluded: not a study (letter, editorial, non-systematic review article, no original data).25599622
Castillo-Mancilla JR, Searls K, Caraway P, . Short communication: Tenofovir diphosphate in dried blood spots as an objective measure of adherence in HIV-infected women. AIDS Res Hum Retroviruses. 2015 Apr;31(4):428–32. doi: 10.1089/aid.2014.0229. PMID: 25328112. Excluded: wrong population.25328112
CDC. HIV testing and risk behaviors among gay, bisexual, and other men who have sex with men - United States. MMWR Morb Mortal Wkly Rep. 2013 Nov 2013;62(47):958–62. PMID: 24280915. Excluded: wrong outcome.24280915
Celum C, Baeten JM. Tenofovir-based pre-exposure prophylaxis for HIV prevention: evolving evidence. Curr Opin Infect Dis. 2012 Feb;25(1):51–7. doi: 10.1097/QCO.0b013e32834ef5ef. PMID: 22156901. Excluded: not a study (letter, editorial, non-systematic review article, no original data).22156901
Celum C, Baeten JM. Antiretroviral-based HIV-1 prevention: antiretroviral treatment and pre-exposure prophylaxis. Antivir Ther. 2012;17(8):1483–93. doi: 10.3851/IMP2492. PMID: 23221365. Excluded: not a study (letter, editorial, non-systematic review article, no original data).23221365
Celum CL. HIV preexposure prophylaxis: new data and potential use. Top Antivir Med. 2011 Dec;19(5):181–5. PMID: 22298887. Excluded: not a study (letter, editorial, non-systematic review article, no original data).22298887
Celum CL, Delany-Moretlwe S, McConnell M, . Rethinking HIV prevention to prepare for oral PrEP implementation for young African women. J Int AIDS Soc. 2015;18(4 Suppl 3):20227. doi: 10.7448/IAS.18.4.20227. PMID: 26198350. Excluded: not a study (letter, editorial, non-systematic review article, no original data).26198350
Centers for Disease Control and Prevention. Interim guidance: preexposure prophylaxis for the prevention of HIV infection in men who have sex with men. MMWR Morb Mortal Wkly Rep. 2011 Jan 2011;60(3):65–8. PMID: 21270743. Excluded: not a study (letter, editorial, non-systematic review article, no original data).21270743
Centers for Disease Control and Prevention. Interim guidance for clinicians considering the use of preexposure prophylaxis for the prevention of HIV infection in heterosexually active adults. MMWR Morb Mortal Wkly Rep. 2012 Aug 2012;61(31):586–9. PMID: 22874836. Excluded: not a study (letter, editorial, non-systematic review article, no original data).22874836
Chakrapani V, Newman PA, Shunmugam M, . Acceptability of HIV pre-exposure prophylaxis (PrEP) and implementation challenges among men who have sex with men in India: a qualitative investigation. AIDS Patient Care STDS. 2015 Oct;29(10):569–77. doi: 10.1089/apc.2015.0143. PMID: 26348459. Excluded: wrong outcome.26348459
Chan L, Asriel B, Eaton EF, . Potential kidney toxicity from the antiviral drug tenofovir: new indications, new formulations, and a new prodrug. Curr Opin Nephrol Hypertens. 2018 03;27(2):102–12. doi: 10.1097/MNH.0000000000000392. PMID: 29278542. Excluded: not a study (letter, editorial, non-systematic review article, no original data).29278542
Chan PA, Rose J, Maher J, . A latent class analysis of risk factors for acquiring HIV among men who have sex with men: Implications for implementing pre-exposure prophylaxis programs. AIDS Patient Care STDS. 2015 Nov;29(11):597–605. doi: 10.1089/apc.2015.0113. PMID: 26389735. Excluded: wrong intervention.26389735
Chan R. Biomedical strategies for human immunodeficiency virus (HIV) prevention? A new paradigm. Ann Acad Med Singapore. 2012 Dec;41(12):595–601. PMID: 23303118. Excluded: not a study (letter, editorial, non-systematic review article, no original data).23303118
Chen A, Dowdy DW. Clinical effectiveness and cost-effectiveness of HIV pre-exposure prophylaxis in men who have sex with men: risk calculators for real-world decision-making. PLoS One. 2014;9(10):e108742. doi: 10.1371/journal.pone.0108742. PMID: 25285793. Excluded: wrong study design for Key Question.25285793
Chua A, Ford N, Wilson D, . The tenofovir pre-exposure prophylaxis trial in Thailand: Researchers should show more openness in their engagement with the community [1] (multiple letters). PLoS Med. 2005;2(10):1044–6. doi: 10.1371/journal.pmed.0020346. PMID: 16231979. Excluded: not a study (letter, editorial, non-systematic review article, no original data).16231979
Cid-Silva P, Llibre JM, Fernandez-Bargiela N, . Clinical experience with the integrase inhibitors dolutegravir and elvitegravir in HIV-infected patients: Efficacy, safety and tolerance. Basic Clin Pharmacol Toxicol. 2017 Nov;121(5):442–6. doi: 10.1111/bcpt.12828. PMID: 28627771. Excluded: inadequate duration.28627771
Clutter DS, Jordan MR, Bertagnolio S, . HIV-1 drug resistance and resistance testing. Infect Genet Evol. 2016 1;46:292–307. PMID: 27587334. Excluded: not a study (letter, editorial, non-systematic review article, no original data).27587334
Cohen MS, Chen YQ, McCauley M, . Antiretroviral therapy for the prevention of HIV-1 Transmission. N Engl J Med. 2016 Jul 18 doi: 10.1056/NEJMoa1600693. PMID: 27424812. Excluded: wrong intervention.27424812
Cohen MS, Chen YQ, McCauley M, . Prevention of HIV-1 infection with early antiretroviral therapy. N Engl J Med. 2011 Aug 2011;365(6):493–505. doi: 10.1056/NEJMoa1105243. PMID: 21767103. Excluded: wrong population.21767103
Cohen MS, Muessig KE, Smith MK, . Antiviral agents and HIV prevention: controversies, conflicts, and consensus. AIDS. 2012 Aug 2012;26(13):1585–98. doi: 10.1097/QAD.0b013e3283543e83. PMID: 22507927. Excluded: not a study (letter, editorial, non-systematic review article, no original data).22507927
Colby D, Srithanaviboonchai K, Vanichseni S, . HIV pre-exposure prophylaxis and health and community systems in the global south: Thailand case study. J Int AIDS Soc. 2015;18(4 Suppl 3):19953. doi: 10.7448/IAS.18.4.19953. PMID: 26198342. Excluded: not a study (letter, editorial, non-systematic review article, no original data).26198342
Collier KL, Colarossi LG, Sanders K. A PrEP information and self-screening tool for women. AIDS Educ Prev. 2018 Feb;30(1):13–25. doi: 10.1521/aeap.2018.30.1.13. PMID: 29481302. Excluded: wrong study design for Key Question.29481302
Conniff J, Evensen A. Preexposure prophylaxis (PrEP) for HIV prevention: The primary care perspective. J Am Board Fam Med. 2016 Jan–Feb;29(1):143–51. doi: 10.3122/jabfm.2016.01.150223. PMID: 26769887. Excluded: not a study (letter, editorial, non-systematic review article, no original data).26769887
Coovadia H, Moodley D. Improving HIV pre-exposure prophylaxis for infants. Lancet. 2016 Feb 2016;387(10018):513–4. doi: 10.1016/S0140-6736(15)00983-6. PMID: 26603916. Excluded: wrong population.26603916
Corneli A, Field S, Namey E, . Preparing for the rollout of pre-exposure prophylaxis (PrEP): A vignette survey to identify intended sexual behaviors among women in Kenya and South Africa if using PrEP. PLoS One. 2015;10(6):e0129177. doi: 10.1371/journal.pone.0129177. PMID: 26056842. Excluded: wrong study design for Key Question.26056842
Corneli A, Namey E, Ahmed K, . Motivations for reducing other HIV risk-reduction practices if taking pre-exposure prophylaxis: Findings from a qualitative study among women in Kenya and South Africa. AIDS Patient Care STDS. 2015 Sep;29(9):503–9. doi: 10.1089/apc.2015.0038. PMID: 26196411. Excluded: wrong outcome.26196411
Corneli A, Perry B, Agot K, . Facilitators of adherence to the study pill in the FEM-PrEP clinical trial. PLoS One. 2015;10(4):e0125458. doi: 10.1371/journal.pone.0125458. PMID: 25867624. Excluded: wrong outcome.25867624
Corneli A, Wang M, Agot K, . Perception of HIV risk and adherence to a daily, investigational pill for HIV prevention in FEM-PrEP. J Acquir Immune Defic Syndr. 2014 Dec 2014;67(5):555–63. doi: 10.1097/QAI.0000000000000362. PMID: 25393942. Excluded: wrong outcome.25393942
Corneli AL, McKenna K, Headley J, . A descriptive analysis of perceptions of HIV risk and worry about acquiring HIV among FEM-PrEP participants who seroconverted in Bondo, Kenya, and Pretoria, South Africa. J Int AIDS Soc. 2014;17(3 Suppl 2):19152. doi: 10.7448/IAS.17.3.19152. PMID: 25224613. Excluded: wrong outcome.25224613
Cremin I, Morales F, Jewell BL, . Seasonal PrEP for partners of migrant miners in southern Mozambique: a highly focused PrEP intervention.[Erratum appears in J Int AIDS Soc. 2016;19(1):20948; PMID: 26905056]. J Int AIDS Soc. 2015;18(4 Suppl 3):19946. doi: 10.7448/IAS.18.4.19946. PMID: 26198340. Excluded: wrong study design for Key Question.26198340
Curlin ME, Martin MT, Wasinrapee P, . Effect of TDF monotherapy PrEP on immune function in seroconverting individuals. Top Antivir Med. 2015;23(453). Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Dai JY, Gilbert PB, Hughes JP, . Estimating the efficacy of preexposure prophylaxis for HIV prevention among participants with a threshold level of drug concentration. Am J Epidemiol. 2013 Feb 2013;177(3):256–63. doi: 10.1093/aje/kws324. PMID: 23302152. Excluded: wrong outcome.23302152
Damery S, Nichols L, Holder R, . Assessing the predictive value of HIV indicator conditions in general practice: a case-control study using the THIN database. Br J Gen Pract. 2013 Jun;63(611):e370–7. doi: 10.3399/bjgp13X668159. PMID: 23735407. Excluded: wrong intervention.23735407
Daughtridge GW, Conyngham SC, Ramirez N, . I am men’s health: Generating adherence to HIV pre-exposure prophylaxis (PrEP) in young men of color who have sex with men. J Int Assoc Provid AIDS Care. 2015 Mar–Apr;14(2):103–7. doi: 10.1177/2325957414555230. PMID: 25331226. Excluded: wrong outcome.25331226
de Lastours V, Fonsart J, Burlacu R, . Concentrations of tenofovir and emtricitabine in saliva: implications for preexposure prophylaxis of oral HIV acquisition. Antimicrob Agents Chemother. 2011 Oct;55(10):4905–7. doi: 10.1128/AAC.00120-11. PMID: 21788466. Excluded: wrong outcome.21788466
Defechereux PA, Mehrotra M, Liu AY, . Depression and oral FTC/TDF pre-exposure prophylaxis (PrEP) among men and transgender women who have sex with men (MSM/TGW). AIDS Behav. 2016 Jul;20(7):1478–88. doi: 10.1007/s10461-015-1082-2. PMID: 26078115. Excluded: wrong outcome.26078115
Dijkstra M, de Bree GJ, Stolte IG, . Development and validation of a risk score to assist screening for acute HIV-1 infection among men who have sex with men. BMC Infect Dis. 2017 Jun 2017;17(1):425. doi: 10.1186/s12879-017-2508-4. PMID: 28615005. Excluded: wrong population.28615005
Dimitrov DT, Masse BR, Donnell D. PrEP adherence patterns strongly affect individual HIV risk and observed efficacy in randomized clinical trials. J Acquir Immune Defic Syndr. 2016 Aug 2016;72(4):444–51. doi: 10.1097/QAI.0000000000000993. PMID: 26990823. Excluded: wrong study design for Key Question.26990823
Dolezal C, Frasca T, Giguere R, . Awareness of post-exposure prophylaxis (PEP) and pre-exposure prophylaxis (PrEP) is low but interest is high among men engaging in condomless anal sex with men in Boston, Pittsburgh, and San Juan. AIDS Educ Prev. 2015 Aug;27(4):289–97. doi: 10.1521/aeap.2015.27.4.289. PMID: 26241380. Excluded: wrong outcome.26241380
Dolling DI, Desai M, McOwan A, . An analysis of baseline data from the PROUD study: an open-label randomised trial of pre-exposure prophylaxis. Trials. 2016;17(1):163. doi: 10.1186/s13063-016-1286-4. PMID: 27013513. Excluded: wrong outcome.27013513
Donnell D, Hughes JP, Wang L, . Study design considerations for evaluating efficacy of systemic preexposure prophylaxis interventions. J Acquir Immune Defic Syndr. 2013 Jul;63: Suppl 2:S130–4. doi: 10.1097/QAI.0b013e3182986fac. PMID: 23764624. Excluded: not a study (letter, editorial, non-systematic review article, no original data).23764624
Donnell D, Ramos E, Celum C, . The effect of oral preexposure prophylaxis on the progression of HIV-1 seroconversion. AIDS. 2017 Sep 2017;31(14):2007–16. doi: 10.1097/QAD.0000000000001577. PMID: 28692542. Excluded: wrong outcome.28692542
Dumond JB, Yeh RF, Patterson KB, . Antiretroviral drug exposure in the female genital tract: implications for oral pre- and post-exposure prophylaxis. AIDS. 2007 Sep 2007;21(14):1899–907. PMID: 17721097. Excluded: wrong outcome.17721097
Eaton LA, Driffin DD, Smith H, . Psychosocial factors related to willingness to use pre-exposure prophylaxis for HIV prevention among Black men who have sex with men attending a community event. Sex Health. 2014 Jul;11(3):244–51. doi: 10.1071/SH14022. PMID: 25001553. Excluded: wrong outcome.25001553
Eccles-Radtke C, Henry K. Turning the tide against AIDS by preventing new HIV infections initial experience with Minnesota’s first PrEP clinic. Minn Med. 2015 Jan;98(1):45–8. PMID: 25665269. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.25665269
Eisingerich AB, Wheelock A, Gomez GB, . Attitudes and acceptance of oral and parenteral HIV preexposure prophylaxis among potential user groups: a multinational study. PLoS One. 2012;7(1):e28238. doi: 10.1371/journal.pone.0028238. PMID: 22247757. Excluded: wrong outcome.22247757
Elion R, Coleman M. The preexposure prophylaxis revolution: from clinical trials to routine practice: implementation view from the USA. Curr Opin HIV AIDS. 2016 Jan;11(1):67–73. doi: 10.1097/COH.0000000000000222. PMID: 26599165. Excluded: not a study (letter, editorial, non-systematic review article, no original data).26599165
Elsesser SA, Oldenburg CE, Biello KB, . Seasons of risk: Anticipated behavior on vacation and interest in episodic antiretroviral pre-exposure prophylaxis (PrEP) among a large national sample of U.S. men who have sex with men (MSM). AIDS Behav. 2016 Jul;20(7):1400–7. doi: 10.1007/s10461-015-1238-0. PMID: 26538056. Excluded: wrong outcome.26538056
Escudero DJ, Kerr T, Operario D, . Inclusion of trans women in pre-exposure prophylaxis trials: a review. AIDS Care. 2015;27(5):637–41. doi: 10.1080/09540121.2014.986051. PMID: 25430940. Excluded: wrong outcome.25430940
Escudero DJ, Lurie MN, Kerr T, . HIV pre-exposure prophylaxis for people who inject drugs: a review of current results and an agenda for future research. J Int AIDS Soc. 2014;17:18899. doi: 10.7448/IAS.17.1.18899. PMID: 24679634. Excluded: wrong study design for Key Question.24679634
Excler JL, Rida W, Priddy F, . AIDS vaccines and preexposure prophylaxis: is synergy possible? AIDS Res Hum Retroviruses. 2011 Jun;27(6):669–80. doi: 10.1089/AID.2010.0206. PMID: 21043994. Excluded: not a study (letter, editorial, non-systematic review article, no original data).21043994
Farcasanu M, Kwon DS. The influence of cervicovaginal microbiota on mucosal immunity and prophylaxis in the battle against HIV. Curr HIV/AIDS Rep. 2018 Feb;15(1):30–8. doi: 10.1007/s11904-018-0380-5. PMID: 29516267. Excluded: wrong study design for Key Question.29516267
Fernandez-Montero JV, Barreiro P, Del Romero J, . Antiretroviral drugs for pre-exposure prophylaxis of HIV infection. AIDS Rev. 2012 Jan–Mar;14(1):54–61. PMID: 22297504. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.22297504
Flash C, Landovitz R, Giler RM, . Two years of Truvada for pre-exposure prophylaxis utilization in the US. J Int AIDS Soc. 2014;17(4 Suppl 3):19730. doi: 10.7448/IAS.17.4.19730. PMID: 25397476. Excluded: wrong study design for Key Question.25397476
Flash CA, Stone VE, Mitty JA, . Perspectives on HIV prevention among urban black women: a potential role for HIV pre-exposure prophylaxis. AIDS Patient Care STDS. 2014 Dec;28(12):635–42. doi: 10.1089/apc.2014.0003. PMID: 25295393. Excluded: wrong outcome.25295393
Fonner VA, Dalglish SL, Kennedy CE, . Effectiveness and safety of oral HIV preexposure prophylaxis for all populations. AIDS. 2016 Jul 2016;30(12):1973–83. doi: 10.1097/QAD.0000000000001145. PMID: 27149090. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.27149090
Ford N, Shubber Z, Calmy A, . Choice of antiretroviral drugs for postexposure prophylaxis for adults and adolescents: a systematic review. Clin Infect Dis. 2015 Jun 2015;60 Suppl 3:S170–6. doi: 10.1093/cid/civ092. PMID: 25972499. Excluded: wrong intervention.25972499
Franks J, Hirsch-Moverman Y, Loquere AS, Jr., . Sex, PrEP, and stigma: Experiences with HIV pre-exposure prophylaxis among New York City MSM participating in the HPTN 067/ADAPT study. Aids Behav. 2018 Apr;22(4):1139–49. doi: 10.1007/s10461-017-1964-6. PMID: 29143163. Excluded: wrong outcome.29143163
Fransen K, de Baetselier I, Rammutla E, . Detection of new HIV infections in a multicentre HIV antiretroviral pre-exposure prophylaxis trial. J Clin Virol. 2017 Aug;93:76–80. doi: 10.1016/j.jcv.2017.03.013. PMID: 28351689. Excluded: wrong study design for Key Question.28351689
Fu R, Owens DK, Brandeau ML. Cost-effectiveness of alternative strategies for provision of HIV preexposure prophylaxis for people who inject drugs. AIDS. 2018 Mar 2018;32(5):663–72. doi: 10.1097/QAD.0000000000001747. PMID: 29334549. Excluded: wrong outcome.29334549
Gandhi M, Glidden DV, Mayer K, . Association of age, baseline kidney function, and medication exposure with declines in creatinine clearance on pre-exposure prophylaxis: an observational cohort study. Lancet HIV. 2016 Nov;3(11):e521–e8. doi: 10.1016/s2352-3018(16)30153-9. PMID: 27658870. Excluded: wrong study design for Key Question.27658870
Gatey C, Pintado C, Chas J, . [Pre-exposure prophylaxis of HIV infection]. Rev Prat. 2014 Oct;64(8):1073–5. PMID: 25510128. Excluded: not English language but possibly relevant.25510128
Glidden DV, Mulligan K, McMahan V, . Brief report: Recovery of bone mineral density after discontinuation of tenofovir-based HIV pre-exposure prophylaxis. J Acquir Immune Defic Syndr. 2017 Oct 2017;76(2):177–82. doi: 10.1097/QAI.0000000000001475. PMID: 28639995. Excluded: wrong outcome.28639995
Goodreau SM, Hamilton DT, Jenness SM, . Targeting human immunodeficiency virus pre-exposure prophylaxis to adolescent sexual minority males in higher prevalence areas of the United States: A modeling study. J Adolesc Health. 2018 Mar;62(3):311–9. doi: 10.1016/j.jadohealth.2017.09.023. PMID: 29248392. Excluded: wrong study design for Key Question.29248392
Grant RM, Liegler T. Weighing the risk of drug resistance with the benefits of HIV preexposure prophylaxis. J Infect Dis. 2015 Apr 2015;211(8):1202–4. doi: 10.1093/infdis/jiu678. PMID: 25587019. Excluded: not a study (letter, editorial, non-systematic review article, no original data).25587019
Grinsztejn B, Hoagland B, Moreira RI, . Retention, engagement, and adherence to pre-exposure prophylaxis for men who have sex with men and transgender women in PrEP Brasil: 48 week results of a demonstration study. Lancet HIV. 2018 03;5(3):e136–e45. doi: 10.1016/S2352-3018(18)30008-0. PMID: 29467098. Excluded: wrong country.29467098
Guest G, Shattuck D, Johnson L, . Changes in sexual risk behavior among participants in a PrEP HIV prevention trial. Sex Transm Dis. 2008 Dec;35(12):1002–8. PMID: 19051397. Excluded: wrong study design for Key Question.19051397
Gulick RM, Wilkin TJ, Chen YQ, . Phase 2 study of the safety and tolerability of maraviroc-containing regimens to prevent HIV Infection in men who have sex with men (HPTN 069/ACTG A5305). J Infect Dis. 2017 Jan 2017;215(2):238–46. doi: 10.1093/infdis/jiw525. PMID: 27811319. Excluded: wrong comparator.27811319
Gunthard HF, Saag MS, Benson CA, . Antiretroviral drugs for treatment and prevention of HIV infection in adults: 2016 recommendations of the International Antiviral Society-USA Panel. JAMA. 2016 Jul 2016;316(2):191–210. doi: 10.1001/jama.2016.8900. PMID: 27404187. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.27404187
Haberer JE, Bangsberg DR, Baeten JM, . Defining success with HIV pre-exposure prophylaxis: a prevention-effective adherence paradigm. AIDS. 2015 Jul 2015;29(11):1277–85. doi: 10.1097/QAD.0000000000000647. PMID: 26103095. Excluded: not a study (letter, editorial, non-systematic review article, no original data).26103095
Haberer JE, Kidoguchi L, Heffron R, . Alignment of adherence and risk for HIV acquisition in a demonstration project of pre-exposure prophylaxis among HIV serodiscordant couples in Kenya and Uganda: a prospective analysis of prevention-effective adherence. J Int AIDS Soc. 2017 07 25;20(1):21842. doi: 10.7448/IAS.20.1.21842. PMID: 28741331. Excluded: wrong outcome.28741331
Hankins C, Macklin R, Warren M. Translating PrEP effectiveness into public health impact: key considerations for decision-makers on cost-effectiveness, price, regulatory issues, distributive justice and advocacy for access. J Int AIDS Soc. 2015;18(4 Suppl 3):19973. doi: 10.7448/IAS.18.4.19973. PMID: 26198343. Excluded: not a study (letter, editorial, non-systematic review article, no original data).26198343
Hannaford A, Lipshie-Williams M, Starrels JL, . The use of online posts to identify barriers to and facilitators of HIV pre-exposure prophylaxis (PrEP) among men who have sex with men: A comparison to a systematic review of the peer-reviewed literature. Aids Behav. 2018 Apr;22(4):1080–95. doi: 10.1007/s10461-017-2011-3. PMID: 29285638. Excluded: wrong outcome.29285638
Haukoos JS, Hopkins E, Bender B, . Comparison of enhanced targeted rapid HIV screening using the Denver HIV risk score to nontargeted rapid HIV screening in the emergency department. Ann Emerg Med. 2013 Mar;61(3):353–61. doi: 10.1016/j.annemergmed.2012.10.031. PMID: 23290527. Excluded: wrong population.23290527
Haukoos JS, Hopkins E, Bucossi MM, . Brief report: Validation of a quantitative HIV risk prediction tool using a national HIV testing cohort. J Acquir Immune Defic Syndr. 2015 Apr 2015;68(5):599–603. doi: 10.1097/qai.0000000000000518. PMID: 25585300. Excluded: wrong population.25585300
Haukoos JS, Lyons MS, Lindsell CJ, . Derivation and validation of the Denver Human Immunodeficiency Virus (HIV) risk score for targeted HIV screening. Am J Epidemiol. 2012 Apr 2012;175(8):838–46. doi: 10.1093/aje/kwr389. PMID: 22431561. Excluded: wrong population.22431561
Havens PL, Stephensen CB, Van Loan MD, . Decline in bone mass with tenofovir disoproxil fumarate/emtricitabine is associated with hormonal changes in the absence of renal impairment when used by HIV-uninfected adolescent boys and young men for HIV preexposure prophylaxis. Clin Infect Dis. 2017 Feb 2017;64(3):317–25. doi: 10.1093/cid/ciw765. PMID: 28013265. Excluded: wrong study design for Key Question.28013265
Hazen R, Hou JG, Kirkham H, . Exploring length of therapy and factors associated with HIV pre-exposure prophylaxis medication adherence using pharmacy claims data. Value in Health. 2017;20(5):A10–A1. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Headley J, Lemons A, Corneli A, . The sexual risk context among the FEM-PrEP study population in Bondo, Kenya and Pretoria, South Africa. PLoS One. 2014;9(9):e106410. doi: 10.1371/journal.pone.0106410. PMID: 25229403. Excluded: wrong outcome.25229403
Heffron R, Ngure K, Odoyo J, . Pre-exposure prophylaxis for HIV-negative persons with partners living with HIV: uptake, use, and effectiveness in an open-label demonstration project in East Africa. Gates Open Res. 2017 Nov 2017;1:3. doi: 10.12688/gatesopenres.12752.1. PMID: 29355231. Excluded: wrong study design for Key Question.29355231
Heffron R, Pintye J, Matthews LT, . PrEP as peri-conception HIV prevention for women and men. Curr HIV/AIDS Rep. 2016 Jun;13(3):131–9. doi: 10.1007/s11904-016-0312-1. PMID: 26993627. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.26993627
Heffron R, Thomson K, Celum C, . Fertility intentions, pregnancy, and use of PrEP and ART for safer conception among East African HIV serodiscordant couples. Aids Behav. 2018 Jun;22(6):1758–65. doi: 10.1007/s10461-017-1902-7. PMID: 28894986. Excluded: wrong study design for Key Question.28894986
Hoagland B, Moreira RI, De Boni RB, . High pre-exposure prophylaxis uptake and early adherence among men who have sex with men and transgender women at risk for HIV Infection: the PrEP Brasil demonstration project. J Int AIDS Soc. 2017 Apr 2017;20(1):1–14. doi: 10.7448/IAS.20.1.21472. PMID: 28418232. Excluded: wrong outcome.28418232
Hoenigl M, Jain S, Moore DJ, . Substance-using MSM on HIV preexposure prophylaxis have better adherence. Top Antivir Med. 2017;25(1):413s–4s. Excluded: wrong intervention.
Hoffman RM, Jaycocks A, Vardavas R, . Benefits of PrEP as an adjunctive method of HIV prevention during attempted conception between HIV-uninfected women and HIV-infected male partners. J Infect Dis. 2015 Nov 2015;212(10):1534–43. doi: 10.1093/infdis/jiv305. PMID: 26092856. Excluded: wrong study design for Key Question.26092856
Hoffmann C, Welz T, Sabranski M, . Higher rates of neuropsychiatric adverse events leading to dolutegravir discontinuation in women and older patients. HIV Med. 2017 Jan;18(1):56–63. doi: 10.1111/hiv.12468. PMID: 27860104. Excluded: inadequate duration.27860104
Hojilla JC, Vlahov D, Crouch PC, . HIV pre-exposure prophylaxis (PrEP) uptake and retention among men who have sex with men in a community-based sexual health clinic. Aids Behav. 2018 Apr;22(4):1096–9. doi: 10.1007/s10461-017-2009-x. PMID: 29243109. Excluded: wrong study design for Key Question.29243109
Hojilla JC, Vlahov D, Glidden DV, . Skating on thin ice: stimulant use and sub-optimal adherence to HIV pre-exposure prophylaxis. J Int AIDS Soc. 2018 Mar;21(3):e25103. doi: 10.1002/jia2.25103. PMID: 29577616. Excluded: wrong outcome.29577616
Hosek SG. HIV pre-exposure prophylaxis diffusion and implementation issues in nonclinical settings. Am J Prev Med. 2013 Jan;44(1 Suppl 2):S129–32. doi: 10.1016/j.amepre.2012.09.032. PMID: 23253753. Excluded: not a study (letter, editorial, non-systematic review article, no original data).23253753
Hsieh YH, Haukoos JS, Rothman RE. Validation of an abbreviated version of the Denver HIV risk score for prediction of HIV infection in an urban ED. Am J Emerg Med. 2014 Jul;32(7):775–9. doi: 10.1016/j.ajem.2014.02.043. PMID: 24768338. Excluded: wrong population.24768338
Huang YA, Tao G, Samandari T, . Laboratory testing of a cohort of commercially insured users of HIV preexposure prophylaxis in the United States, 2011-2015. J Infect Dis. 2018 Jan 2018;217(4):617–21. doi: 10.1093/infdis/jix595. PMID: 29145597. Excluded: wrong outcome.29145597
Joseph Davey DL, Bekker LG, Gorbach PM, . Delivering preexposure prophylaxis to pregnant and breastfeeding women in sub-Saharan Africa: The implementation science frontier. AIDS. 2017;31(16):2193–7. doi: 10.1097/QAD.0000000000001604. PMID: 28723709. Excluded: not a study (letter, editorial, non-systematic review article, no original data).28723709
Jotwani V, Scherzer R, Glidden DV, . Pre-exposure prophylaxis with tenofovir disoproxil fumarate/emtricitabine and kidney tubular dysfunction in HIV-uninfected individuals. J Acquir Immune Defic Syndr. 2018 Jun 2018;78(2):169–74. doi: 10.1097/QAI.0000000000001654. PMID: 29767638. Excluded: wrong outcome.29767638
Kahle EM, Hughes JP, Lingappa JR, . An empiric risk scoring tool for identifying high-risk heterosexual HIV-1-serodiscordant couples for targeted HIV-1 prevention. J Acquir Immune Defic Syndr. 2013 Mar 2013;62(3):339–47. doi: 10.1097/QAI.0b013e31827e622d. PMID: 23187945. Excluded: wrong country.23187945
Kelesidis T, Landovitz RJ. Preexposure prophylaxis for HIV prevention. Curr HIV/AIDS Rep. 2011 Jun;8(2):94–103. doi: 10.1007/s11904-011-0078-4. PMID: 21465112. Excluded: not a study (letter, editorial, non-systematic review article, no original data).21465112
Kenyon C, Colebunders R. Antiretroviral preexposure prophylaxis for HIV prevention. N Engl J Med. 2013 Jan 2013;368(1):82. doi: 10.1056/NEJMc1210464#SA2. PMID: 23281987. Excluded: not a study (letter, editorial, non-systematic review article, no original data).23281987
Kmietowicz Z. Pre-exposure prophylaxis protects against HIV infection in real world setting, study finds. BMJ. 2015;350:h1076. doi: 10.1136/bmj.h1076. PMID: 25716462. Excluded: not a study (letter, editorial, non-systematic review article, no original data).25716462
Koechlin F, Fonner V, . Values and preferences on the use of oral pre-exposure prophylaxis (PrEP) for HIV prevention among populations: a systematic review of the literature. AIDS Behav. 2017;21:1325–35. PMID: 27900502. Excluded: wrong outcome.27900502
Koester KA, Liu A, Eden C, . Acceptability of drug detection monitoring among participants in an open-label pre-exposure prophylaxis study. AIDS Care. 2015;27(10):1199–204. doi: 10.1080/09540121.2015.1039958. PMID: 26001026. Excluded: wrong study design for Key Question.26001026
Krakower D, Ware N, Mitty JA, . HIV providers’ perceived barriers and facilitators to implementing pre-exposure prophylaxis in care settings: a qualitative study. AIDS Behav. 2014 Sep;18(9):1712–21. doi: 10.1007/s10461-014-0839-3. PMID: 24965676. Excluded: wrong outcome.24965676
Kuo I, Olsen H, Patrick R, . Willingness to use HIV pre-exposure prophylaxis among community-recruited, older people who inject drugs in Washington, DC. Drug Alcohol Depend. 2016 Jul 2016;164:8–13. doi: 10.1016/j.drugalcdep.2016.02.044. PMID: 27177804. Excluded: wrong outcome.27177804
Lal L, Audsley J, Murphy DA, . Medication adherence, condom use and sexually transmitted infections in Australian preexposure prophylaxis users. AIDS. 2017 Jul 2017;31(12):1709–14. doi: 10.1097/QAD.0000000000001519. PMID: 28700394. Excluded: wrong outcome.28700394
Lasry A, Sansom SL, Wolitski RJ, . HIV sexual transmission risk among serodiscordant couples: assessing the effects of combining prevention strategies. AIDS. 2014 Jun 2014;28(10):1521–9. doi: 10.1097/QAD.0000000000000307. PMID: 24804859. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.24804859
Lehman DA, Baeten J, McCoy C, . PrEP exposure and the risk of low-frequency drug resistance. Top Antivir Med. START: 2014 Mar 3 CONFERENCE END: 2014 Mar 6, 21st Conference on Retroviruses and Opportunistic Infections, CROI 2014 (21)United States;22(e-1):290–1. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Liegler T, Abdel-Mohsen M, Defechereux P, . Drug resistance among HIV-1 seroconverters in the FEM-PrEP Study. Antivir Ther. 2012;17(5). Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Lippman SA, Koester KA, Amico KR, . Client and provider perspectives on new HIV prevention tools for MSM in the Americas. PLoS One. 2015;10(3):e0121044. doi: 10.1371/journal.pone.0121044. PMID: 25826246. Excluded: wrong study design for Key Question.25826246
Liu A, Cohen S, Follansbee S, . Early experiences implementing pre-exposure prophylaxis (PrEP) for HIV prevention in San Francisco. PLoS Med. 2014 Mar;11(3):e1001613. doi: 10.1371/journal.pmed.1001613. PMID: 24595035. Excluded: wrong study design for Key Question.24595035
Liu C, Ding Y, Ning Z, . Factors influencing uptake of pre-exposure prophylaxis: some qualitative insights from an intervention study of men who have sex with men in China. Sexual Health. 2018 Feb;15(1):39–45. doi: 10.1071/SH17075. PMID: 28859729. Excluded: wrong outcome.28859729
Luz PM, Osher B, Grinsztejn B, . The cost-effectiveness of HIV pre-exposure prophylaxis in men who have sex with men and transgender women at high risk of HIV infection in Brazil. J Int AIDS Soc. 2018 Mar;21(3):e25096. doi: 10.1002/jia2.25096. PMID: 29603888. Excluded: wrong outcome.29603888
Machado DM, de Sant’Anna Carvalho AM, Riera R. Adolescent pre-exposure prophylaxis for HIV prevention: current perspectives. Adolesc Health Med Ther. 2017;8:137–48. doi: 10.2147/AHMT.S112757. PMID: 29238237. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.29238237
Madrasi K, Chaturvedula A, Haberer JE, . Markov mixed effects modeling using electronic adherence monitoring records identifies influential covariates to HIV preexposure prophylaxis. J Clin Pharmacol. doi: 10.1002/jcph.843. PMID: 27922719. Excluded: wrong study design for Key Question.27922719
Manavi K, Clutterbuck D, Mackay R, . A rapid method for identifying high-risk patients consenting for HIV testing: introducing The Edinburgh Risk Assessment Table for HIV testing. Int J STD AIDS. 2006 Apr;17(4):234–6. PMID: 16595045. Excluded: wrong intervention.16595045
Mannheimer S, Hirsch-Moverman Y, Loquere A, . HPTN 067/ADAPT study: A comparison of daily and intermittent pre-exposure prophylaxis dosing for HIV prevention in men who have sex with men and transgender women in New York city. J Int AIDS Soc. 2015;18:24–5. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Marcus JL, Glidden DV, Mayer KH, . No evidence of sexual risk compensation in the iPrEx trial of daily oral HIV preexposure prophylaxis. PLoS One. 2013;8(12):e81997. doi: 10.1371/journal.pone.0081997. PMID: 24367497. Excluded: not a study (letter, editorial, non-systematic review article, no original data).24367497
Marrazzo J, Rabe L, Kelly C, . Herpes simplex virus (HSV) infection in the VOICE (MTN 003) study: Pre-exposure prophylaxis (PrEP) for HIV with daily use of oral tenofovir, oral tenofovir-emtricitabine, or vaginal tenofovir gel. Sex Transm Dis. 2013;89(14). Excluded: wrong study design for Key Question.
Marshall BD, Mimiaga MJ. Uptake and effectiveness of PrEP for transgender women. Lancet HIV. 2015 Dec;2(12):e502–3. doi: 10.1016/S2352-3018(15)00224-6. PMID: 26614960. Excluded: not a study (letter, editorial, non-systematic review article, no original data).26614960
Martin M, Vanichseni S, Suntharasamai P, . Enrollment characteristics and risk behaviors of injection drug users participating in the Bangkok Tenofovir Study, Thailand. PLoS One. 2011;6(9):e25127. doi: 10.1371/journal.pone.0025127. PMID: 21969870. Excluded: wrong intervention.21969870
Martin M, Vanichseni S, Suntharasamai P, . Risk behaviors and risk factors for HIV infection among participants in the Bangkok tenofovir study, an HIV pre-exposure prophylaxis trial among people who inject drugs. PLoS One. 2014;9(3):1–7. doi: 10.1371/journal.pone.0092809. PMID: 24667938. Excluded: wrong comparator.24667938
Martin MT, Vanichseni S, Suntharasamai P, . Preliminary follow-up of injecting drug users receiving preexposure prophylaxis. Top Antivir Med. 2015;23:445–6. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Mayer KH, Chan PA, R RP, . Evolving models and ongoing challenges for HIV preexposure prophylaxis implementation in the United States. J Acquir Immune Defic Syndr. 2018 Feb 2018;77(2):119–27. doi: 10.1097/QAI.0000000000001579. PMID: 29084044. Excluded: wrong outcome.29084044
Mayer KH, Hosek S, Cohen S, . Antiretroviral pre-exposure prophylaxis implementation in the United States: a work in progress. J Int AIDS Soc. 2015;18(4 Suppl 3):19980. doi: 10.7448/IAS.18.4.19980. PMID: 26198345. Excluded: not a study (letter, editorial, non-systematic review article, no original data).26198345
Mayer KH, Mimiaga MJ, Gelman M, . Raltegravir, tenofovir DF, and emtricitabine for postexposure prophylaxis to prevent the sexual transmission of HIV: safety, tolerability, and adherence. J Acquir Immune Defic Syndr. 2012 Apr 2012;59(4):354–9. doi: 10.1097/QAI.0b013e31824a03b8. PMID: 22267017. Excluded: wrong intervention.22267017
Mayer KH, Safren SA, Elsesser SA, . Optimizing pre-exposure antiretroviral prophylaxis adherence in men who have sex with men: Results of a pilot randomized controlled trial of “Life-Steps for PrEP”. AIDS Behav. 2016 Nov 15 doi: 10.1007/s10461-016-1606-4. PMID: 27848089. Excluded: wrong intervention.27848089
McCormack S, Dunn D. Pragmatic open-label randomised trial of preexposure prophylaxis: The PROUD Study. Top Antivir Med. 2015;23:9–10. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
McPherson TD, Sobieszczyk ME, Markowitz M. Cabotegravir in the treatment and prevention of human immunodeficiency virus-1. Expert Opin Investig Drugs. 2018 Apr;27(4):413–20. doi: 10.1080/13543784.2018.1460357. PMID: 29633869. Excluded: wrong intervention.29633869
Mehrotra ML, Glidden DV, McMahan V, . The effect of depressive symptoms on adherence to daily oral PrEP in men who have sex with men and transgender women: A marginal structural model analysis of The iPrEx OLE Study. AIDS Behav. 2016 Jul;20(7):1527–34. doi: 10.1007/s10461-016-1415-9. PMID: 27125241. Excluded: wrong study design for Key Question.27125241
Minnis AM, Gandham S, Richardson BA, . Adherence and acceptability in MTN 001: a randomized cross-over trial of daily oral and topical tenofovir for HIV prevention in women. AIDS Behav. 2013 Feb;17(2):737–47. doi: 10.1007/s10461-012-0333-8. PMID: 23065145. Excluded: wrong intervention.23065145
Minnis AM, van der Straten A, Salee P, . Pre-exposure prophylaxis adherence measured by plasma drug level in MTN-001: Comparison between vaginal gel and oral tablets in two geographic regions. AIDS Behav. 2016 Jul;20(7):1541–8. doi: 10.1007/s10461-015-1081-3. PMID: 25969178. Excluded: wrong comparator.25969178
Molina JM, Capitant C, Spire B, . On demand PrEP with oral TDF-FTC in MSM: Results of the ANRS ipergay trial. Top Antivir Med. 2015;23(10). Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Molina JM, Charreau I, Spire B, . Efficacy, safety, and effect on sexual behaviour of on-demand pre-exposure prophylaxis for HIV in men who have sex with men: an observational cohort study. Lancet HIV. 2017 Sep;4(9):e402–e10. doi: 10.1016/S2352-3018(17)30089-9. PMID: 28747274. Excluded: wrong study design for Key Question.28747274
Montgomery ET, van der Straten A, Stadler J, . Male partner influence on women’s HIV prevention trial participation and use of pre-exposure prophylaxis: the importance of “understanding”. AIDS Behav. 2015 May;19(5):784–93. doi: 10.1007/s10461-014-0950-5. PMID: 25416076. Excluded: wrong outcome.25416076
Moyer VA, U. S. Preventive Services Task Force. Screening for HIV: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013 Jul 2013;159(1):51–60. PMID: 23698354. Excluded: not a study (letter, editorial, non-systematic review article, no original data).23698354
Muganzi DC, Haberer J, Boum Y, . Comparison of adherence measures in a clinical trial of preexposure prophylaxis. Top Antivir Med. 2015;23:448–9. PMID: 26785125. Excluded: not a study (letter, editorial, non-systematic review article, no original data).26785125
Mugwanya KK, Baeten JM, Wyatt C, . Brief report: Frequency of monitoring kidney function in HIV-uninfected persons using daily oral tenofovir disoproxil fumarate pre-exposure prophylaxis. J Acquir Immune Defic Syndr. 2018 Feb 2018;77(2):206–11. doi: 10.1097/QAI.0000000000001575. PMID: 29135656. Excluded: wrong outcome.29135656
Mugwanya KK, Donnell D, Celum C, . Sexual behaviour of heterosexual men and women receiving antiretroviral pre-exposure prophylaxis for hiv prevention: Post-unblinding analysis of the partners PrEP study. Sex Transm Dis. 2013;89(14). Excluded: wrong study design for Key Question.
Mugwanya KK, Donnell D, Celum C, . Sexual behaviour of heterosexual men and women receiving antiretroviral pre-exposure prophylaxis for HIV prevention: a longitudinal analysis. Lancet Infect Dis. 2013 Dec;13(12):1021–8. doi: 10.1016/S1473-3099(13)70226-3. PMID: 24139639. Excluded: wrong outcome.24139639
Mugwanya KK, Wyatt C, Celum C, . Reversibility of glomerular renal function decline in HIV-uninfected men and women discontinuing emtricitabine-tenofovir disoproxil fumarate pre-exposure prophylaxis. J Acquir Immune Defic Syndr. 2016 Apr 2016;71(4):374–80. doi: 10.1097/QAI.0000000000000868. PMID: 26914909. Excluded: wrong outcome.26914909
Mugwanya KK, Wyatt C, Celum C, . Reversibility of kidney function decline in HIV-1-uninfected men and women using preexposure prophylaxis. Top Antivir Med. 2015;23(451). Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Mujugira A, Baeten JM, Donnell D, . Characteristics of HIV-1 serodiscordant couples enrolled in a clinical trial of antiretroviral pre-exposure prophylaxis for HIV-1 prevention. PLoS One. 2011;6(10):e25828. doi: 10.1371/journal.pone.0025828. PMID: 21998703. Excluded: wrong outcome.21998703
Mujugira A, Celum C, Coombs RW, . HIV transmission risk persists during the first 6 months of antiretroviral therapy. J Acquir Immune Defic Syndr. 2016 Aug 2016;72(5):579–84. doi: 10.1097/QAI.0000000000001019. PMID: 27070123. Excluded: wrong comparator.27070123
Murnane PM, Heffron R, Ronald A, . Pre-exposure prophylaxis for HIV-1 prevention does not diminish the pregnancy prevention effectiveness of hormonal contraception. AIDS. 2014 Jul 2014;28(12):1825–30. doi: 10.1097/QAD.0000000000000290. PMID: 24785951. Excluded: not a study (letter, editorial, non-systematic review article, no original data).24785951
Nadery S, Geerlings SE. Pre-exposure prophylaxis (PrEP) in HIV-uninfected individuals with high-risk behaviour. Neth J Med. 2013 Jul–Aug;71(6):295–9. PMID: 23956310. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.23956310
Nagot N, Kankasa C, Tumwine JK, . Extended pre-exposure prophylaxis with lopinavir-ritonavir versus lamivudine to prevent HIV-1 transmission through breastfeeding up to 50 weeks in infants in Africa (ANRS 12174): a randomised controlled trial. Lancet. 2016 Feb 2016;387(10018):566–73. doi: 10.1016/S0140-6736(15)00984-8. PMID: 26603917. Excluded: wrong population.26603917
Newcomb ME, Moran K, Feinstein BA, . Pre-exposure prophylaxis (PrEP) use and condomless anal sex: Evidence of risk compensation in a cohort of young men who have sex with men. J Acquir Immune Defic Syndr. 2018 Apr 2018;77(4):358–64. doi: 10.1097/QAI.0000000000001604. PMID: 29210834. Excluded: wrong study design for Key Question.29210834
Nguyen VK, Greenwald ZR, Trottier H, . Incidence of sexually transmitted infections before and after preexposure prophylaxis for HIV. AIDS. 2018 Feb 2018;32(4):523–30. doi: 10.1097/QAD.0000000000001718. PMID: 29239887. Excluded: wrong study design for Key Question.29239887
Orne-Gliemann J, Balestre E, Tchendjou P, . Increasing HIV testing among male partners. AIDS. 2013 Apr 2013;27(7):1167–77. doi: 10.1097/QAD.0b013e32835f1d8c. PMID: 23343912. Excluded: wrong intervention.23343912
Palanee-Phillips T, Schwartz K, Brown ER, . Characteristics of women enrolled into a randomized clinical trial of dapivirine vaginal ring for HIV-1 prevention. PLoS One. 2015;10(6):e0128857. doi: 10.1371/journal.pone.0128857. PMID: 26061040. Excluded: wrong intervention.26061040
Parker S, Chan PA, Oldenburg CE, . Patient experiences of men who have sex with men using pre-exposure prophylaxis to prevent HIV infection. AIDS Patient Care STDS. 2015 Dec;29(12):639–42. doi: 10.1089/apc.2015.0186. PMID: 26669791. Excluded: wrong outcome.26669791
Parsons JT, Rendina HJ, Grov C, . Accuracy of highly sexually active gay and bisexual men’s predictions of their daily likelihood of anal sex and its relevance for intermittent event-driven HIV pre-exposure prophylaxis. J Acquir Immune Defic Syndr. 2015 Apr 2015;68(4):449–55. doi: 10.1097/QAI.0000000000000507. PMID: 25559594. Excluded: wrong study design for Key Question.25559594
Parsons JT, Rendina HJ, Lassiter JM, . Uptake of HIV pre-exposure prophylaxis (PrEP) in a national cohort of gay and bisexual men in the United States: The motivational PrEP cascade. J Acquir Immune Defic Syndr. 2017:285–92. doi: 10.1097/QAI.0000000000001251. PMID: 28187084. Excluded: wrong outcome.28187084
Pathela P, Braunstein SL, Schillinger JA, . Men who have sex with men have a 140-fold higher risk for newly diagnosed HIV and syphilis compared with heterosexual men in New York City. J Acquir Immune Defic Syndr. 2011 Dec 2011;58(4):408–16. doi: 10.1097/QAI.0b013e318230e1ca. PMID: 21857351. Excluded: wrong outcome.21857351
Pilcher CD, Bisol CA, Paganella MP, . Efficient identification of HIV serodiscordant couples by existing HIV testing programs in South Brazil. PLoS One. 2015;10(11):e0142638. doi: 10.1371/journal.pone.0142638. PMID: 26562436. Excluded: wrong study design for Key Question.26562436
Pintye J, Drake AL, Kinuthia J, . A risk assessment tool for identifying pregnant and postpartum women who may benefit from preexposure prophylaxis. Clin Infect Dis. 2017 Mar 2017;64(6):751–8. doi: 10.1093/cid/ciw850. PMID: 28034882. Excluded: wrong country.28034882
Plosker GL. Emtricitabine/tenofovir disoproxil fumarate: a review of its use in HIV-1 pre-exposure prophylaxis. Drugs. 2013 Mar;73(3):279–91. doi: 10.1007/s40265-013-0024-4. PMID: 23444256. Excluded: not a study (letter, editorial, non-systematic review article, no original data).23444256
Pyra M, Haberer JE, Heffron R, . Brief report: PrEP use during periods of HIV risk among East African women in serodiscordant relationships. J Acquir Immune Defic Syndr. 2018 Jan 2018;77(1):41–5. doi: 10.1097/QAI.0000000000001561. PMID: 29016523. Excluded: wrong study design for Key Question.29016523
Raymond HF, Chen YH, McFarland W. Estimating incidence of HIV infection among men who have sex with men, San Francisco, 2004-2014. AIDS Behav. 2016 Jan;20(1):17–21. PMID: 26471885. Excluded: wrong outcome.26471885
Riddell Jt, Amico KR, Mayer KH. HIV preexposure prophylaxis: A review. JAMA. 2018 Mar 2018;319(12):1261–8. doi: 10.1001/jama.2018.1917. PMID: 29584848. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.29584848
Ridgway JP, Almirol EA, Bender A, . Which patients in the emergency department should receive preexposure prophylaxis? Implementation of a predictive analytics approach. AIDS Patient Care STDS. 2018 May;32(5):202–7. doi: 10.1089/apc.2018.0011. PMID: 29672136. Excluded: wrong study design for Key Question.29672136
Rocha GM, Kerr L, Kendall C, . Risk behavior score: a practical approach for assessing risk among men who have sex with men in Brazil. Braz J Infect Dis. 2018 Mar – Apr;22(2):113–22. doi: 10.1016/j.bjid.2018.02.008. PMID: 29551334. Excluded: wrong country.29551334
Roche M, Youssef E, Gilleece Y, . Do patients adherent on PREP exposed to HIV have seroconversion symptoms and falsely reactive HIV tests? HIV Med. 2014;15(107). Excluded: wrong study design for Key Question.
Sachdev DD, Stojanovski K, Liu AY, . Intentions to prescribe preexposure prophylaxis are associated with self-efficacy and normative beliefs. Clin Infect Dis. 2014 Jun;58(12):1786–7. doi: 10.1093/cid/ciu229. PMID: 24729556. Excluded: not a study (letter, editorial, non-systematic review article, no original data).24729556
Sagaon-Teyssier L, Suzan-Monti M, Demoulin B, . Uptake of PrEP and condom and sexual risk behavior among MSM during the ANRS IPERGAY trial. AIDS Care. 2016 Mar;28: Suppl 1:48–55. doi: 10.1080/09540121.2016.1146653. PMID: 26883400. Excluded: wrong study design for Key Question.26883400
Seidman DL, Weber S, Cohan D. Offering pre-exposure prophylaxis for HIV prevention to pregnant and postpartum women: a clinical approach. J Int AIDS Soc. 2017 Mar 2017;20(Suppl 1):24–30. doi: 10.7448/IAS.20.2.21295. PMID: 28361503. Excluded: not a study (letter, editorial, non-systematic review article, no original data).28361503
Seifert SM, Glidden DV, Meditz AL, . Dose response for starting and stopping HIV preexposure prophylaxis for men who have sex with men.[Erratum appears in Clin Infect Dis. 2015 Jul 2015;61(1):143; PMID: 25957827]. Clin Infect Dis. 2015 Mar 2015;60(5):804–10. doi: 10.1093/cid/ciu916. PMID: 25957827. Excluded: wrong study design for Key Question.25409469
Shen M, Xiao Y, Rong L, . The cost-effectiveness of oral HIV pre-exposure prophylaxis and early antiretroviral therapy in the presence of drug resistance among men who have sex with men in San Francisco. BMC Med. 2018 Apr 2018;16(1):58. doi: 10.1186/s12916-018-1047-1. PMID: 29688862. Excluded: wrong outcome.29688862
Singh S, Song R, Johnson AS, . HIV incidence, prevalence, and undiagnosed infections in U.S. men who have sex with men. Ann Intern Med. 2018 May 2018;168(10):685–94. doi: 10.7326/M17-2082. PMID: 29554663. Excluded: wrong study design for Key Question.29554663
Sivay MV, Zhang Y, Hudelson SE, . Characterization of HIV seroconverters in a TDF/FTC PrEP study: HPTN 067. Top Antivir Med. 2017;25(1):404s. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Solomon MM, Schechter M, Liu AY, . The safety of HIV pre-exposure prophylaxis in the presence of hepatitis B infection. J Int AIDS Soc. 2015;18(46). Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Solomon MM, Schechter M, Liu AY, . The safety of tenofovir-emtricitabine for HIV pre-exposure prophylaxis (PrEP) in individuals with active hepatitis B. J Acquir Immune Defic Syndr. 2016 Mar 2016;71(3):281–6. doi: 10.1097/QAI.0000000000000857. PMID: 26413853. Excluded: wrong study design for Key Question.26413853
Stack C, Oldenburg C, Mimiaga M, . Sexual behavior patterns and PrEP dosing preferences in a large sample of North American men who have sex with men. J Acquir Immune Defic Syndr. 2016 Jan 2016;71(1):94–101. doi: 10.1097/QAI.0000000000000816. PMID: 26371786. Excluded: wrong study design for Key Question.26371786
Tang EC, Vittinghoff E, Anderson PL, . Changes in kidney function associated with daily tenofovir disoproxil fumarate/emtricitabine for HIV preexposure prophylaxis use in the United States Demonstration Project. J Acquir Immune Defic Syndr. 2018 Feb 2018;77(2):193–8. doi: 10.1097/QAI.0000000000001566. PMID: 28991887. Excluded: wrong study design for Key Question.28991887
Tetteh RA, Yankey BA, Nartey ET, . Pre-exposure prophylaxis for HIV prevention: Safety concerns. Drug Saf. 2017 Apr;40(4):273–83. doi: 10.1007/s40264-017-0505-6. PMID: 28130774. Excluded: wrong study design for Key Question.28130774
Thaden JT, Gandhi M, Okochi H, . Seroconversion on preexposure prophylaxis: a case report with segmental hair analysis for timed adherence determination. AIDS. 2018 Jun 2018;32(9):F1–F4. doi: 10.1097/QAD.0000000000001825. PMID: 29683856. Excluded: wrong study design for Key Question.29683856
Thavorn K, Kugathasan H, Tan DHS, . Economic evaluation of HIV pre-exposure prophylaxis strategies: protocol for a methodological systematic review and quantitative synthesis. Syst Rev. 2018 Mar 2018;7(1):47. doi: 10.1186/s13643-018-0710-0. PMID: 29544530. Excluded: not a study (letter, editorial, non-systematic review article, no original data).29544530
Vaccher SJ, Grulich AE, Haire BG, . Validation of participant eligibility for pre-exposure prophylaxis: Baseline data from the PRELUDE demonstration project. PLoS One. 2017;12(9):e0185398. doi: 10.1371/journal.pone.0185398. PMID: 28950022. Excluded: wrong study design for Key Question.28950022
van der Straten A, Stadler J, Montgomery E, . Women’s experiences with oral and vaginal pre-exposure prophylaxis: the VOICE-C qualitative study in Johannesburg, South Africa. PLoS One. 2014;9(2):e89118. doi: 10.1371/journal.pone.0089118. PMID: 24586534. Excluded: wrong outcome.24586534
2Veloso VG, Mesquita F, Grinsztejn B. Pre-exposure prophylaxis for men and transgender women who have sex with men in Brazil: opportunities and challenges. J Int AIDS Soc. 2015;18(4 Suppl 3):20010. doi: 10.7448/IAS.18.4.20010. PMID: 26198347. Excluded: not a study (letter, editorial, non-systematic review article, no original data).26198347
Venter WD, Cowan F, Black V, . Pre-exposure prophylaxis in Southern Africa: feasible or not? J Int AIDS Soc. 2015;18(4 Suppl 3):19979. doi: 10.7448/IAS.18.4.19979. PMID: 26198344. Excluded: not a study (letter, editorial, non-systematic review article, no original data).26198344
Vermeersch S, Callens S, De Wit S, . Health and budget impact of combined HIV prevention - first results of the BELHIVPREV model. Acta Clin Belg. 2018 Feb;73(1):54–67. doi: 10.1080/17843286.2017.1339978. PMID: 28673201. Excluded: wrong study design for Key Question.28673201
Volk JE, Marcus JL, Phengrasamy T, . No new HIV infections with increasing use of HIV preexposure prophylaxis in a clinical practice setting. Clin Infect Dis. 2015 Nov 2015;61(10):1601–3. doi: 10.1093/cid/civ778. PMID: 26334052. Excluded: wrong outcome.26334052
Volk JE, Marcus JL, Phengrasamy T, . Incident hepatitis C virus infections among users of HIV preexposure prophylaxis in a clinical practice setting. Clin Infect Dis. 2015 Jun 2015;60(11):1728–9. doi: 10.1093/cid/civ129. PMID: 25694649. Excluded: not a study (letter, editorial, non-systematic review article, no original data).25694649
Volk JE, Nguyen DP, Hare CB, . HIV infection and drug resistance with unsupervised use of HIV pre-exposure prophylaxis. AIDS Res Hum Retroviruses. 2018 Apr;34(4):329–30. doi: 10.1089/AID.2017.0285. PMID: 29262689. Excluded: not a study (letter, editorial, non-systematic review article, no original data).29262689
Whetham J, Taylor S, Charlwood L, . Pre-exposure prophylaxis for conception (PrEP-C) as a risk reduction strategy in HIV-positive men and HIV-negative women in the UK. AIDS Care. 2014;26(3):332–6. doi: 10.1080/09540121.2013.819406. PMID: 23876052. Excluded: wrong study design for Key Question.23876052
Wilton J, Noor SW, Schnubb A, . High HIV risk and syndemic burden regardless of referral source among MSM screening for a PrEP demonstration project in Toronto, Canada. BMC Public Health. 2018 02 27;18(1):292. doi: 10.1186/s12889-018-5180-8. PMID: 29486737. Excluded: wrong intervention.29486737
Wright E, Grulich A, Roy K, . Australasian society for HIV, viral hepatitis and sexual health medicine HIV pre-exposure prophylaxis: clinical guidelines. Update April 2018. J Virus Erad. 2018 Apr 2018;4(2):143–59. PMID: 29682309. Excluded: not a study (letter, editorial, non-systematic review article, no original data).29682309
Yacoub R, Nadkarni GN, Weikum D, . Elevations in serum creatinine with tenofovir-based HIV pre-exposure prophylaxis: A meta-analysis of randomized placebo-controlled trials. J Acquir Immune Defic Syndr. 2016 Apr 2016;71(4):e115–8. doi: 10.1097/QAI.0000000000000906. PMID: 26627105. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.26627105
Yah CS. Nurturing the continuum of HIV testing, treatment and prevention matrix cascade in reducing HIV transmission. Ethiop J Health Sci. 2017 Nov;27(6):621–30. PMID: 29487471. Excluded: wrong study design for Key Question.29487471
Ying R, Sharma M, Heffron R, . Cost-effectiveness of pre-exposure prophylaxis targeted to high-risk serodiscordant couples as a bridge to sustained ART use in Kampala, Uganda. J Int AIDS Soc. 2015;18(4 Suppl 3):20013. doi: 10.7448/IAS.18.4.20013. PMID: 26198348. Excluded: wrong outcome.26198348
Yun K, Xu JJ, Zhang J, . Female and younger subjects have lower adherence in PrEP trials: a meta-analysis with implications for the uptake of PrEP service to prevent HIV. Sex Transm Dis. 2018 May;94(3):163–8. doi: 10.1136/sextrans-2017-053217. PMID: 28756409. Excluded: systematic review of meta-analysis document used as a source document only to identify individual studies.28756409
Zablotska IB, Selvey C, Guy R, . Expanded HIV pre-exposure prophylaxis (PrEP) implementation in communities in New South Wales, Australia (EPIC-NSW): design of an open label, single arm implementation trial.[Erratum appears in BMC Public Health. 2018 Feb 2018;18(1):297; PMID: 29490635]. BMC Public Health. 2018 02 02;18(1):210. doi: 10.1186/s12889-017-5018-9. PMID: 29394918. Excluded: wrong study design for Key Question.29394918

## Appendix A6 Criteria for Assessing Internal Validity of Individual Studies

### Systematic Reviews

Criteria:

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

Definition of ratings based on above criteria:

Good:: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions
Fair:: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies
Poor:: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

### Case-Control Studies

Criteria:

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls, with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

Definition of ratings based on above criteria:

Good:: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; accurate diagnostic procedures and measurements applied equally to cases and controls; and appropriate attention to confounding variables
Fair:: Recent, relevant, and without major apparent selection or diagnostic workup bias, but response rate less than 80 percent or attention to some but not all important confounding variables
Poor:: Major selection or diagnostic workup bias, response rate less than 50 percent, or inattention to confounding variables

### RCTs and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  ○ For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Definition of ratings based on above criteria:

Good:: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair:: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
Poor:: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of ratings based on above criteria:

Good:: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease
Fair:: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients
Poor:: Has a fatal flaw, such as: Uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

Source: U.S. Preventive Services Task Force Procedure Manual. Accessed at https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes.

## Appendix A7 Expert Reviewers of the Draft Report

❖ Christopher J. Graber, MD, MPH, Associate Clinical Professor of Medicine, David Geffen School of Medicine at University of California, Los Angeles, Greater Los Angeles Healthcare System, Department of Veterans Affairs
❖ Sybil Hosek, PhD, Cook County Health and Hospitals System’s Stroger Hospital, Chicago
❖ Douglas Krakower, MD, Assistant Professor of Medicine, Beth Israel Deaconess Medical Center, Harvard Medical School
❖ Albert Liu, MD, MPH, Clinical Research Director, HIV Prevention Interventions, San Francisco Department of Public Health, Assistant Clinical Professor, University of California, San Francisco School of Medicine
❖ Jamie P. Morano, MD, MPH, Director, Infectious Disease Telehealth Program, James A Haley Veterans Affiars Hospital, Assistant Professor, University of South Florida, Morsani College of Medicine
❖ Jeffrey Murray, MD, MPH, Deputy Director, Division of Antiviral Products, Center for Drug Evaluation Research, U.S. Food and Drug Aministration
❖ Brandy Peaker, MD, MPH, Liaison, Centers for Disease Control and Prevention
❖ Dawn Smith, MD, MPH, MS, Division of HIV/AIDS Prevention, Centers for Disease Control and Prevention

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the report findings.