# References

1 Chou R, Cantor A, Zakher B, . Screening for HIV in pregnant women: systematic review to update the 2005 U.S. Preventive Services Task Force recommendation. Ann Intern Med. 2012;457:719–28. doi: 10.7326/0003-4819-157-10-201211200-00009. PMID: 23165663.23165663
2 Chou R, Cantor A, Bougatsos C, . Screening for HIV in pregnant women: systematic review to update the U.S. Preventive Services Task Force Recommendation. Evidence synthesis No. 96. Agency for Healthcare Research and Quality. AHRQ Publication No. 12-05173-EF-2. Rockville, MD: 2012. PMID: 2325621923256219.
3 Moyer VA, on behalf of the U.S. Preventive Services Task Force. Screening for HIV: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2013 Jul 2;159(1):51–60. doi: 10.7326/0003-4819-159-1-201307020-00645. PMID: 23698354.23698354
4 U.S Services Task Force. Recommendation: Human Immunodeficiency Virus (HIV) Infection: Screening. 2013. www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryFinal/human-immunodeficiency-virus-hiv-infection-screening?ds=1&s=pregnant. Accessed December 12, 2017.
5 Centers for Disease Control and Prevention. 1993 Revised classification system for HIV infection and expanded surveillance case definition for AIDS among adolescents and adults. MMWR Recomm Rep. 1992 December 18;41(RR-17):1–19. PMID: 1361652.1361652
6 Centers for Disease Control and Prevention. HIV-2 infection surveillance- United States: 1987-2009. 2011. www.cdc.gov/mmwr/preview/mmwrhtml/mm6029a3.htm. Accessed December 8, 2017.
7 Centers for Disease Control and Prevention. HIV/AIDS HIV among pregnant women, infants, and children. 2016. http://www.cdc.gov/hiv/group/gender/pregnantwomen/index.html. Accessed October 28, 2016.
8 Centers for Disease Control and Prevention. HIV Surveillance Report: Diagnoses of HIV Infection in the United States and Dependent Areas, 2016. www.cdc.gov/hiv/pdf/library/reports/surveillance/cdc-hiv-surveillance-report-2016-vol-28.pdf Accessed December 12, 2017.
9 Centers for Disease Control and Prevention. HIV Surveillance Report, 2017; vol. 29. http://www.cdc.gov/hiv/library/reports/hiv-surveillance.html Published November 2018. Accessed 4/8/19. 2017.
10 Centers for Disease Control and Prevention. HIV Among Women. https://www.cdc.gov/hiv/group/gender/women/index.html Accessed 4/8/19.
11 Centers for Disease Control and Prevention. HIV Surveillance Supplemental Report: Commentary; Vol 16. No. 2. 2010. http://www.cdc.gov/hiv/surveillance/resources/reports/2010supp_vol16no2/pdf/commentary.pdf. Accessed October 31, 2016.
12 Fowler MG, Gable AR, Lampe MA, . Perinatal HIV and its prevention: progress toward an HIV-free generation. Clin Perinatol. 2010;37(4):699–719. PMID: 21078445.21078445
13 Centers for Disease Control and Prevention. HIV Among Pregnant Women, Infants, and Children. 2017. www.cdc.gov/hiv/pdf/group/gender/pregnantwomen/cdc-hiv-pregnant-women.pdf Accessed December 23, 2017.
14 Little KM, Taylor AW, Borkowf CB, . Perinatal antiretroviral exposure and prevented mother-to-child HIV infections in the era of antiretroviral prophylaxis in the United States, 1994-2010. Pediatr Infect Dis J. 2017 Jan;36(1):66–71. doi: 10.1097/INF.0000000000001355. PMID: 27749662.27749662
15 Nesheim SR, Wiener J, Fitz Harris LF, . Brief report: estimated incidence of perinatally acquired HIV infection in the United States, 1978-2013. J Acquir Immune Defic Syndr. 2017 Dec 15;76(5):461–4. doi: 10.1097/QAI.0000000000001552. PMID: 28991886.28991886
16 American Congress of Obstetricians and Gynecologists. Committee opinion: scheduled cesarean delivery and the prevention of vertical transmission of HIV infection. No. 234, May 2000; reaffirmed 2010. 2010. www.acog.org/~/media/Committee%20Opinions/Committee%20on%20Obstetric%20Practice/co234.ashx?dmc=1&ts=20120105T1247277577. Accessed October 31, 2016.
17 Read JS, AIDS CoP. Human milk, breastfeeding, and transmission of human immunodeficiency virus type 1 in the United States. Pediatrics. 2003 November 1, 2003;112(5):1196–205. PMID: 14595069.14595069
18 Dunn DT, Newell ML, Ades AE, . Risk of human immunodeficiency virus type 1 transmission through breastfeeding. Lancet. 1992;340(8819):585–8. doi: 10.1016/0140-6736(92)92115-v. PMID: 1355163.1355163
19 Nduati R. Breastfeeding and HIV-1 infection: short and long term effects of breast feeding on child health. In: Koletzko B, Michaelsen KF, Hernell O, eds. Short and Long Term Effects of Breast Feeding on Child Health. Vol. 478. Springer US; 2002:201–10.
20 Department of Health and Human Services. Reducing Obstetrician Barriers to offering HIV Testing. 2002. http://www.cdc.gov/hiv/topics/perinatal/resources/meetings/2002/pdf/ps_oig.pdf. Accessed October 31, 2016.
21 Breastfeeding and HIV International Transmission Study Group, Coutsoudis A, Dabis F, . Late postnatal transmission of HIV-1 in breast-fed children: an individual patient data meta-analysis. J Infect Dis. 2004 June 15, 2004;189(12):2154–66. doi: 10.1086/420834. PMID: 15181561.15181561
22 Mofenson LM. Antiretroviral drugs to prevent breastfeeding HIV transmission. [Review]. Antivir Ther. 2010;15(4):537–53. PMID: 20587847.20587847
23 Panel on Treatment of Pregnant Women with HIV Infection and Prevention of Perinatal Transmission. Recommendations for Use of Antiretroviral Drugs in Pregnant Women with HIV Infection and Interventions to Reduce Perinatal HIV Transmission in the United States. Version December 7, 2018. https://aidsinfo.nih.gov/guidelines/html/3/perinatal/224/whats-new-in-the-guidelines.
24 Centers for Disease Control and Prevention. HIV/AIDS HIV Among Women. 2016. http://www.cdc.gov/hiv/group/gender/women/. Accessed October 28, 2016.
25 Kourtis AP, Bulterys M. Mother-to-child transmission of HIV: pathogenesis, mechanisms and pathways. Clin Perinatol. 2010;37:721–37. PMID: 21078446.21078446
26 French R, Brocklehurst P. The effect of pregnancy on survival in women infected with HIV: a systematic review of the literature and meta-analysis. Br J Obstet Gynaecol. 1998 Aug;105(8):827–35. PMID: 9746374.9746374
27 Minkoff H, Hershow R, Watts DH, . The relationship of pregnancy to human immunodeficiency virus disease progression. Am J Obstet Gynecol. 2003;189(2):552–9. doi: 10.1067/s0002-9378(03)00467-8. PMID: 14520233.14520233
28 American Congress of Obstetricians and Gynecologists. ACOG committee opinion: prenatal and perinatal human immunodeficiency virus testing: expanded recommendations. June 2015, No. 635. Obstet Gynecol. 2011;125(6):1544–7. doi: 10.1097/01.AOG.0000466370.86393.d2. PMID: 26000543.26000543
29 Centers for Disease Control and Prevention. Preexposure prophylaxis for the prevention of HIV infection in the United States - 2014. 2014. http://www.cdc.gov/hiv/pdf/guidelines/PrEPguidelines2014.pdf Accessed October 28, 2016.
30 Celum CL, Coombs RW, Jones M, . Risk factors for repeatedly reactive HIV-1 EIA and indeterminate western blots. A population-based case-control study. Arch Intern Med. 1994 May 23;154(10):1129–37. PMID: 7910452.7910452
31 Bulterys M, Jamieson DJ, O’Sullivan MJ, . Rapid HIV-1 testing during labor: a multicenter study. JAMA. 2004 Jul 14;292(2):219–23. PMID: 15249571.15249571
32 Branson BM, Handsfield HH, Lampe MA, . Revised recommendations for HIV testing of adults, adolescents, and pregnant women in health-care settings. MMWR Recomm Rep. 2006 Sep 22;55(RR-14):1–17. PMID: 16988643.16988643
33 American Congress of Obstetricians and Gynecologists. ACOG Committee Opinion No. 752: Prenatal and Perinatal Human Immunodeficiency Virus Testing. Obstet Gynecol. 2018;132(3):e138–e42.30134428
34 American Academy of Pediatrics Committee on Pediatric AIDS. HIV testing and prophylaxis to prevent mother-to-child transmission in the United States. Pediatrics. 2008 Nov;122(5):1127–34. PMID: 18977995.18977995
35 American Academy of Pediatrics. Policy statement: AAP publications reaffirmed and retired: policy statement: HIV testing and prophylaxis to prevent mother-to-child transmission in the United States. Reaffirmed June 2011. Pediatrics; 2011. pediatrics.aappublications.org/content/128/3/e748.full. Accessed December 27, 2017.
36 Qaseem A, Snow V, Shekelle P, . Screening for HIV in health care settings: a guidance statement from the American College of Physicians and HIV Medicine Association. Ann Intern Med. 2009;150:125–31. PMID: 19047022.19047022
37 Centers for Disease Control and Prevention. HIV Testing in Clinical Settings. www.cdc.gov/hiv/testing/clinical/index.html. Accessed December 23, 2017.
38 American Academy of Family Physicians. Summary of recommendations for clinical preventive services. 2016. www.aafp.org/dam/AAFP/documents/patient_care/clinical_recommendations/cps-recommendations.pdf Accessed October 28, 2016.
39 U.S. Preventive Services Task Force. Procedure Manual. 2016. www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes. Accessed October 31, 2016.
40 Chou R, Smits AK, Huffman LH, . Prenatal screening for HIV: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2005 Jul 5;143(1):38–54. PMID: 15998754.15998754
41 Chou R, Smits AK, Huffman LH, . Screening for human immunodeficiency virus in pregnant women: Evidence synthesis No. 39. Rockville, MD: Agency for Healthcare Research and Quality. 2005. www.ahrq.gov/downloads/pub/prevent/pdfser/hivpresyn.pdf Accessed October 31, 2016. PMID: 2072213520722135.
42 Chou R. Screening for HIV Infection in Asymptomatic, Nonpregnant Adolescents and Adults: A Systematic Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 176. AHRQ Publication No. 18-05246-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2019.
43 Mofenson ML, Baggaley CR, Mameletzis CI. Tenofovir disoproxil fumarate safety for women and their infants during pregnancy and breastfeeding. AIDS. 2017 Jan 14;31(2):213–32. doi: 10.1097/QAD.0000000000001313. PMID: 27831952.27831952
44 Fowler MG, Qin M, Fiscus SA, . Benefits and risks of antiretroviral therapy for perinatal HIV prevention. N Engl J Med. 2016 Nov 03;375(18):1726–37. doi: 10.1056/NEJMoa1511691. PMID: 27806243.27806243
45 Sartorius BK, Chersich MF, Mwaura M, . Maternal anaemia and duration of zidovudine in antiretroviral regimens for preventing mother-to-child transmission: a randomized trial in three African countries. BMC Infect Dis. 2013;13:522. doi: 10.1186/1471-2334-13-522. PMID: 24192332.24192332
46 Aaron E, Bonacquisti A, Mathew L, . Small-for-gestational-age births in pregnant women with HIV, due to severity of HIV disease, not antiretroviral therapy. Infect Dis Obstet Gynecol. 2012;2012:135030. doi: 10.1155/2012/135030. PMID: 22778533.22778533
47 Antiretroviral Pregnancy Registry Steering Committee. Antiretroviral Pregnancy Registry Interim Report for 1 January 1989 through 31 January 2018. Wilmington, NC: Registry Coordinating Center; 2018. http://www.apregistry.com/forms/interim_report.pdf Accessed July 27, 2018.
48 Berard A, Sheehy O, Zhao JP, . Antiretroviral combination use during pregnancy and the risk of major congenital malformations. AIDS. 2017 Oct 23;31(16):2267–77. doi: 10.1097/QAD.0000000000001610. PMID: 28806195.28806195
49 Chagomerana MB, Miller WC, Pence BW, . PMTCT option B+ does not increase preterm birth risk and may prevent extreme prematurity: A retrospective cohort study in Malawi. J Acquir Immune Defic Syndr. 2017 Apr 01;74(4):367–74. doi: 10.1097/QAI.0000000000001253. PMID: 27875363.27875363
50 Chen JY, Ribaudo HJ, Souda S, . Highly active antiretroviral therapy and adverse birth outcomes among HIV-infected women in Botswana. J Infect Dis. 2012 Dec 1;206(11):1695–705. doi: 10.1093/infdis/jis553. PMID: 23066160.23066160
51 Chiappini E, Galli L, Giaquinto C, . Use of combination neonatal prophylaxis for the prevention of mother-to-child transmission of HIV infection in European high-risk infants. AIDS. 2013 Mar 27;27(6):991–1000. doi: 10.1097/QAD.0b013e32835cffb1. PMID: 23211776.23211776
52 Duryea E, Nicholson F, Cooper S, . The use of protease inhibitors in pregnancy: maternal and fetal considerations. Infect Dis Obstet Gynecol. 2015 doi: 10.1155/2015/563727. PMID: 26617456.26617456
53 Floridia M, Mastroiacovo P, Tamburrini E, . Birth defects in a national cohort of pregnant women with HIV infection in Italy, 2001-2011. BJOG. 2013 Nov;120(12):1466–75. doi: 10.1111/1471-0528.12285. PMID: 23721372.23721372
54 Kakkar F, Boucoiran I, Lamarre V, . Risk factors for pre-term birth in a Canadian cohort of HIV-positive women: role of ritonavir boosting? J Int AIDS Soc. 2015;18:19933. doi: 10.7448/IAS.18.1.19933. PMID: 26051165.26051165
55 Knapp KM, Brogly SB, Muenz DG, . Prevalence of congenital anomalies in infants with in utero exposure to antiretrovirals. Pediatr Infect Dis J. 2012 Feb;31(2):164–70. doi: 10.1097/INF.0b013e318235c7aa. PMID: 21983213.21983213
56 Kreitchmann R, Li SX, Melo VH, . Predictors of adverse pregnancy outcomes in women infected with HIV in Latin America and the Caribbean: a cohort study. BJOG. 2014 Nov;121(12):1501–8. doi: 10.1111/1471-0528.12680. PMID: 24602102.24602102
57 Li N, Sando MM, Spiegelman D, . Antiretroviral therapy in relation to birth outcomes among HIV-infected women: a cohort study. J Infect Dis. 2016 Apr 1;213(7):1057–64. doi: 10.1093/infdis/jiv389. PMID: 26265780.26265780
58 Lipshultz SE, Williams PL, Zeldow B, . Cardiac effects of in-utero exposure to antiretroviral therapy in HIV-uninfected children born to HIV-infected mothers. AIDS. 2015 Jan 2;29(1):91–100. doi: 10.1097/QAD.0000000000000499. PMID: 25562493.25562493
59 Lopez M, Figueras F, Hernandez S, . Association of HIV infection with spontaneous and iatrogenic preterm delivery: effect of HAART. AIDS. 2012 Jan 02;26(1):37–43. doi: 10.1097/QAD.0b013e32834db300. PMID: 22008651.22008651
60 Lu D, Liu J, Samson L, . Factors responsible for mother-to-child HIV transmission in Ontario, Canada, 1996-2008. Can J Public Health. 2014 Jan-Feb;105(1):e47–52. PMID: 24735697.24735697
61 Mandelbrot L, Tubiana R, Le Chenadec J, . No perinatal HIV-1 transmission from women with effective antiretroviral therapy starting before conception. Clin Infect Dis. 2015 Dec 1;61(11):1715–25. doi: 10.1093/cid/civ578. PMID: 26197844.26197844
62 Moodley T, Moodley D, Sebitloane M, . Improved pregnancy outcomes with increasing antiretroviral coverage in South Africa. BMC Pregnancy Childbirth. 2016 Feb 11;16:35. doi: 10.1186/s12884-016-0821-3. PMID: 26867536.26867536
63 Mor Z, Sheffer R, Chemtob D. Mother-to-child HIV transmissions in Israel, 1985-2011. Epidemiol Infect. 2017 Jul;145(9):1913–21. doi: 10.1017/s0950268817000577. PMID: 28374653.28374653
64 Nozyce ML, Huo Y, Williams PL, . Safety of in utero and neonatal antiretroviral exposure: cognitive and academic outcomes in HIV-exposed, uninfected children 5-13 years of age. Pediatr Infect Dis J. 2014 Nov;33(11):1128–33. doi: 10.1097/INF.0000000000000410. PMID: 25361407.25361407
65 Pintye J, Baeten JM, Celum C, . Maternal tenofovir disoproxil fumarate use during pregnancy is not associated with adverse perinatal outcomes among HIV-infected East African women: A prospective study. J Infect Dis. 2017 Dec 19;216(12):1561–8. doi: 10.1093/infdis/jix542. PMID: 29040666.29040666
66 Ramokolo V, Goga AE, Lombard C, . In utero ART exposure and birth and early growth outcomes among HIV-exposed uninfected infants attending immunization services: Results from National PMTCT Surveillance, South Africa. Open Forum Infect. 2017 Fall. Fall;4(4):ofx187. doi: 10.1093/ofid/ofx187. PMID: 29062860.29062860
67 Rough K, Seage GR, 3rd, Williams PL, . Birth outcomes for pregnant women with HIV using tenofovir-emtricitabine. N Engl J Med. 2018 04 26;378(17):1593–603. doi: 10.1056/NEJMoa1701666. PMID: 29694825.29694825
68 Short CE, Douglas M, Smith JH, . Preterm delivery risk in women initiating antiretroviral therapy to prevent HIV mother-to-child transmission. HIV Med. 2014 Apr;15(4):233–8. doi: 10.1111/hiv.12083. PMID: 24025074.24025074
69 Siberry GK, Williams PL, Mendez H, . Safety of tenofovir use during pregnancy: early growth outcomes in HIV-exposed uninfected infants. AIDS. 2012 Jun 1;26(9):1151–9. doi: 10.1097/QAD.0b013e328352d135. PMID: 22382151.22382151
70 Sibiude J, Le Chenadec J, Bonnet D, . In utero exposure to zidovudine and heart anomalies in the ANRS French perinatal cohort and the nested PRIMEVA randomized trial. Clin Infect Dis. 2015 Jul 15;61(2):270–80. doi: 10.1093/cid/civ260. PMID: 25838291.25838291
71 Sibiude J, Mandelbrot L, Blanche S, . Association between prenatal exposure to antiretroviral therapy and birth defects: an analysis of the French perinatal cohort study (ANRS CO1/CO11). PLoS Med. 2014 Apr;11(4):e1001635. doi: 10.1371/journal.pmed.1001635. PMID: 24781315.24781315
72 Sibiude J, Warszawski J, Tubiana R, . Premature delivery in HIV-infected women starting protease inhibitor therapy during pregnancy: role of the ritonavir boost? Clin Infect Dis. 2012 May;54(9):1348–60. doi: 10.1093/cid/cis198. PMID: 22460969.22460969
73 Snijdewind IJM, Smit C, Godfried MH, . Preconception use of cART by HIV-positive pregnant women increases the risk of infants being born small for gestational age. PLoS ONE. 2018;13(1):e0191389. doi: 10.1371/journal.pone.0191389. PMID: 29351561.29351561
74 Tookey PA, Thorne C, van Wyk J, . Maternal and foetal outcomes among 4118 women with HIV infection treated with lopinavir/ritonavir during pregnancy: analysis of population-based surveillance data from the national study of HIV in pregnancy and childhood in the United Kingdom and Ireland. BMC Infect Dis. 2016;16:65. doi: 10.1186/s12879-016-1400-y. PMID: 26847625.26847625
75 Watts DH, Williams PL, Kacanek D, . Combination antiretroviral use and preterm birth. J Infect Dis. 2013 Feb 15;207(4):612–21. doi: 10.1093/infdis/jis728. PMID: 23204173.23204173
76 Williams PL, Crain MJ, Yildirim C, . Congenital anomalies and in utero antiretroviral exposure in human immunodeficiency virus-exposed uninfected infants. JAMA Pediatr. 2015;169(1):48–55. doi: 10.1001/jamapediatrics.2014.1889. PMID: 25383770.25383770
77 Williams PL, Hazra R, Van Dyke RB, . Antiretroviral exposure during pregnancy and adverse outcomes in HIV-exposed uninfected infants and children using a trigger-based design. AIDS. 2016 Jan 2;30(1):133–44. doi: 10.1097/QAD.0000000000000916. PMID: 26731758.26731758
78 Zash R, Jacobson DL, Diseko M, . Comparative safety of antiretroviral treatment regimens in pregnancy. JAMA Pediatr. 2017 Oct 02;171(10):e172222. doi: 10.1001/jamapediatrics.2017.2222. PMID: 28783807.28783807
79 Zash R, Souda S, Chen JY, . Reassuring birth outcomes with tenofovir/emtricitabine/efavirenz used for prevention of mother-to-child transmission of HIV in Botswana. J Acquir Immune Defic Syndr. 2016 Apr 1;71(4):428–36. doi: 10.1097/QAI.0000000000000847. PMID: 26379069.26379069
80 Gray G, Violari A, McIntyre J, . Antiviral activity of nucleoside analogues during short-course monotherapy or dual therapy: its role in preventing HIV infection in infants. J Acquir Immune Defic Syndr. 2006 Jun;42(2):169–76. doi: 10.1097/01.qai.0000219772.74432.20. PMID: 16639342.16639342
81 Shapiro RL, Thior I, Gilbert PB, . Maternal single-dose nevirapine versus placebo as part of an antiretroviral strategy to prevent mother-to-child HIV transmission in Botswana. AIDS. 2006 Jun 12;20(9):1281–8. doi: 10.1097/01.aids.0000232236.26630.35. PMID: 16816557.16816557
82 Chi BH, Chintu N, Cantrell RA, . Addition of single-dose tenofovir and emtricitabine to intrapartum nevirapine to reduce perinatal HIV transmission. J Acquir Immune Defic Syndr. 2008 Jun 1;48(2):220–3. doi: 10.1097/QAI.0b013e3181743969. PMID: 18520682.18520682
83 Powis KM, Kitch D, Ogwu A, . Increased risk of preterm delivery among HIV-infected women randomized to protease versus nucleoside reverse transcriptase inhibitor-based HAART during pregnancy. J Infect Dis. 2011 Aug 15;204(4):506–14. doi: 10.1093/infdis/jir307. PMID: 21791651.21791651
84 Chi BH, Sinkala M, Mbewe F, . Single-dose tenofovir and emtricitabine for reduction of viral resistance to non-nucleoside reverse transcriptase inhibitor drugs in women given intrapartum nevirapine for perinatal HIV prevention: an open-label randomised trial. Lancet. 2007;370(9600):1698–705. doi: 10.1016/s0140-6736(07)61605-5. PMID: 1799715.17997151
85 Kesho Bora Study Group. Eighteen-month follow-up of HIV-1-infected mothers and their children enrolled in the Kesho Bora study observational cohorts. J Acquir Immune Defic Syndr. 2010 August 15, 2010;54(5):533–41. PMID: 20543706.20543706
86 Kesho Bora Study Group, de Vincenzi I. Triple antiretroviral compared with zidovudine and single-dose nevirapine prophylaxis during pregnancy and breastfeeding for prevention of mother-to-child transmission of HIV-1 (Kesho Bora study): a randomised controlled trial. Lancet Infect Dis. 2011;11(3):171–80. doi: 10.1016/S1473-3099(10)70288-7. PMID: 21237718.21237718
87 Shapiro RL, Hughes MD, Ogwu A, . Antiretroviral regimens in pregnancy and breast-feeding in Botswana. N Engl J Med. 2010;362(24):2282–94. doi: 10.1056/NEJMoa0907736. PMID: 20554983.20554983
88 Thistle P, Spitzer RF, Glazier RH, . A randomized, double-blind, placebo-controlled trial of combined nevirapine and zidovudine compared with nevirapine alone in the prevention of perinatal transmission of HIV in Zimbabwe. Clin Infect Dis. 2007 Jan;44(1):111–9. PMID: 17143826.17143826
89 Alimenti A, Forbes JC, Oberlander TF, . A prospective controlled study of neurodevelopment in HIV-uninfected children exposed to combination antiretroviral drugs in pregnancy. Pediatrics. 2006 Oct;118(4):e1139–45. doi: 10.1542/peds.2006-0525. PMID: 16940166.16940166
90 Townsend CL, Willey BA, Cortina-Borja M, . Antiretroviral therapy and congenital abnormalities in infants born to HIV-infected women in the UK and Ireland, 1990-2007. AIDS. 2009 Feb 20;23(4):519–24. doi: 10.1097/QAD.0b013e328326ca8e. PMID: 19165088.19165088
91 Watts DH, Huang S, Culnane M, . Birth defects among a cohort of infants born to HIV-infected women on antiretroviral medication. J Perinat Med. 2011 Mar;39(2):163–70. doi: 10.1515/jpm.2010.139. PMID: 21142844.21142844
92 Cotter AM, Garcia AG, Duthely ML, . Is antiretroviral therapy during pregnancy associated with an increased risk of preterm delivery, low birth weight, or stillbirth? J Infect Dis. 2006 May 1;193(9):1195–201. doi: 10.1086/503045. PMID: 16586354.16586354
93 European Collaborative Study. HIV-infected pregnant women and vertical transmission in Europe since 1986. AIDS. 2001 Apr 13;15(6):761–70. PMID: 11371691.11371691
94 Grosch-Woerner I, Puch K, Maier RF, . Increased rate of prematurity associated with antenatal antiretroviral therapy in a German/Austrian cohort of HIV-1-infected women. HIV Med. 2008 Jan;9(1):6–13. doi: 10.1111/j.1468-1293.2008.00520.x. PMID: 18199167.18199167
95 Lipshultz SE, Easley KA, Orav EJ, . Absence of cardiac toxicity of zidovudine in infants. Pediatric pulmonary and cardiac complications of vertically transmitted HIV infection study group. N Engl J Med. 2000 Sep 14;343(11):759–66. doi: 10.1056/nejm200009143431102. PMID: 10984563.10984563
96 Lipshultz SE, Shearer WT, Thompson B, . Cardiac effects of antiretroviral therapy in HIV-negative infants born to HIV-positive mothers: NHLBI CHAART-1 (National Heart, Lung, and Blood Institute Cardiovascular Status of HAART Therapy in HIV-Exposed Infants and Children cohort study). J Am Coll Cardiol. 2011 Jan 4;57(1):76–85. doi: 10.1016/j.jacc.2010.08.620. PMID: 21185505.21185505
97 Marti C, Pena JM, Bates I, . Obstetric and perinatal complications in HIV-infected women. Analysis of a cohort of 167 pregnancies between 1997 and 2003. Acta Obstet Gynecol Scand. 2007;86(4):409–15. doi: 10.1080/00016340601148531. PMID: 17486461.17486461
98 Patel D, Thorne C, Fiore S, . Does highly active antiretroviral therapy increase the risk of congenital abnormalities in HIV-infected women? J Acquir Immune Defic Syndr. 2005 Sep 1;40(1):116–8. PMID: 16123696.16123696
99 Schulte J, Dominguez K, Sukalac T, . Declines in low birth weight and preterm birth among infants who were born to HIV-infected women during an era of increased use of maternal antiretroviral drugs: Pediatric Spectrum of HIV Disease, 1989-2004. Pediatrics. 2007 Apr;119(4):e900–6. doi: 10.1542/peds.2006-1123. PMID: 17353299.17353299
100 Townsend CL, Cortina-Borja M, Peckham CS, . Antiretroviral therapy and premature delivery in diagnosed HIV-infected women in the United Kingdom and Ireland. AIDS. 2007 May 11;21(8):1019–26. doi: 10.1097/QAD.0b013e328133884b. PMID: 17457096.17457096
101 Tuomala RE, Watts DH, Li D, . Improved obstetric outcomes and few maternal toxicities are associated with antiretroviral therapy, including highly active antiretroviral therapy during pregnancy. J Acquir Immune Defic Syndr. 2005 Apr 1;38(4):449–73. PMID: 15764963.15764963
102 Watts DH, Balasubramanian R, Maupin RT, Jr., . Maternal toxicity and pregnancy complications in human immunodeficiency virus-infected women receiving antiretroviral therapy: PACTG 316. Am J Obstet Gynecol. 2004 Feb;190(2):506–16. doi: 10.1016/j.ajog.2003.07.018. PMID: 14981398.14981398
103 Williams PL, Marino M, Malee K, . Neurodevelopment and in utero antiretroviral exposure of HIV-exposed uninfected infants. Pediatrics. 2010 Feb;125(2):e250–60. doi: 10.1542/peds.2009-1112. PMID: 20083530.20083530
104 Briand N, Mandelbrot L, Le Chenadec J, . No relation between in-utero exposure to HAART and intrauterine growth retardation. AIDS. 2009 Jun 19;23(10):1235–43. doi: 10.1097/QAD.0b013e32832be0df. PMID: 19424054.19424054
105 Cooper ER, Charurat M, Mofenson L, . Combination antiretroviral strategies for the treatment of pregnant HIV-1-infected women and prevention of perinatal HIV-1 transmission. J Acquir Immune Defic Syndr. 2002;29(5):484–94.11981365
106 European Collaborative Study. Mother-to-child transmission of HIV infection in the era of highly active antiretroviral therapy. Clin Infect Dis. 2005;40(3):458–65.15668871
107 Italian Register for Human Immunodeficiency Virus Infection in Children. Determinants of mother-to-infant human immunodeficiency virus 1 transmission before and after the introduction of zidovudine prophylaxis. Arch Pediatr Adolesc Med. 2002;156(9):915–21.12197800
108 Mandelbrot L, Landreau-Mascaro A, Rekacewicz C, . Lamivudine-zidovudine combination for prevention of maternal-infant transmission of HIV-1. JAMA. 2001;285(16):2083–93.11311097
109 Tuomala RE, Shapiro DE, Mofenson LM, . Antiretroviral therapy during pregnancy and the risk of an adverse outcome. N Engl J Med. 2002 Jun 13;346(24):1863–70. doi: 10.1056/NEJMoa991159. PMID: 12063370.12063370
110 Garcia-Tejedor A, Maiques V, Perales A, . Influence of highly active antiretroviral treatment (HAART) on risk factors for vertical HIV transmission. Acta Obstet Gynecol Scand. 2009;88(8):882–7. PMID: 19557554.19557554
111 Harris NS, Fowler MG, Sansom SL, . Use of enhanced perinatal human immunodeficiency virus surveillance methods to assess antiretroviral use and perinatal human immunodeficiency virus transmission in the United States, 1999-2001. Am J Obstet Gynecol. 2007 Sep;197:(3 Suppl):S33–41. PMID: 17825649.17825649
112 Tariq S, Townsend CL, Cortina-Borja M, . Use of zidovudine-sparing HAART in pregnant HIV-infected women in Europe: 2000-2009.[Erratum appears in J Acquir Immune Defic Syndr. 2011 Aug 15;57(5):e117]. J Acquir Immune Defic Syndr. 2011 Aug 1;57(4):326–33. PMID: 21499113.21499113
113 Townsend CL, Cortina-Borja M, Peckham CS, . Low rates of mother-to-child transmission of HIV following effective pregnancy interventions in the United Kingdom and Ireland, 2000-2006. AIDS. 2008 May 11;22(8):973–81. PMID: 18453857.18453857
114 Brocklehurst P. Interventions for reducing the risk of mother-to-child transmission of HIV infection. Cochrane Database Syst Rev. 2002(1):Cd000102. doi: 10.1002/14651858.Cd000102. PMID: 11869564.11869564
115 Liao C, Golden WC, Anderson JR, . Missed opportunities for repeat HIV testing in pregnancy: Implications for elimination of mother-to-child transmission in the United States. Aids Patient Care STDS. 2017 Jan;31(1):20–6. doi: 10.1089/apc.2016.0204. PMID: 27936863.27936863
116 Williams B, Costello M, McHugh E, . Repeat antenatal HIV testing in the third trimester: a study of feasibility and maternal uptake rates. HIV Med. 2014 Jul;15(6):362–6. doi: 10.1111/hiv.12110. PMID: 24215444.24215444
117 Criniti SM, Aaron E, Levine AB. Using the rapid HIV test to rescreen women in the third trimester of pregnancy. J Midwifery Womens Health. 2009 Nov-Dec;54(6):492–6. doi: 10.1016/j.jmwh.2009.03.009. PMID: 19879522.19879522
118 Sansom SL, Jamieson DJ, Farnham PG, . Human immunodeficiency virus retesting during pregnancy: costs and effectiveness in preventing perinatal transmission. Obstet Gynecol. 2003 Oct;102(4):782–90. PMID: 14551009.14551009
119 Connor EM, Sperling RS, Gelber R, . Reduction of maternal-infant transmission of human immunodeficiency virus type 1 with zidovudine treatment. Pediatric AIDS Clinical Trials Group Protocol 076 Study Group. N Engl J Med. 1994 Nov 3;331(18):1173–80. doi: 10.1056/nejm199411033311801. PMID: 7935654.7935654
120 Birkhead GS, Pulver WP, Warren BL, . Acquiring human immunodeficiency virus during pregnancy and mother-to-child transmission in New York: 2002-2006. Obstet Gynecol. 2010 Jun;115(6):1247–55. doi: 10.1097/AOG.0b013e3181e00955. PMID: 20502297.20502297
121 Department of Health and Human Services. Guidelines for the Prevention and Treatment of Opportunistic Infections in the HIV-Infected Adults and Adolescents. 2017. aidsinfo.nih.gov/contentfiles/lvguidelines/adult_oi.pdf Accessed December 12, 2017.