# Chapter 3 Results

A total of 1,232 new references from electronic database searches and manual searches of recently published studies were reviewed and 162 full-text papers were evaluated for inclusion. Twenty-nine new studies (in 36 articles)^44–79^ were included, and 33 studies (in 35 articles)^80–114^ were carried forward from the prior USPSTF report. Included studies and quality ratings are described in Appendix B.

## Key Question 1 What Are the Benefits of Screening for HIV Infection in Pregnant Women on Risk of Mother-to-Child Transmission of HIV Infection?

As in the prior USPSTF review, no RCT or observational study compared clinical outcomes (including risk of perinatal transmission) between pregnant women screened and not screened for HIV infection. As previously noted by the USPSTF, the number of infants with perinatally- acquired HIV transmission has markedly declined in the United States, likely due to a combination of screening during pregnancy and increased effectiveness and use of interventions to prevent transmission.

## Key Question 2 What Is the Yield of Repeat HIV Screening at Different Intervals in Pregnant Women, and How Does the Yield of Screening Vary in Different Risk Groups?

### Summary

No study compared the yield of one-time versus repeat screening or different frequencies of screening for HIV in pregnancy. Three studies conducted in the United States or the United Kingdom identified no cases of HIV infection among women who were rescreened for HIV during the third trimester of pregnancy; details regarding HIV risk status were not reported and not all women were rescreened.^115–117^

### Evidence

As in the prior USPSTF review, we identified no RCT or observational study on the yield of repeat prenatal HIV screening compared with one-time screening, or that compared the yield of different strategies for repeat screening (e.g., risk-based repeat screening vs. a routine repeat test). Three studies reported rescreening rates and positive screening results in 3,473 pregnant women, but did not meet inclusion criteria because they did not compare different screening strategies.^115–117^ One retrospective study of pregnant women (n=1,632) was conducted in Baltimore, Maryland, a state that mandates that pregnant women be screened for syphilis at presentation and again in the third trimester, providing an opportunity for HIV rescreening as well.^115^ HIV rescreening was performed in 28 percent of women, with no cases of HIV infection identified. A second study of 2,392 women in the United Kingdom with an initial negative prenatal HIV screening result found no cases of HIV infection in those retested during the third trimester.^116^ The third study retested 75 women in ambulatory obstetrics-gynecology clinics in Philadelphia with a rapid HIV test in the third trimester and identified no new cases of HIV infection.^117^ In these studies, details were unavailable regarding risk of HIV acquisition (e.g., HIV risk category or prevalence of HIV risk behaviors), and not all women were rescreened.

Repeat screening and the optimal timing of repeat testing during pregnancy depends on the incidence of new HIV infections following an initial negative prenatal screening result. One modeling study discussed in the 2005 USPSTF review estimated that repeat testing in the third trimester after a negative test in the first trimester would detect 5.3 new infections per 100,000 average-risk women tested and 192 infections per 100,000 high-risk women tested.^118^

## Key Question 3 What Are the Harms of Screening for HIV Infection in Pregnant Women?

As in the prior USPSTF review, no study compared psychological or other harms associated with screening for HIV infection in pregnant women or adverse clinical consequences of interventions given as a result of false-positive results.

## Key Question 4 What Is the Effectiveness of Currently Recommended ART Regimens for Reducing Mother-to-Child Transmission of HIV Infection?

### Summary

The 2012 USPSTF review included eight cohort studies^105–108,110–113^ that found full-course (starting in first trimester or early in second trimester) combination ART associated with rates of mother-to-child transmission of less than 1 to 2.4 percent, compared with 9 to 22 percent with no ART. Consistent with the prior USPSTF review, five new European, North American, and Israeli cohort studies published since 2012 found perinatal full-course triple ART associated with a risk of mother-to-child transmission that ranged from less than 1 to 2.8 percent.^51,60,61,63,74^

Two African RCTs included in the prior USPSTF review found combination ART started at 26 to 28 weeks of gestation associated with mother-to-child transmission rates of 1 to 5 percent.^86,87^ One new RCT conducted primarily in Africa found combination ART after 14 weeks of gestation associated with a lower rate of mother-to-child transmission than zidovudine monotherapy (0.5% vs. 1.8%).^44^ Across studies, including four African RCTs included in the prior USPSTF review,^80,81,84,88^ later initiation of ART during pregnancy or treatment with fewer than three antiretroviral medications was associated with increased risk of mother-to-child transmission.

### Evidence

The landmark Pediatric AIDS Clinical Trials Group protocol 076 study found that a three-phase maternal and infant zidovudine regimen starting at 14 to 34 weeks of gestation through 6 weeks postpartum decreased the risk of mother-to-child transmission in nonbreastfeeding women to 8 percent compared with 25 percent with placebo.^119^ The 2012 USPSTF review identified no completed trials on full-course combination ART during pregnancy in nonresource-poor, nonbreastfeeding settings. It included eight U.S. or European cohort studies that found full-course combination ART associated with rates of mother-to-child transmission ranging from less than 1 to 2.4 percent, compared with 9 to 22 percent with no ART. The prior USPSTF review also included two RCTs of breastfeeding women in Africa that found triple ART started at 26 to 28 weeks of gestation associated with mother-to-child transmission rates of 1 to 5 percent.^86,87^ Four other African trials in the prior USPSTF review found shorter courses of perinatal ART and regimens using fewer than three drugs associated with a lower risk of mother-to-child transmission of HIV infection compared with the expected transmission rate without therapy, but generally higher transmission rates than with full-course, three-drug regimens.^80,81,84,88^ These RCTs are likely to be most applicable in the United States to HIV-infected women identified later in pregnancy, who cannot receive full-course regimens.

We identified no new RCTs on full-course combination ART during pregnancy in nonresource-poor, nonbreastfeeding settings. Five fair-quality cohort studies conducted in high-income settings and published since the prior USPSTF review evaluated the effectiveness of combination ART during pregnancy on risk of mother-to-child transmission^51,60,61,63,74^ (Table 1, Appendix B Tables 2–5). Results were consistent with the findings from the prior review (Table 1). One large study (n=4,459) conducted an individual patient data meta-analysis of infants born between 1996 and 2010 in seven cohorts from six European countries who were at high risk of acquiring HIV infection (mother with viral load >50 copies/mL in the last 8 weeks of pregnancy, or mother only received intrapartum ART or received no antenatal or intrapartum ART).^51^ More than 25 percent of women did not receive ART during pregnancy. In women who received ART, the timing of initiation during pregnancy was not reported. Treatment with three or more antiretroviral drugs was associated with decreased risk of mother-to-child transmission compared to zero drugs (2.8% vs. 14.3%; adjusted odds ratio (OR), 0.36 [95% confidence interval (CI), 0.23 to 0.57]). One or two antiretroviral drugs were also associated with decreased risk of mother-to-child transmission compared with no ART (adjusted OR, 0.33 [95% CI, 0.19 to 0.55] and OR, 0.12 [95% CI, 0.04 to 0.40], respectively).

Table 1 U.S.-Relevant Studies of Mother-to-Child HIV Transmission While Using Antiretroviral Therapy

Author, Year | Setting | Intervention | Sample | Mother-to-child transmission rates by treatment group | Quality rating
Garcia-Tejedor et al, 2009^110^; Included in prior report | Spain; Maternity hospitals | ART; A: No treatment; B: Mono/dual therapy; C: ART | 489 mother-infant pairs analyzed; Rate of Caesarean delivery 51%; No infants breastfed; Followup NR; Timing of infant HIV testing NR | A: 18% (39/214); B: 8.6% (10/116); C: 0.6% (1/159); p<0.001 | Fair
Harris et al, 2007^111^; Enhanced Perinatal Surveillance Project; Included in prior report | U.S.; Population surveillance data from areas reporting ≥60 HIV-positive women giving birth per year | ART; A: No treatment; B: Prenatal, intrapartum, and neonatal ART* | 7,344 HIV-exposed infants with ART data; Rate of Caesarean delivery 53% Breastfeeding rate NR; Timing of infant HIV testing: Followup by health department every 6 months until HIV status determined; analyses of data over 3 years | A: 22% (59/265); OR referent; B: 2.4% (139/5,757); AOR, 0.09 (95% CI, 0.06 to 0.12) Prenatal ART regimen and infant infection status among 3 treatment arms:; ZDV: OR referent; ZDV + other drugs with PI: AOR, 0.4 (95% CI, 0.3 to 0.7); ZDV + other drugs with no PI: AOR, 0.5 (95% CI, 0.3 to 0.8); Other drugs with PI, no ZDV: AOR, 0.6 (95% CI, 0.2 to 1.4); Other drugs with no PI, no ZDV: AOR, 0.3 (95% CI, 0.1 to 1.5); n=5,602 due to exclusions | Fair
Townsend et al, 2008^113^; Included in prior report | Ireland, U.K.; Population surveillance data from NSHPC | Antepartum treatment; A: ART therapy; B: Dual therapy; C: Monotherapy; D: No therapy | 5,027 mother-infant pairs with ART data; Rate of Caesarean delivery 78%; 0.6% of infants breastfed; Followup NR; Analyses of data over 6-year study period; Timing of infant HIV testing: Overall NR; some reported having results within 72 hours of birth | A: 1.0% (40/4,120); B: 0.8% (1/126); C: 0.5% (3/638); D: 9.1% (13/143); A: AOR, 1.0; B: AOR, 1.7 (95% CI, 0.2 to 13); p=0.61; C: AOR, 0.6 (95% CI, 0.2 to 1.9); p=0.37; D: AOR, 3.2 (95% CI, 1.2 to 8.6); p=0.02; n=4,084 due to exclusions | Fair
Tariq et al, 2011^112^; Included in prior report | U.K., Ireland, Belgium, Denmark, Germany, Italy, the Netherlands, Poland, Spain, Sweden; Population surveillance data from the ECS and NSHPC | ART; A: ZDV-containing; B: ZDV-sparing | 7,573 mother-child pairs analyzed; Rate of Caesarean delivery 74%; Breastfeeding rate NR; Followup NR; Analyses of data over 9-year study period; Timing of infant HIV testing NR | 0.9% (56/6,130) (95% CI, 0.7 to 1.0) of infants were infected (infection status available for 80% [6,130/7,645] of infants at analysis); A: 0.9% (n=5,214); AOR, 1; B: 0.8% (n=897); AOR, 1.8 (95% CI, 0.8 to 4.3); p=0.18 | Fair
Chiappini et al, 2013^51^ | EPPICC; 7 cohorts from 6 countries; (Ukraine excluded due to heterogeneity) | A. ≥3 drugs; B. 2 drugs; C. 1 drug; D. No therapy; E. Unknown | 4,459 high-risk mother-infant pairs: no therapy (28%), only intrapartum prophylaxis (17%), and ART received but mother’s viral load remained detectable (55%); % screen-detected HIV during pregnancy NR; 45% no antenatal or only intrapartum ART; None breastfed (Ukraine cohort not included in transmission analysis); Timing of infant HIV testing NR | A. 2.8% (65/2,355); AOR, 0.36 (95% CI, 0.23 to 0.57); p<0.001; B. 1.2% (3/255); AOR, 0.12 (95% CI, 0.04 to 0.40); p<0.001; C. 3.1% (21/681); AOR, 0.33 (95% CI, 0.19 to 0.55); p<0.005; D. 14.3% (158/1,107); AOR, 1 reference | Fair
Lu et al, 2014^60^ | Canada, CPHSP | ART; A. Complete ART during pregnancy, ZDV during labor, infant received ZDV; B. Incomplete ART; C. No therapy | 645 mother-child pairs analyzed; Rate of Caesarean delivery 43%; Breastfeeding rate NR; Followup NR; Proportion of mothers born in HIV-endemic country 65%; Analysis of data over 12-year study period; % screen-detected HIV during pregnancy NR; 13% were considered late diagnoses (diagnosed at or after delivery); Timing of infant HIV testing NR | A. 1% (3/251); B. 2% (8/336); C. 67% (39/58) | Fair
Mandelbrot et al, 2015^61^ | France, national prospective multicenter French Perinatal Cohort (ANSR-EPF) | First ART; A. Triple NRTI; B. PI-based; C. NNRTI-based; D. Three classes; E. Other | 8,075 mother-child pairs analyzed; Rate of Caesarean delivery 57%; Breastfeeding rate 0%; Followup: Clinicians encouraged to followup from birth to ages 18 to 24 months; Analysis of data over 11-year study period; % screen-detected HIV during pregnancy NR; 57% initiated ART during pregnancy; 72% of mothers born in Africa; Timing of infant HIV testing NR | Transmission rates did not differ based on choice of initial ART (PI- vs. NNRTI-based); Transmission based on timing of ART initiation; Before conception, 0.2%; AOR, 1 (reference); 1st trimester, 0.4%; AOR, 2.9 (95% CI, 0.6 to 17.7); 2nd trimester, 0.9%; AOR, 6.0 (95% CI, 1.7 to 29.7); 3rd trimester, 2.2%; AOR, 7.8 (95% CI, 2.1 to 28.8) | Fair
Mor et al, 2017^63^ | Israel, all HIV- infected women who delivered in Israel (and were citizens) between 1988 and 2011 | A. HAART (392); B. No HAART (404) | 796 mother-infant pairs; 82% of mothers born in Ethiopia; 8 infants were breastfed; Timing of infant HIV testing NR | HAART vs. no HAART during pregnancy: AOR, 0.4 (95% CI, 0.1 to 0.8); Overall transmission: 3% (25/796); Transmission with HAART and vaginal delivery: 1.5%; Transmission with HAART and Caesarean delivery: 0.6% | Fair
Tookey et al, 2016^74^ | U.K. and Ireland, NSHPC | A. LPV/r + ZDV + 3TC; B. LPV/r + TDF-FTC; C. LPV/r + ABC + 3TC; D. LPV/r + other or missing NRTIs | 4,864 enrolled; 2,406 mother-infant pairs (2008–2012); 67% were given LPV/r + ZDV + 3TC; proportion of mothers born in sub-Saharan Africa 77%; some mother-infant pairs at high risk for HIV transmission likely also counted in the Chiappini study; Timing of infant HIV testing NR | By timing of LPV/r initiation:; Overall: 12/2,406 (0.5% [95% CI, 0.2% to 0.8%]); Before conception: 2/635 (0.3% [95% CI, 0.1% to 1.1%]); First trimester: 0/77 (0%); Second trimester: 5/1,397 (0.4% [95% CI, 0.2% to 0.8%]); Third trimester: 5/264 (1.9% [95% CI, 0.8% to 4.4%]) | Fair

Abbreviations: 3TC=lamivudine; ABC=abacavir; ANRS-EPF=French Agence Nationale de Recherche sur le SIDA-Enquête Périnatale Française; AOR=adjusted odds ratio; ART=antiretroviral therapy; CI=confidence interval; CPHSP=Canadian Perinatal HIV Surveillance Program; ECS=European Collaborative Study; EPPICC=European Pregnancy and Paediatric HIV Cohort Collaboration; FTC=emtricitabine; HAART=highly active antiretroviral therapy; LPV/r=lopinavir/ritonavir; NSHPC=National Study of HIV in Pregnancy and Childhood; NR=not reported; NNRTI=nonnucleoside reverse transcriptase inhibitor; NRTI=nucleoside reverse transcriptase inhibitor; PI=protease inhibitor; OR=odds ratio; TDF=tenofovir disoproxil fumarate; U.K.=United Kingdom; ZDV=zidovudine.

The French Perinatal Cohort is an ongoing observational study involving 95 percent of all HIV-infected women in 90 perinatal centers throughout France.^61^ Between 2000 and 2011, combination ART was initiated during pregnancy in 4,583 women (8% in the first trimester, 32% in the second trimester, 12% in the third trimester, and 47% before conception). Most regimens were protease inhibitor–based triple therapy (82.5%). There were 50 cases of mother-to-child HIV transmission (1.2% of births). The rate of mother-to-child HIV transmission was highest in women who initiated ART during the third trimester and in whom viral loads nearest delivery were detectable (4.4% [95% CI, 2.1 to 7.9]). There were no HIV transmissions among 2,651 women who started ART before pregnancy, continued ART throughout pregnancy, and had a viral load less than 50 copies/mL at the time of delivery.

Two smaller cohort studies, one from Canada^60^ and one from the United Kingdom and Ireland,^74^ reported rates of mother-to-child HIV transmission with combination ART of 1 and 0.5 percent, respectively. In the U.K./Ireland study, ritonavir-boosted lopinavir was associated with a higher transmission rate when ART was initiated during the third trimester (1.9%).^74^ Some mother-infant pairs in this study may have been included in the individual patient data meta-analysis discussed above. An Israeli cohort study^63^ found combination ART during pregnancy associated with decreased risk of vertical transmission (adjusted OR, 0.4 [95% CI, 0.1 to 0.8]); transmission rates were 1.5 percent with vaginal delivery and 0.6 percent with Caesarean delivery. Results were not stratified by timing of ART delivery.

One new fair-quality RCT (the Promoting Maternal and Infant Survival Everywhere [PROMISE] trial; n=3,490) was conducted in India and Africa among HIV-infected women with CD4 counts at or above 350 cells/mm^3^ who were at or beyond 14 weeks of gestation (Table 2).^44^ The rate of mother-to-child transmission at 1 week after birth was 1.8 percent with zidovudine alone; 0.5 percent with ART with zidovudine, lamivudine, and lopinavir-ritonavir; and 0.6 percent with ART with tenofovir, emtricitabine, and lopinavir/ritonavir (difference in rate for combined ART regimens vs. zidovudine alone, −1.3% [95% CI, −2.1 to −0.4]). The proportion of women who breastfed was 92 percent.

Table 2 African-Based Trials of Mother-to-Child HIV Transmission While Using Antiretroviral Therapy

Author, year | Setting | Prenatal intervention | Peripartum intervention | Postpartum intervention | Sample | Mother-to-child transmission rates by treatment group | Quality rating
Chi et al, 2008^82^ Other publication: Chi et al, 2007^84^; Included in prior report | Zambia | From 32 weeks: ZDV to all groups | A: TDF-FTC + NVP; B: NVP | All neonates: NVP dose in hospital + ZDV for 1 week | 355 mother-infant pairs analyzed 92% of infants breastfed in both groups | 6 weeks postpartum; A: 6%; B: 8%; p=0.4 | Fair
de Vincenzi et al, 2011^86^ Other publication: Kesho Bora Study Group, 2010^85^; Included in prior report | Burkina Faso, Kenya, South Africa | From 28 weeks:; A: ZDV + 3TC + LPV/r; B: ZDV | A: ZDV, 3TC, LPV/r; B: ZDV + sdNVP | A: Maternal ZDV, 3TC, LPV/r until cessation of breastfeeding (maximum 6.5 months postpartum); B: Maternal 3TC and ZDV for 1 week postpartum^*^; All neonates: ZDV for 1 week,^*^ NVP dose within 72 hours of birth, cotrimoxazole from age 6 weeks to 12 months unless not HIV infected after cessation of breastfeeding | 805 live-born infants; 77% of infants in group A and 78% in group B were ever breastfed | Age 12 months; A: 5.4% (21/333) (95% CI, 3.6 to 8.1); B: 9.5% (37/305) (95% CI, 7.0 to 13); RR reduction, 0.43; p=0.03 | Good
Gray et al, 2006^80^; Included in prior report | South Africa | From 34 weeks gestation:; A: D4T; B: ddI; C: D4T + ddI; D: ZDV | A: D4T; B: ddl; C: D4T + ddl; D: ZDV | Infants received same ART regimen as mother until age 6 weeks | 362 mother-infant pairs analyzed; No infants breastfed | 24 weeks postpartum; A: 12% (11/91) (95% CI, 6.2 to 21); B: 11% (10/94) (95% CI, 5.2 to 19); C: 4.6% (4/88) (95% CI, 1.3 to 11); D: 5.6% (5/89) (95% CI, 1.9 to 13); All groups: 8.3% (30/362) (95% CI, 5.7 to 12) | Fair
Shapiro et al, 2010^87^; Included in prior report | Botswana | Randomization groups^†^; From 26 weeks:; A: ABC + ZDV + 3TC; B: LPV/r + ZDV + 3TC Observational group^‡^; From 18 weeks:; C: NVP + ZDV + 3TC | A: ABC + ZDV + 3TC; B: LPV/r + ZDV + 3TC; C: NVP + ZDV + 3TC | A: ABC + ZDV + 3TC; B: LPV + RTV + ZDV + 3TC Above to continue until weaning or 6 months postpartum, whichever came first; C: NVP + ZDV + 3TC to continue indefinitely; All neonates: sdNVP at birth + ZDV from birth to 4 weeks | 709 live-born infants (including 156 in the observational group); 97% of live-born infants breastfed and 71% continued for >5 months | Age 6 months; A: 2.1% (6/283); B: 0.4% (1/270); Percentage point difference, 1.7 (95% CI, −2.0 to 7.1)^§^; All groups: 1.1% (8/709) (95% CI, 0.5 to 2.2) | Fair
Shapiro et al, 2006^81^; Included in prior report | Botswana | From 34 weeks: ZDV to all groups^║^ | A: sdNVP; B: Placebo | All neonates: NVP at birth and ZDV from birth to age 1 month^¶^ | 694 live first-born infants; 50% of infants in both groups were breastfed; Infant followup until age 1 month | Age 1 month; A: 4.3% ± 2.3 (SD, 2) (15/345); B: 3.7% ± 2.2 (SD, 2) (13/346); 95% CI for difference, −2.4% to 3.8% (met equivalence) | Fair
Thistle et al, 2007^88^; Included in prior report | Zimbabwe | None | A: ZDV/sdNVP; B: sdNVP | A: Infant ZDV for 72 hours after delivery and NVP dose within 72 hours of delivery; B: Infant NVP dose within 72 hours of delivery | Study terminated secondary to futility 609 infants with data; 89% of infants in group A and 91% in group B were breastfed at 6 weeks (1 infant in group A was breast and formula fed) | Age 6 weeks; A: 14% (45/312) HIV+, 7.4% (23/312) mortality, 22% (68/312) met primary outcome (death or HIV infection); B: 17% (49/297) HIV+, 7.1% (21/297) mortality, 24% (70/297) met primary outcome | Fair
Fowler et al, 2016^44^ | India, Malawi, South Africa, Tanzania, Uganda, Zambia, Zimbabwe | Randomized; From 14 weeks:; A. ZDV; B. ZDV + 3TC + LPVr; C. TDF + FTC + LPVr | A. sdNVP (ZDV-only group) | A. TDF + FTC (6–14 days; ZVD-only group); B. ZDV + 3TC + LPV/r; C. TDF + FTC + LPV/r | 3,202 live-born infants; mothers primarily black African; 92% breastfed; % screen-detected HIV during pregnancy NR | A. 1.8% (25/1,386); B. 0.5% (7/1,385); C. 0.6% (2/325); B + C vs. A: Difference in percentage point, −1.3 (95% CI, −2.1 to −0.4) | Fair

* Began after protocol change in December 2006 (enrollment commenced June 2005).

† Women with CD4 count >200 cells/mm^3^.

‡ Women with CD4 count <200 cells/mm^3^ or with AIDS-defining illness.

§ Study not powered for between-group comparisons of transmission rates.

║ ART was offered to women with CD4 counts <200 cells/mm^3^ or AIDS-defining illness at any point in study participation. If women started ART before delivery, they did not receive peripartum nevirapine or placebo.

¶ Infants confirmed to be HIV-infected were also given ART.

Abbreviations: 3TC=lamivudine; ABC=abacavir; ART=antiretroviral therapy; CI=confidence interval; D4T=stavudine; ddl=didanosine; FTC=emtricitabine; LPV/r=lopinavir/ritonavir; NVP=nevirapine; RR=relative risk; RTV=ritonavir; sdNVP=single-dose nevirapine; SD=standard deviation; TDF=tenofovir disoproxil fumarate; ZDV=zidovudine.

## Key Question 5 What Are the Harms of Currently Recommended ART Regimens Given During Pregnancy to the Mother and Infant?

### Summary

New evidence (two trials^44,45^ and 21 cohort studies in 30 publications)^46–50,52–59,61,62,64–73,75–79^ on infant and maternal harms associated with perinatal exposure to ART was generally consistent with the evidence included in the 2012 USPSTF review. One fair-quality RCT conducted in Africa and seven cohort studies published since the last review found antenatal ART associated with increased risk of preterm birth compared with no treatment or zidovudine monotherapy. The trial and 12 cohort studies found mixed results for the association between ART given during pregnancy and low birth weight, small size for gestational age, and stillbirth. Five cohort studies, including the Antiretroviral Pregnancy Registry,^47^ found that most antiretroviral drugs recommended in the United States as initial therapy for HIV in pregnancy were not associated with increased risk of birth defects. The trial reported increased risk of neonatal death with ART with tenofovir, emtricitabine, and lopinavir/ritonavir (4.4%) compared with ART with zidovudine, lamivudine, and lopinavir/ritonavir (0.6%), but there was no difference between the tenofovir combination ART regimen and zidovudine monotherapy in risk of early infant death (4.4% vs. 3.2%,;p=0.43). Some methodological limitations were present in this trial.

### Evidence

#### Birth Outcomes

The 2012 USPSTF review^1^ included one RCT^83^ and three prospective cohort studies^92,94,99^ published after 2005 that found maternal exposure to combination ART with a protease inhibitor associated with increased risk of preterm delivery (<37 weeks) compared with nonnucleoside reverse transcriptase-based ART (OR, 2.0 [95% CI, 1.3 to 3.3]),^83^ combination ART without a protease inhibitor (adjusted OR, 1.8 [95 % CI, 1.1 to 3.0]),^92^ dual therapy (adjusted OR, 1.2 [95% CI, 1.0 to 1.4]),^99^ or monotherapy (adjusted OR, 3.4 [95% CI, 1.1 to 10])^94^ (Table 3). A fourth cohort study^100^ found combination therapy associated with increased risk of preterm delivery (adjusted OR, 1.4 [95% CI, 1.1 to 1.8]) compared with monotherapy or dual therapy, with no difference in risk according to whether the antiretroviral regimen included a protease inhibitor or not. There was no clear association between maternal exposure to ART and increased risk of other adverse birth outcomes (e.g., low birth weight, small size for gestational age).

Table 3 Studies Examining the Association Between Birth Outcomes and HIV Antiretroviral Therapy

Harm category | Study, year Country Study name | ART regimen (n; %) | Birth outcome Definition | Birth outcome Distribution | Magnitude of risk: adjusted OR (95% CI); p-value
Preterm Delivery | Cotter et al, 2006^92^; U.S.; University of Miami study; Included in prior report | A. None (n=338; 25%); B. Monotherapy (n=492; 37%); C. Combination therapy with PI (n=134; 10%); D. Combination therapy without PI (n=373; 28%); Total N=1,337 | Preterm delivery; <37 weeks; Very preterm <32 weeks | Median at delivery 39 weeks | Combination with vs. without PI:; <37 weeks: 1.8 (1.1 to 3.0); p=0.03; Combination + PI:; <37 weeks: 36.6% of women; p<0.05; <32 weeks: 2.2% of women; p-value NS
Preterm Delivery | Grosch-Warner et al, 2008^94^; Germany, Austria; Included in prior report | A. Monotherapy (n=76; 42%); B. Dual therapy (n=32; 17%); C. ART without PI (n=54; 30%); D. ART with PI (n=21; 11%); Total N=183 | Preterm delivery <36 weeks | <36 weeks 34%^*^ (crude rate) | A. 1 reference; C. ART (-) PI: 0.89 (0.38 to 2.12); p=0.8; D. ART (+) PI: 3.40 (1.13 to 10.2); p=0.03
Preterm Delivery | Powis et al, 2011^83^; Botswana; Included in prior report | A. PI group (LPV/r with ZDV/3TC) (n=275; 49%); B. NRTI group, TZV (n=285; 51%); Total N=560 | Preterm delivery <37 weeks | <37 weeks 11.8%^*^; Triple NRTI; 21.4% PI- based; <32 weeks 2.6% (n=12); 8/12 associated with ART + PI; 4/12 triple NRTI | A. ART (+) PI: 2.03 (1.26 to 3.27); p=0.004; B. ART (-) PI (NRTI-based): 1.0
Preterm Delivery | Schulte et al, 2007^99^ U.S.; Pediatric Spectrum of HIV Disease cohort; Included in prior report | A. None (n=2,565; 29%); B. Monotherapy (n=2,621; 30%); C. Dual therapy (n=1,044; 12%); D. Triple therapy: ART, non-PI (n=1,781; 20%); E. Triple therapy: ART, PI (n=782; 9%); Total N=8,793 | Preterm delivery <37 weeks | Mean 37 weeks (range, 26 to 42) | C. 1 reference; E. 1.21 (1.04 to 1.48); p-value NR
Preterm Delivery | Townsend et al, 2007^100^; U.K., Ireland; Included in prior report | A. ART (n=3,384; 69%); B. Mono/dual therapy (n=1,061; 21%); C. Untreated; not included in analyses (n=494; 10%); Total N=4,939 | Preterm delivery <37 weeks | <37 weeks 14.1%^*^; <35 weeks 7.8%; <32 weeks 1.4% | A. <37 weeks: 1.39 (1.05 to1.83); p=0.02; A. <35 weeks: 2.02 (1.35 to 3.04); p=0.001; A. <32 weeks: 2.63 (1.3 to 5.33); p=0.007; B. 1 reference all comparisons
Preterm Delivery | Chagomerana et al, 2017^49^; Malawi | Started ART before 27 weeks or not at all; A. ART (2,909; 95%); B. No ART (165; 5%); Total N=3,074 | Preterm delivery 27 to 37 weeks | 24% | Delivery after 27 weeks:; A. 1 reference; B. aRR, 1.14 (0.84 to 1.55)
Preterm Delivery | Chen et al, 2012^50^; Botswana; Approximately 87% received ZDV/3TC/NVP | A. Initiated HAART during pregnancy (ZVD/3TC/NVP or ZVD/3TC/LVP/r) (1,101; 12%); B. Initiated ZVD only during pregnancy (4,625; 51%); C. No ART (1,234; 13%); D. HAART continued from before pregnancy (2,189; 24%); Total N=9,149 | Preterm delivery <37 weeks | 24%^*^ | Initiated HAART vs. initiated ZDV: 1.4 (1.2 to 1.8); Continued HAART vs. all others: 1.2 (1.1 to 1.4)
Preterm Delivery | Duryea et al, 2015^52^; U.S.; University of Texas study | A. ART with PI (597; 59%); B. ART without PI (230; 23%); C. No ART (177; 18%); Total N=1,004 | Preterm delivery <37 weeks | 13% to 21% depending on ART regimen | A. 1 reference; B. 0.9 (0.5 to 1.5); C. 1.0 (0.5 to 2.0)
Preterm Delivery | Kakkar et al, 2015^54^; Canada | A. NRTI/NNRTI (159; 30%); B. Boosted PI (119; 23%); C. Unboosted PI (195; 37%); D. No treatment (52; 10%); Total N=525 | Preterm delivery <37 weeks | 14%^*^ | A. 0.67 (0.27 to 1.63); p=0.37; B. 2.17 (1.05 to 4.51); p=0.038; C. 1 reference; D. 1.50 (0.33 to 6.78); p=0.60
Preterm Delivery | Kreitchmann et al, 2014^56^; Latin America Caribbean | At least 28 days in 3rd trimester:; A. HAART + PI (888; 59%); B. HAART no PI (410; 27%); C. Non-HAART (134; 9%); D. No ARV (80; 5%); Total N=1,512 | Preterm delivery <37 weeks | 21%^*^ | Receiving vs. not receiving ART at conception: 1.53 (1.11 to 2.09)
Preterm Delivery | Li et al, 2016^57^; Tanzania | A. Initiated ZDV during pregnancy (1,768; 53%); B. Initiated HAART during pregnancy (512; 15%); C. Continued HAART from before pregnancy (582; 18%); D. No ART (452; 14%); Total N=3,314 | Preterm delivery <37 weeks; Very preterm <34 weeks | No infants had HIV; <37 weeks 29%^*^; <34 weeks 10%^*^ | HAART vs. ZDV started during pregnancy:; <37 weeks: 0.85 (0.70 to 1.02); p=0.14; <34 weeks: 0.87 (0.60 to 1.25); p=0.45
Preterm Delivery | Lopez et al, 2012^59^; Spain | A. HAART entire pregnancy (226; 44%); B. HAART 2nd half of pregnancy only (72; 14%); C. PI during pregnancy (178; 34%); D. No HAART (221; 43%); Total N=697 | Preterm delivery <37 weeks | 20%^*^ | Spontaneous preterm birth:; A. 0.55 (0.20 to 1.51); B. 0.55 (0.18 to 1.68); C. 1.95 (0.87 to 4.38); D. HIV-uninfected women; Iatrogenic preterm birth:; A. 3.42 (0.80 to 14.63); B. 6.16 (1.42 to 26.8); C. 0.44 (0.18 to 1.10); D. HIV-uninfected women
Preterm Delivery | Moodley et al, 2016^62^; South Africa | A. No ART (148; 4%); B. AZT + NVP (974; 26%); C. D4T + 3TC + NVP (907; 25%); D. EFV + TDF-FTC (1,666; 45%); Total N=3,695 | Preterm delivery <37 weeks | 22.3% | A. 1 reference; B. 0.20 (0.08 to 0.51); p=0.001; C. 0.21 (0.08 to 0.55); p=0.001; D. 0.31 (0.11 to 0.90); p=0.03
Preterm Delivery | Pintye et al, 2017^65^; Kenya and Uganda | A. TDF-containing ART (208; 49%); B. Non-TDF–containing ART (214; 51%); Total N=422 | Preterm delivery <37 weeks | 8% | A vs. B: Adjusted prevalence rate ratio 0.37 (0.15 to 0.89); p=0.03
Preterm Delivery | Ramokolo et al, 2017^66^; South Africa | A. Postconception ART (780; 30%); B. ZDV (873; 34%); C. No ART (330; 13%); D. Preconception ART (616; 24%); Total N=2,599 | Preterm delivery <37 weeks | 12.5% | A. 1 reference; B. 1.4 (0.9 to 2.0); p=0.11; C. 1.9 (1.1 to 3.1); p=0.01; D. 1.7 (1.1 to 2.5); p=0.02
Preterm Delivery | Rough et al, 2018^67^; U.S.; PHACS and IMPAACT | A. TDF-FTC + LPV/r (128; 8%); B. ZDV + 3TC + LPV/r (954; 59%); C. TDF-FTC + ATV/r (539; 33%); Total N=1,621 | Preterm delivery <37 weeks; Very preterm delivery <34 weeks | 18% Preterm delivery; 5% Very preterm delivery | Preterm delivery, adjusted OR:; A vs. B: 0.90 (0.60 to 1.33); C vs. B: 0.69 (0.51 to 0.94); A vs. C: 1.14 (0.75 to 1.72); Very preterm delivery, unadjusted OR:; A vs. B: 0.85 (0.34 to 2.13); C vs. B: 1.04 (0.60 to 1.83); A vs. C: 0.82 (0.31 to 2.17)
Preterm Delivery | Short et al, 2013^68^; U.K. | A. ZDV (65; 20%); B. Dual NRTI (7; 2%); C. Triple NRTI (5; 2%); D. Short-term combination ART (59; 18%); E. Preconception combination ART (131; 40%); F. New continuous combination ART (56; 17%); G. No therapy (8; 2%); Total N=331 | Preterm delivery <37 weeks | 13%^*^ | Short-term combination ART vs. ZVD: 5.00 (1.49 to 16.79)
Preterm Delivery | Sibiude et all, 2012^72^; France | A. HAART (6,738; 59%); HAART with boosted PI (1,066; 9%); HAART without nonboosted PI (187; 2%); B. Dual therapy (1,664; 15%); C. Monotherapy (2,975; 26%); Total N=11,377 | Preterm delivery <37 weeks | 14%^*^ | A. 1.69 (1.38 to 2.07); Boosted PI, 2.03 (1.06 to 3.89); p=0.03 vs. nonboosted PI; B. 1.24 (0.96 to 1.60); C. 1 reference
Preterm Delivery | Snijdewind et al, 2018^73^; The Netherlands | A. PI-based (928; 67%); B. NNRTI-based (438; 31%); C. Both or NRTI (12; 1%); Total N=1,378 | Preterm delivery <37 weeks | 15% | Unadjusted OR:; A. 1 (reference); B. 1.30 (0.95 to 1.77); p=0.11; C. 1.15 (0.41 to 3.19); p=0.78
Preterm Delivery | Watts et al, 2013^75^; U.S.; PHACS/SMARTT | A. Combination, with PI (1,319; 74%); B. Combination, with NNRTI, no PI (160; 9%); C. Combination, with ≥3 NRTIs (193; 10%); Total N=1,672 | Preterm delivery <37 weeks | Any preterm birth: <37 weeks 19%^*^; Spontaneous preterm birth: <37 weeks 10%^*^ | Any preterm birth:; A. 1.49 (0.83 to 2.67); p=0.18; B. 1.28 (0.62 to 2.66); p=0.50; C. 1.04 (0.50 to 2.14); p=0.93); Spontaneous preterm birth:; A. 1.41 (0.66 to 2.99); p=0.38; B. 1.53 (0.62 to 3.81); p=0.36; C. 0.88 (0.34 to 2.29); p=0.80); (all vs. monotherapy or dual therapy)
Preterm Delivery | Zash et al, 2016^79^; Botswana | All CD4 counts:; A. TDF-FTC/EFV (1,054; 33%); B. Other ART (2,172; 64%); Total N=3,226; CD4 counts >350 cells/mm^3^; A. TDF-FTC/EFV (335; 31%); B. ZDF (752; 69%); Total N=1,087 | Preterm delivery <37 weeks | 27% | A vs. B (all CD4 counts): 0.7 (0.5 to 1.1); A vs. B (CD4 count >350 cells/mm^3^): 1.1 (0.6 to 2.1)
Preterm Delivery | Zash et al, 2017^78^; Botswana | A. TDF-FTC/EFV (2,472; 49%); B. TDF-FTC/NVP (760; 15%); C. TDF-FTC/LPV/r (231; 5%); D. ZDV/3TC/NVP (1,365; 27%); E. ZDV/3TC/LPV/r (167; 3%); Total N=4,995 | Preterm delivery <37 weeks; Very preterm delivery <32 weeks | 22% Preterm delivery; 5% Very preterm delivery | aRR:; A. 1 reference; B. 0.88 (0.75 to 1.05) preterm delivery; B. 1.23 (0.84 to 1.80) very preterm delivery; C. 1.12 (0.88 to 1.43) preterm delivery; C. 1.36 (0.76 to 2.45) very preterm delivery; D. 1.14 (1.01 to 1.29) preterm delivery; D. 1.44 (1.07 to 1.95) very preterm delivery; E. 1.36 (1.06 to 1.75) preterm delivery; E. 2.21 (1.29 to 3.79) very preterm delivery
Low Birth Weight | Kreitchmann et al, 2014^56^; Latin America Caribbean | At least 28 days in 3rd trimester:; A. HAART + PI (888; 59%); B. HAART no PI (410; 27%); C. Non-HAART (134; 9%); D. No ARV (80; 5%); Total N=1,512 | Low birth weight <2,500 g | 16%^*^ | HAART with PI vs. no ART: 0.59 (0.28 to 1.26); HAART with no PI vs. no ART: 0.33 (0.14 to 0.74); Non-HAART vs. no ART: 0.40 (0.15 to 1.05)
Low Birth Weight | Moodley et al, 2016^62^; South Africa | A. No ART (148; 4%); B. AZT + NVP (974; 26%); C. D4T +3TC + NVP (907; 25%); D. EFV + TDF-FTC (1,666; 45%); Total N=3,695 | Low birth weight <2,500 g | 13.5% | A. 1 reference; B. 0.06 (0.02 to 0.18); p<0.001; C. 0.09 (0.03 to 0.24); p<0.001; D. 0.12 (0.04 to 0.37); p<0.001
Low Birth Weight | Ramokolo et al, 2017^66^; South Africa | A. Postconception ART (780; 30%); B. ZDV (873; 34%); C. No ART (330; 13%); D. Preconception ART (616; 24%); Total N=2,599 | Low birth weight <2,500 g | 10.7% | A. 1 reference; B. 0.8 (0.6 to 1.1); p=0.14; C. 1.1 (0.8 to 1.6); p=0.47; D. 0.9 (0.6 to 1.3); p=0.54
Low Birth Weight | Rough et al, 2018^67^; U.S.; PHACS and IMPAACT | A. TDF-FTC + LPV/r (128; 8%); B. ZDV + 3TC + LPV/r (954; 59%); C. TDF-FTC + ATV/r (539; 33%); Total N=1,621 | Low birth weight <2,500 g; Very low birth weight <1,500 g | 18% Low birth weight; 2% Very low birth weight | Low birth weight, adjusted OR:; A vs. B: 1.13 (0.78 to 1.64); C vs. B: 0.80 (0.60 to 1.09); A vs. C: 1.45 (0.96 to 2.17); Very low birth weight, unadjusted OR:; A vs. B: 0.41 (0.06 to 3.06); C vs. B: 0.89 (0.40 to 2.00); A vs. C: 0.49 (0.07 to 3.57)
Low Birth Weight | Siberry et al, 2012^69^; U.S.; PHACS/SMARTT | A. TDF-containing ART (449; 22%); B. Non-TDF–containing ART (1,580; 78%); Total N=2,029 | Low birth weight <2,500 g | 19% | A vs. B: 0.73 (0.48 to 1.11); p=0.14
Low Birth Weight | Snijdewind et al, 2018^73^; The Netherlands | A. PI-based (928; 67%); B. NNRTI-based (438; 31%); C. Both or NRTI (12; 1%); Total N=1,378 | Low birth weight <2,500 g | 16% | Unadjusted OR:; A. 1 (reference); B. 1.19 (0.88 to 3.97); p=0.26; C. 1.47 (0.54 to 3.97); p=0.45
Small Size for Gestational Age | Aaron et al, 2012^46^; U.S.; Drexel University study | A. NRTI + NNRTI (39; 21%); B. NRTI + PI (117; 64%); C. NRTI alone (27; 15%); Total N=183 | SGA; <10th percentile of birth weight by gestational age (based on infant sex and mother’s parity) | <10th percentile 31%^*^; <3rd percentile 13%^*^ | <10th percentile:; A. 0.28 (0.10 to 0.75); p<0.05 vs. others; B. 1.68 (0.79 to 3.55); p>0.05 vs. others; <3rd percentile:; A. 0.16 (0.03 to 0.91); p<0.05 vs. others; B. 2.73 (0.83 to 9.00); p>0.05 vs. others
Small Size for Gestational Age | Chen et al, 2012^50^; Botswana | A. Initiated HAART during pregnancy (ZVD/3TC/NVP or ZVD/3TC/LVP/r) (1,101; 12%); B. Initiated ZVD only during pregnancy (4,625; 51%); C. No ART (1,234; 13%); D. HAART continued from before pregnancy (2,189; 24%); Total N=9,149 | SGA; <10th percentile | 13.5%^*^ | Initiated HAART vs. initiated ZDV: 1.5 (1.2 to 1.9); Continued HAART vs. initiated HAART: 1.3 (1.0 to 1.5); Continued HAART vs. all others: 1.8 (1.6 to 2.1)
Small Size for Gestational Age | Duryea et al, 2015^52^; U.S.; University of Texas study | A. ART with PI (597; 59%); B. ART without PI (230; 23%); C. No ART (177; 18%); Total N=1,004 | SGA; <10th percentile of birth weight by gestational age | 4% to 10% depending on ART regimen | A. 1 reference; B. 1.3 (0.8 to 1.9); C. 1.1 (0.6 to 2.0)
Small Size for Gestational Age | Li et al, 2016^57^; Tanzania | A. Initiated ZDV during pregnancy (1,768; 53%); B. Initiated HAART during pregnancy (512; 15%); C. Continued HAART from before pregnancy (582; 18%); D. No ART (452; 14%); Total N=3,314 | SGA; <10th percentile of birth weight by gestational age; <3rd percentile for severe SGA | 3rd–10th percentile 9%^*^; <3rd percentile 11%^*^ | HAART vs. ZDV started during pregnancy:; 3rd–10th percentile: 1.09 (0.88 to 1.35); p=0.41; <3rd percentile: 1.47 (1.09 to 1.98); p=0.01
Small Size for Gestational Age | Moodley et al, 2016^62^; South Africa | A. No ART (148; 4%); B. AZT + NVP (974; 26%); C. D4T + 3TC + NVP (907; 25%); D. EFV + TDF-FTC (1,666; 45%); Total N=3,695 | SGA | 8.2% | A. 1 reference; B. 0.37 (0.10 to 1.45); p=0.15; C. 0.29 (0.08 to 1.07); p=0.06; D. 0.25 (0.07 to 0.87); p=0.03
Small Size for Gestational Age | Ramokolo et al, 2017^66^; South Africa | A. Postconception ART (780; 30%); B. ZDV (873; 34%); C. No ART (330; 13%); D. Preconception ART (616; 24%); Total N=2,599 | SGA; <10th percentile of birth weight by gestational age | 14.9% | A. 1 reference; B. 0.7 (0.5 to 1.0); p=0.05; C. 0.7 (0.4 to 1.1); p=0.08; D. 0.9 (0.6 to 1.3); p=0.52
Small Size for Gestational Age | Siberry et al, 2012^69^; U.S.; PHACS/SMARTT | A. TDF-containing ART (449; 22%); B. Non-TDF–containing ART (1,580; 78%); Total N=2,029 | SGA | 8.6% | A vs. B: 0.96 (0.60 to 1.52); p=0.85
Small Size for Gestational Age | Snijdewind et al, 2018^73^; The Netherlands | A. PI-based (928; 67%); B. NNRTI-based (438; 31%); C. Both or NRTI (12; 1%); Total N=1,378 | SGA; <10th percentile of birth weight by gestational age | 24% | Unadjusted OR:; A. 1 (reference); B. 1.04 (0.80 to 1.16); p=0.76; C. 2.51 (1.16 to 5.53); p=0.02; Adjusted OR:; A. 1 (reference); B. 0.95 (0.71 to 1.27); p=0.73; C. 2.11 (0.98 to 4.57); p=0.06
Small Size for Gestational Age | Watts et al, 2013^75^; U.S.; PHACS/SMARTT | A. Combination, with PI (1,319; 74%); B. Combination, with NNRTI, no PI (160; 9%); C. Combination, with ≥3 NRTIs (193; 10%); Total N=1,672 | SGA; <10th percentile of birth weight by gestational age | 7%^*^ | All vs. no ARV in 1st trimester:; A. 0.79 (0.49 to 1.26); p=0.32; B. 1.17 (0.54 to 2.54); p=0.70; C. 0.99 (0.34 to 2.86); p=0.99; All vs. monotherapy or dual therapy:; A. 1.79 (0.64 to 5.04); p=0.27; B. 1.77 (0.53 to 5.99); p=0.36; C. 1.45 (0.43 to 4.89); p=0.55
Small Size for Gestational Age | Zash et al, 2016^79^; Botswana | All CD4 counts:; A. TDF-FTC/EFV (1,054; 33%); B. Other ART (2,172; 64%); Total N=3,226; CD4 count >350 cells/mm^3^; A. TDF-FTC/EFV (335; 31%); B. ZDF (752; 69%); Total N=1,087 | SGA; <10th percentile of birth weight by gestational age; (Botswana norms) | 19% | A vs. B (all CD4 counts): 0.4 (0.3 to 0.6); A vs. B (CD4 >350 cells/mm^3^): 0.6 (0.4 to 1.0)
Small Size for Gestational Age | Zash et al, 2017^78^; Botswana | A. TDF-FTC/EFV (2,472; 49%); B. TDF-FTC/NVP (760; 15%); C. TD-/FTC/LPV/r (231; 5%); D. ZDV/3TC/NVP (1,365; 27%); E. ZDV/3TC/LPV/r (167; 3%); Total N=4,995 | SGA; <10th percentile of birth weight by gestational age; VSGA; <3rd percentile | 22% SGA; 10% VSGA | aRR:; A. 1 reference; B. 1.44 (1.24 to 1.68) SGA; B. 1.52 (1.18 to 1.94) VSGA; C. 1.56 (1.25 to 1.97) SGA; C. 1.81 (1.26 to 2.59) VSGA; D. 1.66 (1.46 to 1.87) SGA; D. 1.76 (1.44 to 2.16) VSGA; E. 1.13 (0.82 to 1.56) SGA; E. 1.70 (1.10 to 2.62) VSGA
Stillbirth | Chen et al, 2012^50^; Botswana | A. Initiated HAART during pregnancy (ZDV/3TC/NVP or ZDV/3TC/LVPr (1,101; 12%); B. Initiated ZDV only during pregnancy (4,625; 51%); C. No ART (1,234; 13%); D. HAART continued from before pregnancy (2,189; 24%); Total N=9,149 | Stillbirth (fetal death with APGAR of 0) | 3.3%^*^ | HAART initiation vs. ZDV initiation: 2.5 (1.6 to 3.9); Continued HAART vs. all others: 1.5 (1.2 to 1.8)
Stillbirth | Kreitchmann et al, 2014^56^; Latin America Caribbean | At least 28 days in 3rd trimester:; A. HAART with PI (888; 59%); B. HAART with no PI (410; 27%); C. Non-HAART (134; 9%); D. No ARV (80; 5%); Total N=1,512 | Stillbirth; Birth at 20 weeks of gestation or later with no signs of life | 2%^*^ | HAART with PI vs. no ART: 0.14 (0.05 to 0.34); HAART with no PI vs. no ART: 0.11 (0.04 to 0.34)
Stillbirth | Moodley et al, 2016^62^; South Africa | A. No ART (148; 4%); B. AZT + NVP (974; 26%); C. D4T + 3TC + NVP (907; 25%); D. EFV + TDF-FTC (1,666; 45%); Total N=3,695 | Stillbirth | 3.1% | A. 1 reference; B. 0.08 (0.04 to 0.16); p<0.001; C. 0.20 (0.11 to 0.38); p<0.001; D. 0.18 (0.10 to 0.34); p<0.001
Stillbirth | Rough et al, 2018^67^; U.S.; PHACS and IMPAACT | A. TDF-FTC + LPV/r (128; 8%); B. ZDV + 3TC + LPV/r (954; 59%); C. TDF-FTC + ATV/r (539; 33%); Total N=1,621 | Fetal loss was undefined, included stillbirth (likely also included spontaneous abortion and fetal demise) | 0.6% | Unadjusted OR (our analysis) for initial drug regimen:; A vs. B: 2.51 (0.50 to 13); A vs. C: 4.26 (0.60 to 31); B vs. C: 1.70 (0.34 to 8.45)
Stillbirth | Zash et al, 2016^79^; Botswana | All CD4 counts:; A. TDF-FTC/EFV (1,054; 33%); B. Other ART (2,172; 64%); Total N=3,226; CD4 counts >350 cells/mm^3^; A. TDF-FTC/EFV (335; 31%); B. ZDF (752; 69%); Total N=1,087 | Stillbirth | 3% | A vs. B (all CD4 counts): 0.6 (0.3 to 1.3); A vs. B (CD4 >350 cells/mm^3^): 0.9 (0.4 to 2.1)
Stillbirth | Zash et al, 2017^78^; Botswana | A. TDF-FTC/EFV (2,472; 49%); B. TDF-FTC/NVP (760; 15%); C. TDF-FTC/LPV/r (231; 5%); D. ZDV/3TC/NVP (1,365; 27%); E. ZDV/3TC/LPV/r (167; 3%); Total N=4,995 | Stillbirth | 3.6% | aRR:; A. 1 reference; B. 1.15 (0.70 to 1.89); C. 1.81 (0.94 to 3.50); D. 2.31 (1.64 to 3.26); E. 1.53 (0.67 to 3.49)
Neonatal Death | Pintye et al, 2017^65^; Kenya and Uganda | A. TDF-containing ART (208; 49%); B. Non-TDF–containing ART (214; 51%); Total N=422 | Neonatal death within 3 days of live birth | 2% | A vs. B: Adjusted prevalence rate ratio, 0.55 (0.17 to 1.77); p=0.30
Neonatal Death | Rough et al, 2018^67^; U.S.; PHACS and IMPAACT | A. TDF-FTC + LPV/r (128; 8%); B. ZDV + 3TC + LPV/r (954; 59%); C. TDF-FTC + ATV/r (539; 33%); Total N=1,621 | Neonatal death within 14 days of live birth | 0.1% (2 events) | Unadjusted OR (our analysis) for initial drug regimen:; A vs. B: 2.47 (0.10 to 61); A vs. C: 1.40 (0.06 to 34); B vs. C: 0.56 (0.04 to 9.04)
Neonatal Death | Zash et al, 2017^78^; Botswana | A. TDF-FTC/EFV (2,472; 49%); B. TDF-FTC/NVP (760; 15%); C. TDF-FTC/LPV/r (231; 5%); D. ZDV/3TC/NVP (1,365; 27%); E. ZDV/3TC/LPV/r (167; 3%); Total N=4,995 | Neonatal death at less than 28 days | 1.6% | aRR:; A. 1 reference; B. 1.57 (0.81 to 3.06); C. 1.60 (0.56 to 4.56); D. 1.94 (1.13 to 3.33); E. 4.01 (1.78 to 9.11)
Congenital Abnormalities | Antiretroviral Pregnancy Registry Interim Report (1989 through 2018)^47^; Multinational (69 countries), 75% U.S. and its territories | Preferred initial treatment drugs in U.S.:; A. ABC (1,131; 12%); B. 3TC (5,008; 54%); C. TDF (3,535; 38%); D. FTC (2,785; 30%); E. ATV (1,279; 14%); F. RTV (3,155; 34%); G. DRV (456; 5%); H. RAL (291; 3%); Alternative initial treatment drugs in U.S.:; I. ZDV (4,178; 45%); J. LPV (1,418; 15%); K. EFV (1,023; 11%); L. RPV (297; 3%); Total N=9,336 | Birth defects Centers for Disease Control and Prevention guidelines | 2.73% First trimester exposure; 2.77% Any trimester exposure | 1st-trimester exposed vs. unexposed, unadjusted OR (our analysis):; A. 1.04 (0.72 to 1.52); B. 1.26 (0.98 to 1.63); C. 0.77 (0.59 to 1.01); D. 0.85 (0.64 to 1.13); E. 0.77 (0.52 to 1.15); F. 0.74 (0.56 to 0.97); G. 0.88 (0.48 to 1.61); H. 1.14 (0.58 to 2.24); I. 1.38 (1.08 to 1.77); J. 0.74 (0.50 to 1.09); K. 0.84 (0.55 to 1.29); L. 0.36 (0.11 to 1.12)
Congenital Abnormalities | Floridia et al, 2013^53^; Italy | Preferred initial treatment drugs in U.S.:; A. ABC (88; 7%); B. 3TC (544; 43%); C. TDF (173; 14%); D. FTC (87; 7%); E. ATV (63; 5%); F. RTV (231; 18%); Alternative initial treatment drugs in U.S.:; G. ZDV (358; 28%); H. LPV (140; 11%); I. EFV (80; 6%); J. Any NRTI (716; 56%); K. Any PI (353; 28%); L. Any NNRTI (273; 21%); Total N=1,257 | Birth defects Not defined | 3.4%^*^ | Not clear if ORs are adjusted; 1st-trimester exposure vs. unexposed:; ABC, 1.01 (0.29 to 3.47); p=0.99; 3TC, 1.14 (0.61 to 2.15); p=0.67; TD,F 0.85 (0.31 to 2.31); p=0.75; FTC, 0.67 (0.15 to 2.93); p=0.60; ATV, 0.93 (0.21 to 4.11); p=0.93; RTV, 1.02 (0.44 to 2.37); p=0.96; ZDV, 0.65 (0.28 to 1.51); p=0.32; LPV, 1.28 (0.50 to 3.26); p=0.61; EFV, 0.73 (0.17 to 3.20); p=0.68; Any NRTI, 0.95 (0.51 to 1.76); p=0.86; Any PI, 0.92 (0.43 to 1.95); p=0.82; Any NNRTI, 1.20 (0.56 to 2.55); p=0.64
Congenital Abnormalities | Knapp et al, 2012^55^; U.S.; (IMPAACT); These patients may also be represented in the Antiretroviral Pregnancy Registry | Preferred initial treatment drugs in U.S.:; A. ABC (312; 28%); B. 3TC (979; 88%); C. TDF (235; 21%); D. FTC (121; 11%); E. ATV (104; 9%); F. RTV (131; 12%); Alternative initial treatment drugs in U.S.:; G. ZDV (924; 83%); H. LPVr (306; 28%); I. EFV (56; 5%); J. Any NRTI (1,097; 99%); K. Any PI (804; 72%); L. Any NNRTI (205; 18%); Total N=1,112 | Birth defects MACDP classification | 5%^*^ | All vs. unexposed:; ABC 1st T, 1.45 (0.68 to 3.10); ABC 2-3 T, 1.25 (0.62 to 2.51); 3TC 1st T, 1.68 (0.61 to 4.58); 3TC 2-3 T, 1.52 (0.56 to 4.08); TDF 1st T, 1.69 (0.83 to 3.44); TDF 2-3 T, 1.01 (0.38 to 2.65); FTC 1st T, 1.33 (0.49 to 3.60); FTC 2-3 T, 0.56 (0.06 to 2.31); ATV 1st T, 1.83 (0.73 to 4.58); ATV 2-3 T, 0.87 (0.10 to 3.65); RTV 1st T, 1.60 (0.64 to 3.99); RTV 2-3 T, 1.18 (0.29 to 3.54); ZDV 1st T, 1.02 (0.45 to 2.28); ZDV 2-3 T, 1.02 (0.48 to 2.17); LPVr 1st T, 1.66 (0.81 to 3.38); LPVr 2-3 T, 0.80 (0.35 to 1.82); EFV 1st T, 2.84 (1.13 to 7.16); EFV 2-3 T, NA (0 to 9.05); Any NRTI 1st T, 0.84 (0.11 to 39.45); Any NRTI 2-3 T, 0.62 (0.08 to 29.05); Any PI 1st T, 1.32 (0.64 to 2.71); Any PI 2-3 T, 1.15 (0.58 to 2.29); Any NNRTI 1st T, 1.53 (0.72 to 3.25); Any NNRTI 2-3 T, 0.77 (0.14 to 2.69)
Congenital Abnormalities | Sibiude et al, 2014^71^; France | Preferred initial treatment drugs in U.S.:; A. ABC (1,104; 8%); B. 3TC (9,170; 70%); C. TDF (1,031; 8%); D. FTC (670; 5%); E. ATV (513; 4%); F. RTV (5,087; 39%); Alternative initial treatment drugs in U.S.:; G. ZDV (10,760; 82%); H. LPV (3,704; 28%); I. EFV (389; 3%); J. Any NRTI (12,663; 96%); K. Any PI (7,235; 55%); L. Any NNRTI (1,504; 11%); Total N=13,124 | Birth defects EUROCAT and MACDP classifications | EUROCAT 4.4%^*^; MACDP 7.0%^*^ | All vs. unexposed (EUROCAT):; ABC 1st T, 1.39 (1.06 to 1.83); ABC 2-3 T, 1.16 (0.90 to 1.51); 3TC 1st T, 1.37 (1.06 to 1.73); 3TC 2-3 T, 1.26 (1.01 to 1.57); TDF 1st T, 0.75 (0.51 to 1.10); TDF 2-3 T, 0.82 (0.40 to 1.69); FTC 1st T, 0.52 (0.30 to 0.90); FTC 2-3 T, 1.38 (0.63 to 3.02); ATV 1st T, 0.58 (0.32 to 1.05); ATV 2-3 T, 1.23 (0.38 to 4.01); RTV 1st T, 0.86 (0.67 to 1.10); RTV 2-3 T, 0.92 (0.74 to 1.15); ZDV 1st T, 1.39 (1.06 to 1.83); ZDV 2-3 T, 1.16 (0.90 to 1.51); LPV 1st T, 0.92 (0.68 to 1.23); LPV 2-3 T, 1.13 (0.90 to 1.41); EFV 1st T, 1.16 (0.73 to 1.85); EFV 2-3 T, 1.83 (0.23 to 14.5); Any NRTI 1st T, 2.36 (0.86 to 6.47); Any NRTI 2-3 T, 2.04 (0.75 to 5.59); Any PI 1st T, 0.91 (0.73 to 1.13); Any PI 2-3 T, 0.94 (0.77 to 1.16); Any NNRTI 1st T, 1.02 (0.76 to 1.37); Any NNRTI 2-3 T, 1.21 (0.72 to 2.03)
Congenital Abnormalities | Williams et al, 2015^76^; U.S.; PHACS/SMARTT | Preferred initial treatment drugs in U.S.:; A. ABC (222; 9%); B. 3TC (797; 32%); C. TDF (431; 17%); D. FTC (374; 15%); E. ATV (222; 9%); F. RTV (635; 25%); G. DRV (54; 2%); Alternative initial treatment drugs in U.S.:; H. ZDV (726; 29%); I. LPV (341; 9%); J. EFV (94; 4%); K. Any NRTI (1,211; 48%); L. Any PI (887; 35%); M. Any NNRTI (214; 9%); Total N=2,580 | Birth defects Antiretroviral Pregnancy Registry modification to MACDP classifications | 6.8% | All vs. unexposed:; A. 0.94 (0.53 to 1.65); B. 1.14 (0.81 to 1.60); C. 1.14 (0.76 to 1.71); D. 1.14 (0.74 to 1.74); E. 1.95 (1.24 to 3.05); F. 1.56 (1.11 to 2.20); G. 0.30 (0.04 to 2.21); H. 1.10 (0.78 to 1.56); I. 1.37 (0.90 to 2.09); J. 1.13 (0.51 to 2.50); K. 1.19 (0.86 to 1.65); L. 1.39 (1.00 to 1.92); M. 0.97 (0.54 to 1.74)

Note: Studies that adjusted for confounders.

* Percent of study population.

Abbreviations: 3TC=lamivudine; ABC=abacavir; APGAR=appearance, pulse, grimace, activity, respiration; aRR=adjusted risk ratio; ART=antiretroviral therapy; ARV=antiretroviral; ATV=atazanavir; ATV/r=atazanavir/ritonavir; AZT=azidothymidine; CD4=cluster of differentiation 4; CI=confidence interval; D4T=stavudine; DRV=darunavir; EFV=efavirenz; EUROCAT=European Surveillance of Congenital Anomalies; FTC=emtricitabine; HAART=highly-active antiretroviral therapy; IMPAACT=International Maternal Pediatric Adolescents AIDS Clinical Trials Network; LPV=lopinavir; LPVr=lopinavir/ritonavir; MACDP=Metropolitan Atlanta Congenital Defects Program; NA=not assessed; NR=not reported; NNRTI=nonnucleoside reverse transcriptase inhibitor; NRTI=nucleoside reverse transcriptase inhibitor; NS=not significant; NVP=nevirapine; OR=odds ratio; PHACS=Pediatric HIV/AIDS Cohort Study; PI=protease inhibitor; RAL=raltegravir; RPV=rilpivirine; RR=relative risk; RTV=ritonavir; SGA=small size for gestational age; SMARTT=Surveillance Monitoring for ART Toxicities study; 1st T=first trimester; 2-3 T=second and third trimester; TDF=tenofovir disoproxil fumarate; TZV=abacavir/zidovudine/lamivudine; U.K.=United Kingdom; U.S.=United States; VSGA=very small size for gestational age; ZDV=zidovudine.

One open-label, Africa-based RCT^44^ and 21 cohort studies in 30 publications^46–50,52–59,61,62,64–73,75–79^ published since the prior USPSTF review evaluated the association between maternal exposure to ART and risk of preterm delivery, low birth weight, and other birth outcomes (Table 3; Appendix B Tables 2–5). Sample sizes ranged from 183 to 13,124 (total N=71,472). Eight studies were conducted in the United States, seven studies in Canada or Europe, and the remainder in Africa or Latin America. One cohort study, the Antiretroviral Pregnancy Registry^47^ (n=22,360), is an international (69 countries) voluntary registry with 74 percent of data currently from the United States and its territories. ART regimens and comparisons varied across studies. Most cohort studies did not include a control group of women who did not receive ART; other methodological limitations were high attrition and unclear blinding of outcome assessors or data analysts.

The new fair-quality RCT (PROMISE; n=3,490) (see Key Question 4 for study details)^44^ found ART with zidovudine, lamivudine, and lopinavir/ritonavir associated with increased risk of preterm delivery versus zidovudine monotherapy (20.5% vs. 13.1%; p<0.001). Zidovudine-containing combination therapy was also associated with increased risk of low birth weight (23% vs. 12%; p<0.001) and “any adverse birth outcome” (defined as low birth weight, preterm delivery, spontaneous abortion, stillbirth, or congenital anomaly; 40% vs. 27.5%; p<0.001). ART with tenofovir, emtricitabine, and lopinavir/ritonavir was associated with increased risk of low birth weight (16.9% vs. 8.9%; p=0.004) and any neonatal adverse event (34.7% vs. 27.2%; p=0.04) versus zidovudine monotherapy; effects on risk of preterm delivery were not statistically significant (18.5% vs. 13.5%; p=0.09). Tenofovir-containing ART was associated with increased risk of early infant death versus zidovudine-containing ART (4.4% vs. 0.6%; p<0.001) and increased risk of very preterm (<34 weeks) delivery (6.0% vs. 2.6%; p=0.04), but there was no difference between tenofovir-containing ART versus zidovudine monotherapy in risk of early infant death (4.4% vs. 3.2%; p=0.43). There were also no differences in the rates of stillbirth between treatments. Methodological limitations of the trial included open-label design and changes in randomization from two ART groups (period 1) to three groups (period 2), resulting in a smaller sample for tenofovir-containing ART. Comparisons between zidovudine-containing ART and zidovudine monotherapy included outcomes from both period 1 and period 2 (N=3,084), whereas comparisons between tenofovir-containing ART (N=406) and zidovudine-containing ART (N=410) or zidovudine monotherapy (N=413) included only outcomes from period 2. In addition, there were unexplained differences in rates of events with zidovudine-containing ART between period 1 and period 2 for neonatal death (1.2% vs. 0.6%) and stillbirth (3.3% vs. 0.9%).

Consistent with the prior USPSTF review, one new RCT^44^ and three new cohort studies^54,72,75,78^ found ART containing a boosted protease inhibitor associated with an approximate 30 percent increased risk of preterm birth versus treatment not containing a boosted protease inhibitor (N=7,584). However, two new cohort studies (N=1,140) found treatment with a protease inhibitor associated with a 50 percent decreased risk of preterm delivery^54^ or no difference in risk^52^ when compared with no ART.

Like the prior review,^1^ new evidence identified for this update also found mixed evidence on other adverse birth outcomes. Four new cohort studies evaluated effects of ART on risk of low birth weight.^56,62,66,69^ Two studies found combination ART associated with an approximate 80 percent decreased risk of low birth weight versus no ART (two studies; N=3,192),^56,62^ one study found no association between ART versus no ART and low birth weight (one study; N=2,599),^66^ and two studies found no difference between tenofovir-containing versus nontenofovir-containing ART in risk of low birth weight (two studies; N=3,650).^67,69^

Ten new cohort studies (in 11 publications) evaluated the association between ART and risk of small for gestational age.^46,50,52,57,62,66,69,73,75,78,79^ Four new cohort studies found about a 40 percent decreased risk of small for gestational age with some regimens (three studies, N=8,404),^46,78,79^ and one study (n=1,814) reported a decrease risk of small for gestational age with the ART regimen tenofovir, emtricitabine, and efavirenz compared with no ART (adjusted OR, 0.25 [95% CI, 0.07 to 0.87]).^62^ Other studies found no effect between different ART regimens on risk of small for gestational age,^46,52,69,73,75^ or no effect of ART versus no ART on risk of small for gestational age.^52,66^ One new cohort study (n=5,726) found treatment with the ART regimen zidovudine, lamivudine, and either nevirapine- or ritonavir- boosted lopinavir associated with increased risk of small for gestational age versus zidovudine monotherapy (adjusted OR, 1.5 [95% CI, 1.2 to 1.9]),^50^ while two other studies reported no difference between ART and zidovudine monotherapy.^57,66^

Five studies evaluated the association between ART and risk of stillbirth.^56,62,65,78,79^ One cohort study (n=5,726) found treatment with ART associated with increased risk of stillbirth versus zidovudine monotherapy (adjusted OR, 2.5 [95% CI, 1.6 to 3.9]),^50^ while two studies reported a significantly decreased risk of stillbirth compared with no ART.^56,62^ Stillbirth was less likely with the regimen tenofovir, emtricitabine, and efavirenz compared with zidovudine, lamivudine, and nevirapine (n=3,837; adjusted relative risk [RR], 0.43 [95% CI, 0.31 to 0.61]),^78^ but the difference was not statistically significant when tenofovir, emtricitabine, and efavirenz was compared with other ART regimens grouped together (n=3,226; adjusted OR, 0.6 [95% CI, 0.3 to 1.3]).^79^ Two new cohort studies (n=4,381) reported no increase in risk of neonatal death with tenofovir-based ART^65,78^ but one study (n=2,639) found increased risk of neonatal death with the ART regimen zidovudine, lamivudine, and ritonavir-boosted lopinavir compared with tenofovir, emtricitabine, and efavirenz (adjusted RR, 4.01 [95% CI, 1.78 to 9.11]).^78^ A combined analysis of two studies (n=1,621) found no difference in risk of fetal loss (undefined in this study but normally would include spontaneous abortion, fetal demise, and stillbirth) between initial therapy with tenofovir and emtricitabine combined with either ritonavir-boosted lopinavir or atazanavir versus zidovudine and lamivudine combined with ritonavir-boosted lopinavir.^67^ This study also found no difference in risk of neonatal death within 14 days after birth between the three treatment regimens.

#### Overall Congenital Abnormalities

The 2012 USPSTF review found no association between perinatal exposure to ART and overall congenital abnormalities, based on three cohort studies.^90,91,98^ Five new cohort studies (N=40,436),^53,55,71,76^ including the Antiretroviral Pregnancy Registry,^47^ evaluated the association between combination ART in HIV-infected pregnant women and risk of congenital anomalies (Table 3). All of the newer cohort studies included patients who received one or more of the preferred nucleoside reverse transcriptase inhibitors for use in pregnancy (abacavir, lamivudine, tenofovir, or emtricitabine). Most antiretroviral agents and classes were not associated with an increased risk of congenital abnormalities, but findings were limited by small numbers of studies, imprecision in estimates, and multiple comparisons. One study found no antiretroviral agent associated with increased risk of birth defects.^53^ One study found an association between atazanavir, ritonavir, or any protease inhibitor and increased risk of congenital abnormalities versus nonexposure;^76^ one study found an association between lamivudine, first-trimester exposure to abacavir, and first-trimester exposure to zidovudine and risk of congenital abnormalities;^71^ one study found an association between first-trimester exposure to efavirenz and risk of congenital abnormalities;^55^ and one study found emtricitabine associated with decreased risk of congenital anomalites.^71^ The Antiretroviral Pregnancy Registry found zidovudine associated with increased risk of overall birth defects, but ritonavir associated with decreased risk.^47^

One of the cohort studies (n=2,580) also reported specific categories of birth defects in children exposed in utero to ART.^76^ Atazanavir was associated with increased risk of congenital musculoskeletal and skin anomalies (adjusted OR, 2.57 [95% CI, 1.30 to 5.08] and 6.01 [95% CI, 1.43 to 25.3], respectively). Ritonavir as booster therapy was associated with musculoskeletal birth defects (adjusted OR, 1.79 [95% CI, 1.02 to 3.14]) and zidovudine was associated with increased risk of male genital defects (primarily hypospadias and cryptorchidism; adjusted OR, 3.18 [95% CI, 1.10 to 9.22]). An additional cohort study found exposure to ART during the first trimester associated with malformation of the small intestine (adjusted OR, 10 [95% CI, 2.85 to 37]),^48^ but there was no increase in risk of birth defects with prenatal ART exposure on the urogenital, musculoskeletal, nervous, and circulatory systems.

#### Cardiovascular Congenital Anomalies

The 2012 USPSTF review included one cohort study^95^ that found no association between in utero exposure to zidovudine and acute or chronic abnormalities in left ventricular structure or function, although another study^96^ found an association between in utero ART and echocardiographic findings of unknown clinical significance in children age 2 years or younger. We identified one subsequent RCT and two cohort studies (in three publications) that also reported somewhat mixed results on the association between ART exposure and cardiac findings^58,70,76^ (Appendix B Tables 2 and 3). A U.S.-based cohort study (the Surveillance Monitoring for ART Toxicities [SMARTT] study) of 2,580 HIV-uninfected children born between 1995 and 2008 with in utero ART exposure found no currently recommended ART drug associated with increased risk of cardiovascular defects, although there was a trend toward increased risk with ritonavir (adjusted OR, 1.83 [95% CI, 0.96 to 3.49]).^76^ A large French cohort study of 12,888 children born between 1994 and 2010 found first-trimester exposure to zidovudine associated with congenital heart defects compared with no zidovudine exposure (1.5% vs. 0.77%; adjusted OR, 2.2 [95% CI, 1.5 to 3.2]).^70,71^ The most common condition was ventricular septal defect. A second analysis of 400 HIV-uninfected children exposed to ART in utero^58^ found that at age 2 to 7 years (median, 4 years), exposure to some antiretroviral drugs, particularly during the first trimester, was associated with reduced stress velocity index, reduced left ventricular short-axis dimension, and increased left ventricular posterior wall thickness. None of the echocardiographic findings were associated with significant cardiovascular compromise.

Another study evaluated the association between in utero exposure to ART and echocardiographic measures. A nested RCT within a cohort (Protease Inhibitor Monotherapy Evaluation [PRIMEVA] French National Agency for Research on AIDS and Viral Hepatitis [ANRS] 135 study) of combination ART (zidovudine, lamivudine, and ritonavir-boosted lopinavir) versus protease inhibitor monotherapy (ritonavir-boosted lopinavir alone) performed echocardiographic assessments at 1 month (n=53) and 1 year (n=42). There was no difference in echocardiographic parameters in boys, but in girls combination therapy was associated with higher left ventricular shortening fraction at 1 month (a measure of decreased left ventricular systolic function; p=0.02) and a trend toward increased posterior wall thickness at 1 year (p=0.07).^70^

A third study (n=367) found no effect of ART versus no ART exposure during the first trimester on cardiovascular congenital anomalies (adjusted OR, 0.75 [95% CI, 0.31 to 1.85]).^48^

#### Neurodevelopmental Outcomes in Children

The 2012 USPSTF review included three cohort studies that found no association between in utero exposure to ART and long-term adverse effects on child growth and development.^89,93,103^ We identified two publications of a U.S.-based surveillance cohort (the SMARTT study) of HIV-exposed, uninfected infants and children (Appendix B Table 2).^64,77^ One study measured the Wechsler Preschool and Primary Scale of Intelligence-III at age 5 years (n=369) and the Wechsler Abbreviated Scale of Intelligence and the Wechsler Individual Achievement Test at ages 7, 9, 11, and 13 years (n=451).^64^ There was no association between in utero exposure to ART and lower scores on these tests, although test scores were lower overall than in population norms. In younger children, in utero exposure to tenofovir was associated with higher performance intelligence quotient, based on the Wechsler Preschool and Primary Scale of Intelligence-III, compared with children not exposed to tenofovir (p<0.05). Another publication from the SMARTT study found in utero exposure to combination ART associated with less neurodevelopmental impairment than no in utero exposure to ART (adjusted RR, 0.47 [95% CI, 0.27 to 0.83]) (Appendix B Tables 2 and 3).^77^

#### Maternal Harms

The 2012 USPSTF review included one study that found receipt of ART during pregnancy associated with increased risk of gestational diabetes (adjusted OR, 3.5 [95% CI, 1.2 to 10]) and anemia (adjusted OR, 1.6 [95% CI, 1.1 to 2.4]) compared with no ART.^101^ Two additional studies reported a trend toward increased risk of gestational diabetes with ART compared with monotherapy or no ART (RR, 9.37 [95% CI, 0.57 to 153]^102^ and RR, 1.86 [95% CI, 0.65 to 5.29]^97^). We identified no new studies on the association between use of ART during pregnancy versus no ART and risk of diabetes or gestational diabetes. One RCT conducted in three African countries (n=8,848) of women with CD4 counts of 200 to 500 cells/mm^3^ found no difference in risk of anemia between combination ART (zidovudine, lamivudine, and ritonavir-boosted lopinavir) beginning between 28 and 36 weeks of gestation and zidovudine monotherapy starting from 34 to 36 weeks of gestation until onset of labor followed by zidovudine and a single dose of nevirapine at the onset of labor (Appendix B Tables 2 and 3).^45^ Women were given iron and folic acid supplementation upon study enrollment.

In the previously discussed PROMISE trial (n=3,490; see Key Question 4 for study details), antenatal zidovudine-based combination ART was associated with a higher rate of maternal grade 2 or higher adverse events than zidovudine alone (21% vs. 17%; p=0.008; specific adverse events not reported) and increased risk of abnormalities in blood chemistry values (5.8% vs. 1.3%; p<0.001), primarily elevation in alanine aminotransferase levels.^44^ There was also an increased risk of abnormal blood chemistry values (not specified) with tenofovir-based ART than with zidovudine monotherapy (2.9% vs. 0.8%; p=0.03). Few women withdrew from the study due to adverse events.