# Chapter 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^39^ the USPSTF and the Agency for Healthcare Research and Quality determined the scope and Key Questions for this review. Investigators created an analytic framework with the Key Questions and the patient populations, interventions, and outcomes reviewed (Figure 1). Key informants with expertise in HIV screening and HIV infection during pregnancy were surveyed for input, and the draft Research Plan was posted for public comment prior to finalization. The target population for HIV screening was pregnant women (including adolescents, defined as women ages 13 to <18 years) without signs or symptoms of HIV infection.

Figure 1 Analytic Framework and Key Questions

*Harms of screening include false-positive results, anxiety and effects of labeling, and partner discord, abuse, or violence.

^†^ Harms of treatment include adverse maternal and infant outcomes associated with use of antiretroviral therapy.

Abbreviation: CD4=cluster of differentiation 4.

Key Questions

1. What are the benefits of screening for HIV infection in pregnant women on risk of mother-to-child transmission of HIV infection?
2. What is the yield of repeat HIV screening at different intervals in pregnant women, and how does the yield of screening vary in different risk groups?
3. What are the harms of screening for HIV infection in pregnant women?
4. What is the effectiveness of currently recommended ART regimens for reducing mother-to-child transmission of HIV infection?
5. What are the harms of currently recommended ART regimens given during pregnancy to the mother and infant?

The analytic framework shows the relationship between the population, intervention, outcomes, and harms of screening for HIV. The far left of the framework describes the target population for screening as asymptomatic pregnant women not known to be HIV positive. To the right of the population is an arrow corresponding to key question 2, which represents screening. This arrow leads to both HIV-positive and HIV-negative populations, and an arrow assessing potential harms of screening corresponds to key question 3. From the HIV-positive population, an arrow leads to disease staging with viral load and CD4 count testing followed by intervention with antiretroviral therapy (key question 4), which assesses the clinical outcome of mother-to-child transmission of HIV infection. This step may lead to harms, which corresponds to key question 5. An arrow assessing potential harms of treatment follows, which corresponds to key question 5, and includes adverse maternal and infant outcomes associated with use of antiretroviral therapy. An overarching arrow for key question 1 goes directly from screening to the clinical outcome.

### Key Questions

1. What are the benefits of screening for HIV infection in pregnant women on risk of mother-to-child transmission of HIV infection?
2. What is the yield of repeat HIV screening at different intervals in pregnant women, and how does the yield of screening vary in different risk groups?
3. What are the harms of screening for HIV infection in pregnant women?
4. What is the effectiveness of currently recommended ART regimens for reducing mother-to-child transmission of HIV infection?
5. What are the harms of currently recommended ART regimens given during pregnancy to the mother and infant?

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, and Ovid MEDLINE (2012 through June 2018) for relevant studies and systematic reviews. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles.

After June 2018, we conducted surveillance through article alerts and targeted searches of high-impact journals to identify major studies that may affect conclusions. The last surveillance was conducted on January 25, 2019 and identified no primary research that would meet inclusion criteria for this review.

## Study Selection

All titles and abstracts identified through searches were independently reviewed by two members of the research team for eligibility against predefined inclusion and exclusion criteria, as specified using the PICOTS (population, intervention, comparator, outcome, timing, study design/setting) framework (Appendix A2). Studies marked for possible inclusion by either reviewer underwent full-text review. All results were tracked using EndNote® reference management software (Thomson Reuters, New York, NY).

Each full-text article was independently reviewed by two trained members of the research team for inclusion or exclusion on the basis of the eligibility criteria. If the reviewers disagreed, conflicts were resolved by discussion and consensus or by consulting another member of the review team. Results of the full-text review were also tracked in the EndNote database, including the reason for exclusion for full-text publications. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists the included studies, and Appendix A5 lists the excluded studies with reasons for exclusion.

### Scope of Review

The prior USPSTF recommendation on prenatal HIV screening was an “A” recommendation, based on convincing evidence that the benefits of prenatal screening substantially outweigh harms. This review focuses on key areas for which evidence was lacking in the prior USPSTF review, including direct evidence on benefits and harms (including false-positive results and anxiety) of screening and the yield of repeat screening during pregnancy. Given changes in ART regimens that are used in pregnant women, this review addresses evidence on effectiveness and harms of ART,^23^ with a focus on regimens currently recommended by the U.S. Department of Health and Human Services Panel on Treatment of Pregnant Women with HIV Infection and Prevention of Perinatal Transmission. A list of currently recommended ART regimens in pregnant women is shown in Appendix B Table 1. Most studies that reviewed various ART regimens evaluated outcomes associated with components of ART regimens, rather than entire regimens; we included studies that evaluated currently recommended regimens or ART agents that are part of currently recommended regimens. We excluded regimens and ART agents that are no longer recommended in current U.S. practice.

This update does not address diagnostic accuracy of screening, which the USPSTF previously found to be high.^40,41^ This update also does not rereview effects of avoidance of breastfeeding and elective cesarean delivery in women with viremia on risk of perinatal transmission, as the effectiveness of these interventions is well established^4,40,41^ and part of standard U.S. practice. Effects of early initiation of long-term ART are addressed in a separate report on screening for HIV infection in nonpregnant adolescents and adults.^42^

The population of interest for prenatal screening is asymptomatic pregnant women not known to be HIV-positive. For Key Questions on benefits and harms of ART, the population was HIV-infected pregnant women. Patient subgroups included those defined by age and race/ethnicity. The screening intervention was standard or rapid HIV antibody testing with confirmatory testing. Outcomes were mother-to-child transmission, yield of screening (number of cases of HIV infection identified per number of tests performed), harms of screening (including labeling, anxiety, and other harms), and maternal and infant harms of treatment, including long-term harms following in utero exposure to ART. For Key Questions on screening, comparisons were screening versus no screening, one-time versus repeat screening, and repeat screening at different intervals. For Key Questions on benefits and harms of ART, we included studies that compared full-course (initiated in first or early second trimester) combination ART versus no ART, abbreviated courses of ART, or one- or two-drug therapy. For all Key Questions, we included randomized, controlled trials (RCTs), cohort studies, and case-control studies. We included studies conducted in primary care–applicable settings (e.g., prenatal, antenatal, and family planning clinics) and other health care settings in which screening is commonly performed (e.g., emergency room, urgent care, or labor and delivery). Although the target for treatment studies was those conducted in the United States and other high-income/low HIV prevalence countries, we also included RCTs on effects of ART on mother-to-child transmission conducted in low- and middle-income settings. For harms associated with prenatal ART, we included RCTs and cohort studies from any setting but restricted cohort studies to those that adjusted for potential confounders.

## Data Abstraction and Quality Rating

For studies meeting inclusion criteria, we abstracted data on characteristics of study populations, interventions, comparators, outcomes, study designs, settings, and methods. For each study, data abstraction was conducted by one investigator and reviewed for completeness and accuracy by another investigator.

Predefined criteria were used to assess the quality of individual controlled trials, systematic reviews, and observational studies developed by the USPSTF. Studies were rated as “good,” “fair,” or “poor” quality in accordance with USPSTF methods, based on the seriousness of the methodological shortcomings (Appendix A6).^39^ For each study, quality assessment was independently performed by two team members. Any disagreements were resolved by consensus.

## Data Synthesis

We did not attempt meta-analysis of studies on effectiveness of ART on mother-to-child transmission or on harms of ART due to differences across studies in ART regimens and comparisons evaluated, harms outcomes, geographic settings, and methodological factors (e.g., observational studies performed statistical adjustment on different variables). There were too few studies to consider meta-analysis for other Key Questions.

For all Key Questions, the overall quality of evidence was determined using the approach described in the USPSTF Procedure Manual.^39^ Evidence was rated “good,” “fair,” or “poor,” based on the number, quality, and size of studies, consistency of results between studies, and directness of evidence, and is summarized in a table.^39^

## External Review

The draft report was reviewed by content experts (Appendix A7), USPSTF members, Agency for Healthcare Research and Quality Project Officers, and collaborative partners, and was posted for public comment; it has been revised accordingly.

## Response to Public Comments

The draft report was posted for public comment from November 20, 2018 to December 26, 2018, and few comments were received. In response to the comments, we added a reference in the Discussion section to a systematic review on the safety of tenofovir disoproxil fumarate (TDF) in pregnancy.^43^