# Chapter 1 Introduction and Background

## Purpose

HIV infection is transmissible during pregnancy and the postpartum period. The purpose of this report is update a previous review^1,2^ commissioned by the U.S. Preventive Services Task Force (USPSTF) on benefits and harms of prenatal screening for HIV infection. This report will be used to update the USPSTF’s 2013 recommendation, which states that clinicians screen all pregnant women for HIV, including those who present in labor who are untested and whose HIV status is unknown (“A” recommendation),^3,4^ a confirmation of the USPSTF’s 2005 recommendation on prenatal HIV screening. The confirmation was based on prior findings that antiretroviral therapy (ART) is acceptable to pregnant women and that early detection and treatment of HIV is associated with large reductions in the risk of mother-to-child transmission, as well as some evidence that newer antiretroviral regimens are more effective than older regimens for preventing perinatal transmission. Although the USPSTF found some evidence that perinatal ART is associated with increased risk of preterm delivery, there was no clear association with low birth weight, congenital abnormalities, or impaired infant neurodevelopment, and no data indicating serious maternal harms.^1,2^

## Condition Background

### Condition Definition

HIV is a ribonucleic acid (RNA) retrovirus that infects human immune cells, in particular CD4+ helper T lymphocyte (CD4) cells. Left untreated, HIV infection results in progressive immunodeficiency and AIDS.^5^ AIDS is a life-threatening condition characterized by presence of HIV infection and severe immune dysfunction (CD4 count ≤200 cells/mm^3^) or one or more AIDS-defining neoplastic conditions or opportunistic infections.^5^ HIV-1 infection is the most common variant in the United States. HIV-2 infection is rare in the United States, less clinically severe, and endemic in parts of West Africa.^6^

In HIV-infected pregnant women, HIV can cross the placenta, is present in cervical secretions in blood, and is present in breast milk. Therefore, transmission of HIV infection from mother to child can occur during pregnancy, during labor and delivery, and in the postpartum period through breastfeeding.^7^

### Prevalence and Burden of Disease/Illness

In 2017, women accounted for 19 percent of all new diagnoses of HIV infection among adults and adolescents in the United States.^8^ Between 2012 and 2017, the number of new HIV diagnoses in women declined 11 percent.^9^ About 235,004 women in the United States were living with HIV infection in 2016, with 7,312 new cases.^9^ Approximately 258 new diagnoses were in women ages 13 to 19 years.^9^ An estimated 60 percent of infections were in black women, 20 percent in white women, and 15 percent in Hispanic/Latina women.^9^ An estimated 12 percent of women with HIV infection are unaware of their status.^10^

Approximately 8,500 HIV-positive women give birth each year in the United States.^7^ In 2005 to 2008, approximately 30 percent of HIV-infected women were unaware of their status prior to pregnancy and approximately 4 percent were undiagnosed prior to the time of delivery.^11^ Mother-to-child transmission accounts for approximately three-quarters of pediatric HIV infections in the United States and 90 percent of pediatric cases of AIDS.^7^ Through 2013, there have been nearly 5,000 cumulative deaths of U.S. children younger than age 13 years with perinatally acquired HIV infection.^7^ The number of cases of perinatal HIV infection in the United States peaked at about 1,650 in 1992, declining dramatically following the widespread adoption of routine prenatal screening, coupled with the use of effective therapies for preventing mother-to-child transmission. There were an estimated 215 to 370 cases of perinatal transmission in 2005^12^ and 99 cases in 2016.^8^ The Centers for Disease Control and Prevention (CDC) estimates that between 1994 and 2010, 21,956 cases of perinatally acquired HIV infection were prevented.^13,14^ The overall annual rate of perinatally acquired HIV infection decreased from 6.0 cases per 100,000 live births in 2008 to 1.8 cases per 100,000 live births in 2013.^15^ Rates of perinatally acquired HIV infection differ according to age group. In 2013, among black persons, the rate of HIV infection was 11.3 cases per 100,000 live births (from 23.6 cases per 100,000 live births in 2008), compared with 1.8 cases among Hispanic persons and 0.6 cases in white persons.

### Etiology and Natural History

Peripartum transmission of HIV infection can occur during pregnancy (intrauterine), during labor and delivery (intrapartum), and following delivery (postpartum). In the absence of breastfeeding, intrauterine transmission is thought to account for 25 to 40 percent of vertically infected infants, with the remaining cases occurring during labor and delivery.^16^ Most intrauterine transmission is thought to occur shortly before delivery.^17^ HIV is present in and transmitted through breast milk^18^ and breastfeeding is thought to be the only important mode of postpartum transmission to newborns and infants.^19,20^ In resource-poor settings in which women breastfeed for prolonged periods, postpartum transmission accounts for about 44 percent of infant cases.^21^ Antiretroviral treatment of the mother and infant does not completely eliminate breastfeeding transmission risk.^22^ In the United States, HIV-infected women are advised against breastfeeding, given the risk of transmission and the availability of affordable and safe alternatives.^23^

### Risk Factors

Most (87%) new HIV diagnoses in women (regardless of pregnancy status) are attributed to acquisition via heterosexual sex, followed by injection drug use (12%).^24^ In HIV-infected pregnant women, about 50 percent were exposed to HIV through heterosexual contact, 8 percent through injection drug use, and 8 percent through some other exposure category (such as blood transfusion or perinatal exposure).^11^ In about one-third of women, HIV exposure was unknown.

Well-established risk factors for perinatal transmission include higher viral load, immunologically or clinically advanced disease in the mother, prolonged rupture of membranes, maternal infection with other sexually transmitted infections, and labor and delivery procedures and events associated with an increased probability of bodily fluid contact between mother and infant (such as abruptio placentae, fetal scalp electrode use, episiotomy, and second-degree or greater perineal laceration).^25^

Risk factors for clinical progression of HIV infection (in particular, high viral load and low CD4 count) appear to be similar for pregnant and nonpregnant women. In developed countries, pregnancy itself does not appear to be an important independent predictor of clinical progression in chronically-infected HIV-positive women.^26,27^

### Rationale for Screening/Screening Strategies

A major goal of prenatal screening for HIV is to reduce the risk of mother-to-child transmission through provision of subsequent interventions. Other important goals are to improve long-term clinical outcomes in HIV-infected women through initiation of ART and other interventions (e.g., prophylaxis for opportunistic infections in women with immunologically advanced disease), facilitate early identification of infected newborns, help women to make more informed future reproductive choices, and reduce risk of horizontal transmission through effects on risky behaviors. The prior USPSTF review on prenatal HIV screening found that ART in combination with avoidance of breastfeeding and elective Caesarean delivery in women with viremia substantially reduces risk of mother-to-child transmission, from 9 to 22 percent with no ART to less than 1 to 2.4 percent with full-course combination ART.^3,4^

### Interventions/Treatment

The current standard of care to prevent perinatal transmission of HIV infection in the United States is combination ART started at the time of diagnosis in all HIV-infected women (regardless of viral load or CD4 count), intravenous zidovudine and elective Caesarean delivery before labor or rupture of membranes in women with HIV RNA levels greater than 1,000 copies/mL or unknown HIV RNA levels near the time of delivery, antiretroviral treatment of the infant in the postnatal period, and avoidance of breastfeeding.^23^ The selection of antiretroviral drugs is based on evidence on effectiveness for reducing perinatal transmission, risks to the fetus, side effect profile, and other factors, such as the potential for drug interactions or the possibility of inducing antiretroviral drug resistance, and may be informed by results of antiretroviral drug resistance testing. Because delayed treatment may reduce effectiveness of ART on risk of mother-to-child transmission, current guidelines recommend that clinicians consider initiating ART as soon as HIV is diagnosed during pregnancy, and not delay selection of the initial ART while awaiting results of drug resistance testing.^23^ For women who present in labor with unknown HIV status, rapid testing with initiation of maternal (intravenous zidovudine during labor) and infant (combination ART) prophylaxis is recommended, with continuation of infant prophylaxis based on results of confirmatory testing. Consistent with management of nonpregnant persons with HIV infection, guidelines now recommend that HIV-positive women diagnosed during pregnancy be offered long-term ART following delivery, regardless of CD4 count.^23,28^

HIV-positive women identified during pregnancy may also benefit from other interventions that would be considered in nonpregnant persons with HIV infection, including long-term ART, prophylaxis for opportunistic infections, immunizations, and counseling to reduce high-risk behaviors for horizontal transmission; in addition, male sexual partners may benefit from pre-exposure prophylaxis with ART.^29^

### Current Clinical Practice/Recommendations of Other Groups

The diagnostic accuracy of standard HIV testing is thought to be similar for pregnant and nonpregnant persons.^30^ A large, prospective cohort study of 5,744 pregnant women presenting in labor in six U.S. cities (HIV prevalence, 0.59%) found rapid testing (prior to confirmation) associated with a sensitivity of 100 percent, specificity of 99.9 percent, positive predictive value of 90 percent, and negative predictive value of 100 percent.^31^ Point-of-care rapid tests are recommended for women presenting in labor who have not received prenatal care or who were not tested earlier in pregnancy for other reasons.^32^ Basing therapeutic decisions on a positive rapid test prior to confirmation is only recommended in situations in which decisions to initiate treatments cannot wait, such as in women presenting in active labor. Otherwise, confirmation of positive rapid tests prior to initiating interventions is recommended due to the possibility of false-positive tests,^31^ which could result in unnecessary exposure to antiretroviral or other therapies.

Current practice in the United States for HIV screening in pregnant women includes “opt-out” HIV screening at the initial prenatal visit as part of the standard prenatal test panel.^23^ Opt-out screening refers to screening that is performed after informing the woman about the test, unless the woman specifically declines. The CDC recommends that clinicians consider repeat testing in all women in the third trimester for those who test negative initially, and recommends repeat testing for women who continue to practice high-risk behaviors or who live in a high-incidence setting.^32^

In the United States, about 85 percent of HIV-infected women receive ART during pregnancy, with about 40 percent undergoing an elective cesarean delivery.^11^ More than 95 percent of infants born to HIV-infected women receive ART during the postnatal period.

Many groups, including the American College of Obstetricians and Gynecologists,^33^ the American Academy of Pediatrics,^34,35^ the American College of Physicians,^36^ and the CDC^32,37^ recommend voluntary “opt out” testing for HIV in all pregnant women as part of routine prenatal care. The CDC^32,37^ and the American College of Obstetricians and Gynecologists^33^ recommend repeat testing for women with risk factors and those who live or receive care in high-incidence settings, and recommend that clinicians consider repeat testing for all women with a negative test result early in pregnancy. The USPSTF recommends that women screened during a previous pregnancy be rescreened in subsequent pregnancies, but does not address repeat screening during the same pregnancy.^4^ The American Academy of Family Physicians follows the 2013 USPSTF recommendation.^38^