# Appendix B Evidence Tables and Quality Tables

Appendix B Table 1 Currently Recommended Initial Regimens for Antiretroviral-Naive Pregnant Women With HIV

Appendix B Table 2 Evidence Table of Included Studies: Study Characteristics

Appendix B Table 3 Evidence Table of Included Studies: Results

Appendix B Table 4 Quality Assessment of Cohort Studies

Appendix B Table 5 Quality Assessment of Randomized Trials