# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Screening

#### Database: Ovid MEDLINE(R) without Revisions

1. exp HIV/
2. HIV Antibodies/
3. HIV Antigens/
4. HIV Seroprevalence/
5. HIV Seropositivity/
6. HIV Seronegativity/
7. AIDS Serodiagnosis/
8. human immunodeficiency virus.ti,ab
9. hiv.ti,ab.
10. Mass Screening/
11. screen$.ti.
12. or/1-9
13. 10 or 11
14. 12 and 13
15. limit 14 to (english language and humans)
16. limit 15 to yr=“2012 - 2018”
17. 16 and pregnan*.ti,ab.
18. 16 and mother*.ti,ab.
19. 17 or 18

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp HIV/
2. HIV Antibodies/
3. HIV Antigens/
4. HIV Seroprevalence/
5. HIV Seropositivity/
6. HIV Seronegativity/
7. AIDS Serodiagnosis/
8. human immunodeficiency virus.ti.
9. hiv.ti,ab.
10. Mass Screening/
11. screen$.ti.
12. or/1-9
13. 10 or 11
14. 12 and 13
15. limit 14 to yr=“2012 - 2018”
16. limit 15 to english language
17. 16 and (pregnan* or mother*).ti,ab.

### Treatment

#### Database: Ovid MEDLINE(R) without Revisions and EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp HIV Infections/dt, pc, th
2. exp Anti-Retroviral Agents/ad, tu
3. Antiretroviral Therapy, Highly Active/
4. or/1-3
5. Infectious Disease Transmission, Vertical/
6. ((mother* or child*) and transmission).mp.
7. 5 or 6
8. 4 and 7
9. limit 8 to yr=“2012 - 2018”
10. limit 9 to (clinical trial, all or comparative study or meta analysis or randomized controlled trial or systematic reviews)
11. 9 and (random* or control* or cohort).ti,ab.
12. 10 or 11 (630)
13. 12 and pregnan*.mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier] (450)

### Treatment harms

#### Database: Ovid MEDLINE(R) without Revisions and EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp HIV Infections/dt, pc, th [
2. exp Anti-Retroviral Agents/ad, tu
3. Antiretroviral Therapy, Highly Active/
4. or/1-3
5. 4 and (harm* or safety or adverse).ti,ab.
6. limit 5 to yr=“2012 - 2018”
7. 6 and (pregnan* or mother*).mp.

### Screening and treatment

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. (hiv or “human immunodeficiency virus”).ti.
2. 1 and screen*.ti.
3. 1 and (treatment or antiretroviral or therapy).ti.
4. 2 or 3
5. 4 and pregnan*.mp.

## Appendix A2 Inclusion and Exclusion Criteria

Category | Include | Exclude
Settings | KQs 1–3: Primary care or other settings generalizable to primary care (e.g., prenatal, antenatal, and family planning clinics) and other health care settings in which screening is commonly performed (e.g., emergency room or urgent care); KQs 4–5: Focus on studies conducted in the United States and other high-income countries with low prevalence of HIV infection and in which management of HIV infection is similar to that in the United States, except for RCTs of ART and harms of treatment if currently recommended regimens or drugs are used | Studies of screening conducted in low- and middle-income countries, unless fair- or good-quality studies in the United States are not available
Populations | KQs 1–3: Asymptomatic pregnant women not known to be HIV positive, including adolescents (ages 13 to 18 years); KQ 4: Pregnant women living with HIV and their infants; KQ 5: Women who received ART regimens while pregnant; neonates, infants, and children who were exposed to ART in utero | KQs 1–3: Women who have known HIV infection, are on dialysis, are posttransplant, or have occupational exposure (because of risk of needle stick or other parenteral exposure); women with known infection with hepatitis C virus, hepatitis B virus, or tuberculosis; KQs 4, 5: Women who are already or were previously taking ART prior to pregnancy; women with acute HIV infection; studies limiting enrollment to persons with hepatitis C virus, hepatitis B virus, or tuberculosis coinfection
Interventions | KQs 1–3: Rapid or standard HIV antibody testing with confirmatory testing; KQs 4, 5: Currently recommended ART regimens or drugs, or studies published since 2012 that reported outcomes for combination antiretroviral regimens and reported the categorizations for ART regimens used in the study | KQs 4, 5: Regimens that are clearly outside of current U.S. practice; Women who discontinued ART during pregnancy; women with treatment interruption
Comparisons | KQs 1, 3: HIV screening vs. no screening; KQ 2: Repeat HIV screening during pregnancy vs. one-time screening; screening at one interval vs. another; KQs 4, 5: Currently recommended ART regimens; full-course combination ART vs. no ART, abbreviated courses of ART, or one- or two-drug therapy
Outcomes | KQs 1, 4: Mother-to-child HIV transmission rates; KQ 2: Yield of screening (number of cases of HIV infection identified per number of tests performed); KQ 3: Harms of screening, including false-positive results, anxiety and effects of labeling, and partner discord, abuse, or violence; KQ 5: Maternal and infant harms of treatment, including long-term harms following in utero exposure to ART | KQs 1, 5: Pharmacokinetic outcomes
Study designs/countries | KQs 1–3: RCTs and controlled observational studies; KQ 4: RCTs in any country as long as recommended ART regimens were evaluated, and observational studies in countries similar to the United States; KQ 5: RCTs and observational studies that controlled for potential confounders; any countries as long as recommended ART regimens were evaluated | KQs 1–4: Modeling studies
Timing | KQ 5: Any timing

Abbreviations: ART=antiretroviral therapy; KQ=key question; RCT=randomized, controlled trial.

## Appendix A3 Literature Flow Diagram

*Other sources include reference lists of relevant articles, studies, and systematic reviews and suggestions from reviewers; also includes background articles.

^†^In addition, 33 studies (in 35 articles) were carried forward from the prior U.S. Preventive Services Task Force reviews.

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows 1,239 citations were identified through literature database searches, 89 citations were identified through other sources, and 35 citations were identified from previous reviews, resulting in 1,232 unique citations that were screened after duplicates were removed. 162 full-text articles were reviewed for eligibility for all Key Questions after excluding 1,070 citations based on review of title and abstract. 91 articles were excluded due to: wrong population (13), wrong intervention (5), wrong outcomes (16), wrong comparator (8), wrong study design for key question (11), not a study (9), inadequate duration (1), sample size too small (1), systematic review or meta-analysis used as a source document only to identify individual studies (6), wrong country (6), or did not adjust for confounders and/or did not provide adequate data (15). 29 new studies in 36 articles were included that provide evidence for the Key Questions, as follows: 1 trial and 5 cohort studies for Key Question 4, and 2 trials and 21 cohort studies in 28 articles for Key Question 5. No evidence was included for Key Questions 1, 2, or 3. A footnote indicates that in addition, 33 studies in 35 articles were carried forward from the prior USPSTF reviews.

## Appendix A4 Included Studies List

Aaron E, Bonacquisti A, Mathew L, . Small-for-gestational-age births in pregnant women with HIV, due to severity of HIV disease, not antiretroviral therapy. Infect Dis Obstet Gynecol. 2012;2012:135030. doi: 10.1155/2012/135030. PMID: 22778533.22778533
Antiretroviral Pregnancy Registry Steering Committee. Antiretroviral Pregnancy Registry Interim Report for 1 January 1989 through 31 January 2018. Wilmington, NC: Registry Coordinating Center; 2018. http://www.apregistry.com/forms/interim_report.pdf Accessed July 27, 2018.
Berard A, Sheehy O, Zhao JP, . Antiretroviral combination use during pregnancy and the risk of major congenital malformations. AIDS. 2017;31(16):2267–77. doi: 10.1097/QAD.0000000000001610. PMID: 28806195.28806195
Chagomerana MB, Miller WC, Pence BW, . PMTCT option B+ does not increase preterm birth risk and may prevent extreme prematurity: A retrospective cohort study in Malawi. J Acquir Immune Defic Syndr. 2017;74(4):367–74. doi: 10.1097/QAI.0000000000001253. PMID: 27875363.27875363
Chen JY, Ribaudo HJ, Souda S, . Highly active antiretroviral therapy and adverse birth outcomes among HIV-infected women in Botswana. J Infect Dis. 2012;206(11):1695–705. doi: 10.1093/infdis/jis553. PMID: 23066160.23066160
Chiappini E, Galli L, Giaquinto C, . Use of combination neonatal prophylaxis for the prevention of mother-to-child transmission of HIV infection in European high-risk infants. AIDS. 2013;27(6):991–1000. doi: 10.1097/QAD.0b013e32835cffb1. PMID: 23211776.23211776
Duryea E, Nicholson F, Cooper S, . The use of protease inhibitors in pregnancy: maternal and fetal considerations. Infect Dis Obstet Gynecol. 2015 doi: 10.1155/2015/563727. PMID: 26617456.26617456
Floridia M, Mastroiacovo P, Tamburrini E, . Birth defects in a national cohort of pregnant women with HIV infection in Italy, 2001-2011. BJOG. 2013;120(12):1466–75. doi: 10.1111/1471-0528.12285. PMID: 23721372.23721372
Fowler MG, Qin M, Fiscus SA, . Benefits and risks of antiretroviral therapy for perinatal HIV prevention. N Engl J Med. 2016;375(18):1726–37. doi: 10.1056/NEJMoa1511691. PMID: 27806243.27806243
Kakkar F, Boucoiran I, Lamarre V, . Risk factors for pre-term birth in a Canadian cohort of HIV-positive women: role of ritonavir boosting? J Int AIDS Soc. 2015;18:19933. doi: 10.7448/IAS.18.1.19933. PMID: 26051165.26051165
Knapp KM, Brogly SB, Muenz DG, . Prevalence of congenital anomalies in infants with in utero exposure to antiretrovirals. Pediatr Infect Dis J. 2012;31(2):164–70. doi: 10.1097/INF.0b013e318235c7aa. PMID: 21983213.21983213
Kreitchmann R, Li SX, Melo VH, . Predictors of adverse pregnancy outcomes in women infected with HIV in Latin America and the Caribbean: a cohort study. BJOG. 2014;121(12):1501–8. doi: 10.1111/1471-0528.12680. PMID: 24602102.24602102
Li N, Sando MM, Spiegelman D, . Antiretroviral therapy in relation to birth outcomes among HIV-infected women: a cohort study. J Infect Dis. 2016;213(7):1057–64. doi: 10.1093/infdis/jiv389. PMID: 26265780.26265780
Lipshultz SE, Williams PL, Zeldow B, . Cardiac effects of in-utero exposure to antiretroviral therapy in HIV-uninfected children born to HIV-infected mothers. AIDS. 2015;29(1):91–100. doi: 10.1097/QAD.0000000000000499. PMID: 25562493.25562493
Lopez M, Figueras F, Hernandez S, . Association of HIV infection with spontaneous and iatrogenic preterm delivery: effect of HAART. AIDS. 2012;26(1):37–43. doi: 10.1097/QAD.0b013e32834db300. PMID: 22008651.22008651
Lu D, Liu J, Samson L, . Factors responsible for mother-to-child HIV transmission in Ontario, Canada, 1996-2008. Can J Public Health. 2014;105(1):e47–52. PMID: 24735697.24735697
Mandelbrot L, Tubiana R, Le Chenadec J, . No perinatal HIV-1 transmission from women with effective antiretroviral therapy starting before conception. Clin Infect Dis. 2015;61(11):1715–25. doi: 10.1093/cid/civ578. PMID: 26197844.26197844
Moodley T, Moodley D, Sebitloane M, . Improved pregnancy outcomes with increasing antiretroviral coverage in South Africa. BMC Pregnancy Childbirth. 2016;16:35. doi: 10.1186/s12884-016-0821-3. PMID: 26867536.26867536
Mor Z, Sheffer R, Chemtob D. Mother-to-child HIV transmissions in Israel, 1985-2011. Epidemiol Infect. 2017;145(9):1913–21. doi: 10.1017/s0950268817000577. PMID: 28374653.28374653
Nozyce ML, Huo Y, Williams PL, . Safety of in utero and neonatal antiretroviral exposure: cognitive and academic outcomes in HIV-exposed, uninfected children 5-13 years of age. Pediatr Infect Dis J. 2014;33(11):1128–33. doi: 10.1097/INF.0000000000000410. PMID: 25361407.25361407
Pintye J, Baeten JM, Celum C, . Maternal tenofovir disoproxil fumarate use during pregnancy is not associated with adverse perinatal outcomes among HIV-infected East African women: A prospective study. J Infect Dis. 2017;216(12):1561–8. doi: 10.1093/infdis/jix542. PMID: 29040666.29040666
Ramokolo V, Goga AE, Lombard C, . In utero ART exposure and birth and early growth outcomes among HIV-exposed uninfected infants attending immunization services: Results from National PMTCT Surveillance, South Africa. Open Forum Infect. 2017;4(4):ofx187. doi: 10.1093/ofid/ofx187. PMID: 29062860.29062860
Rough K, Seage GR, 3rd, Williams PL, . Birth outcomes for pregnant women with HIV using tenofovir-emtricitabine. N Engl J Med. 2018;378(17):1593–603. doi: 10.1056/NEJMoa1701666. PMID: 29694825.29694825
Sartorius BK, Chersich MF, Mwaura M, . Maternal anaemia and duration of zidovudine in antiretroviral regimens for preventing mother-to-child transmission: a randomized trial in three African countries. BMC Infect Dis. 2013;13:522. doi: 10.1186/1471-2334-13-522. PMID: 24192332.24192332
Short CE, Douglas M, Smith JH, . Preterm delivery risk in women initiating antiretroviral therapy to prevent HIV mother-to-child transmission. HIV Med. 2014;15(4):233–8. doi: 10.1111/hiv.12083. PMID: 24025074.24025074
Siberry GK, Williams PL, Mendez H, . Safety of tenofovir use during pregnancy: early growth outcomes in HIV-exposed uninfected infants. AIDS. 2012;26(9):1151–9. doi: 10.1097/QAD.0b013e328352d135. PMID: 22382151.22382151
Sibiude J, Le Chenadec J, Bonnet D, . In utero exposure to zidovudine and heart anomalies in the ANRS French perinatal cohort and the nested PRIMEVA randomized trial. Clin Infect Dis. 2015;61(2):270–80. doi: 10.1093/cid/civ260. PMID: 25838291.25838291
Sibiude J, Mandelbrot L, Blanche S, . Association between prenatal exposure to antiretroviral therapy and birth defects: an analysis of the French perinatal cohort study (ANRS CO1/CO11). PLoS Med. 2014;11(4):e1001635. doi: 10.1371/journal.pmed.1001635. PMID: 24781315.24781315
Sibiude J, Warszawski J, Tubiana R, . Premature delivery in HIV-infected women starting protease inhibitor therapy during pregnancy: role of the ritonavir boost? Clin Infect Dis. 2012;54(9):1348–60. doi: 10.1093/cid/cis198. PMID: 22460969.22460969
Snijdewind IJM, Smit C, Godfried MH, . Preconception use of cART by HIV-positive pregnant women increases the risk of infants being born small for gestational age. PLoS ONE. 2018;13(1):e0191389. doi: 10.1371/journal.pone.0191389. PMID: 29351561.29351561
Tookey PA, Thorne C, van Wyk J, . Maternal and foetal outcomes among 4118 women with HIV infection treated with lopinavir/ritonavir during pregnancy: analysis of population-based surveillance data from the national study of HIV in pregnancy and childhood in the United Kingdom and Ireland. BMC Infect Dis. 2016;16:65. doi: 10.1186/s12879-016-1400-y. PMID: 26847625.26847625
Watts DH, Williams PL, Kacanek D, . Combination antiretroviral use and preterm birth. J Infect Dis. 2013;207(4):612–21. doi: 10.1093/infdis/jis728. PMID: 23204173.23204173
Williams PL, Crain MJ, Yildirim C, . Congenital anomalies and in utero antiretroviral exposure in human immunodeficiency virus-exposed uninfected infants. JAMA Pediatr. 2015;169(1):48–55. doi: 10.1001/jamapediatrics.2014.1889. PMID: 25383770.25383770
Williams PL, Hazra R, Van Dyke RB, . Antiretroviral exposure during pregnancy and adverse outcomes in HIV-exposed uninfected infants and children using a trigger-based design. AIDS. 2016;30(1):133–44. doi: 10.1097/QAD.0000000000000916. PMID: 26731758.26731758
Zash R, Jacobson DL, Diseko M, . Comparative safety of antiretroviral treatment regimens in pregnancy. JAMA Pediatr. 2017;171(10):e172222. doi: 10.1001/jamapediatrics.2017.2222. PMID: 28783807.28783807
Zash R, Souda S, Chen JY, . Reassuring birth outcomes with tenofovir/emtricitabine/efavirenz used for prevention of mother-to-child transmission of HIV in Botswana. J Acquir Immune Defic Syndr. 2016;71(4):428–36. doi: 10.1097/QAI.0000000000000847. PMID: 26379069.26379069

## Appendix A5 Excluded Studies List

Abimpaye M, Kirk CM, Iyer HS, . The impact of “Option B” on HIV transmission from mother to child in Rwanda: An interrupted time series analysis. PLoS ONE. 2018;13(2):e0192910. doi: 10.1371/journal.pone.0192910. PMID: 29451925. Excluded: wrong population.29451925
Ajibola G, Zash R, Shapiro RL, . Detecting congenital malformations - Lessons learned from the Mpepu study, Botswana. PLoS One. 2017;12(3):e0173800. doi: 10.1371/journal.pone.0173800. PMID: 28339500. Excluded: did not adjust for confounders and/or did not provide adequate data.28339500
Ambia J, Mandala J. A systematic review of interventions to improve prevention of mother-to-child HIV transmission service delivery and promote retention. J Int AIDS Soc. 2016;19(1):20309. doi: 10.7448/IAS.19.1.20309. PMID: 27056361. Excluded: wrong outcome.27056361
Association of Women’s Health Obstetric Neonatal Nursing. HIV screening for pregnant women and infants. Nurs Womens Health. 2012 Feb-Mar;16(1):88–9. doi: 10.1111/j.1751-486X.2012.01711.x. PMID: 22900734. Excluded: wrong study design for Key Question.22900734
Awodele O, Popoola D, Odunsi P, . Assessing the risk of birth defects associated with exposure to highly active anti-retroviral therapy during organogenesis in rats. Tokai J Exp Clin Med. 2013 Jul;38(2):82–92. PMID: 23868740. Excluded: wrong population.23868740
Bera E, Mia R. Safety of nevirapine in HIV-infected pregnant women initiating antiretroviral therapy at higher CD4 counts: a systematic review and meta-analysis. S Afr Med J. 2012 Nov;102(11 Pt 1):855–9. doi: 10.7196/samj.5700. PMID: 23116743. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.23116743
Bisio F, Nicco E, Calzi A, . Pregnancy outcomes following exposure to efavirenz-based antiretroviral therapy in the Republic of Congo. New Microbiol. 2015 Apr;38(2):185–92. PMID: 25938743. Excluded: did not adjust for confounders and/or did not provide adequate data.25938743
Bispo S, Chikhungu L, Rollins N, . Postnatal HIV transmission in breastfed infants of HIV-infected women on ART: a systematic review and meta-analysis. J Int AIDS Soc. 2017 02 22;20(1):21251. doi: 10.7448/IAS.20.1.21251. PMID: 28362072. Excluded: wrong population.28362072
Bokharaei-Salim F, Kalantari S, Gholamypour Z, . Investigation of the effects of a prevention of mother-to-child HIV transmission program among Iranian neonates. Arch Virol. 2018 May;163(5):1179–85. doi: 10.1007/s00705-017-3661-1. PMID: 29383588. Excluded: did not adjust for confounders and/or did not provide adequate data.29383588
Bolduc P, Roder N, Colgate E, . Care of patients with HIV infection: diagnosis and monitoring. Fp Essent. 2016 Apr;443:11–5. PMID: 27092562. Excluded: not a study (letter, editorial, non-systematic review article, no original data).27092562
Browne JL, Schrier VJ, Grobbee DE, . HIV, antiretroviral therapy, and hypertensive disorders in pregnancy: a systematic review and meta-analysis. J Acquir Immune Defic Syndr. 2015 Sep 1;70(1):91–8. doi: 10.1097/QAI.0000000000000686. PMID: 26322669. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.26322669
Bunupuradah T, Phupitakphol T, Sophonphan J, . Prevalence of persistent renal dysfunction in perinatally HIV-infected Thai adolescents. Pediatr Infect Dis J. 2018 Jan;37(1):66–70. doi: 10.1097/INF.0000000000001684. PMID: 28719505. Excluded: wrong population.28719505
Caniglia EC, Zash R, Jacobson DL, . Emulating a target trial of antiretroviral therapy regimens started before conception and risk of adverse birth outcomes. AIDS. 2018 Jan 02;32(1):113–20. doi: 10.1097/QAD.0000000000001673. PMID: 29112066. Excluded: wrong population.29112066
Cecchini DM, Martinez MG, Morganti LM, . Antiretroviral therapy containing raltegravir to prevent mother-to-child transmission of HIV in infected pregnant women. Infect Dis Rep. 2017 May 31;9(2):7017. doi: 10.4081/idr.2017.7017. PMID: 28663779. Excluded: did not adjust for confounders and/or did not provide adequate data.28663779
Centers for Disease Control and Prevention. HIV/AIDS HIV among pregnant women, infants, and children. 2016. http://www.cdc.gov/hiv/group/gender/pregnantwomen/index.html. Accessed October 28, 2016. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Cha S, Malik T, Abara WE, . Screening for syphilis and other sexually transmitted infections in pregnant women - Guam, 2014. MMWR Morb Mortal Wkly Rep. 2017 Jun 23;66(24):644–8. doi: 10.15585/mmwr.mm6624a4. PMID: 28640799. Excluded: wrong outcome.28640799
Chaiyachati KH, Ogbuoji O, Price M, . Interventions to improve adherence to antiretroviral therapy: a rapid systematic review. AIDS. 2014 Mar;28: Suppl 2:S187–204. doi: 10.1097/QAD.0000000000000252. PMID: 24849479. Excluded: wrong outcome.24849479
Chaudhury S, Williams PL, Mayondi GK, . Neurodevelopment of HIV-exposed and HIV-unexposed uninfected children at 24 months. Pediatrics. 2017 Oct;140(4)doi: 10.1542/peds.2017-0988. PMID: 28912368. Excluded: wrong comparator.28912368
Colbers AP, Hawkins DA, Gingelmaier A, . The pharmacokinetics, safety and efficacy of tenofovir and emtricitabine in HIV-1-infected pregnant women. AIDS. 2013 Mar 13;27(5):739–48. doi: 10.1097/QAD.0b013e32835c208b. PMID: 23169329. Excluded: sample size too small.23169329
Coovadia HM, Brown ER, Fowler MG, . Efficacy and safety of an extended nevirapine regimen in infant children of breastfeeding mothers with HIV-1 infection for prevention of postnatal HIV-1 transmission (HPTN 046): a randomised, double-blind, placebo-controlled trial. Lancet. 2012 Jan 21;379(9812):221–8. doi: 10.1016/S0140-6736(11)61653-X. PMID: 22196945. Excluded: wrong population.22196945
Currier J, . Randomized trial of stopping or continuing ART among postpartum women with pre-ART CD4 ≥400 cells/mm^3 (PROMISE 1077HS). 21st International AIDS Conference (AIDS 2016). 2016. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
da Silva KM, de Sa CD, Carvalho R. Evaluation of motor and cognitive development among infants exposed to HIV. Early Hum Dev. 2017 Feb;105:7–10. doi: 10.1016/j.earlhumdev.2016.12.013. PMID: 28088692. Excluded: wrong comparator.28088692
d’Arminio Monforte A, Galli L, Lo Caputo S, . Pregnancy outcomes among ART-naive and ART-experienced HIV-positive women: data from the ICONA foundation study group, years 1997-2013. J Acquir Immune Defic Syndr. 2014 Nov 1;67(3):258–67. doi: 10.1097/QAI.0000000000000297. PMID: 25314248. Excluded: wrong outcome.25314248
Davis NL, Miller WC, Hudgens MG, . Adherence to extended postpartum antiretrovirals is associated with decreased breast milk HIV-1 transmission. AIDS. 2014 Nov 28;28(18):2739–49. doi: 10.1097/QAD.0000000000000492. PMID: 25493600. Excluded: wrong intervention.25493600
Decker S, Rempis E, Schnack A, . Prevention of mother-to-child transmission of HIV: Postpartum adherence to Option B+ until 18 months in Western Uganda. PLoS One. 2017;12(6):e0179448. doi: 10.1371/journal.pone.0179448. PMID: 28662036. Excluded: wrong outcome.28662036
Del Bianco G, Bell CS, Benjamins LJ, . Persistently high perinatal transmission of HIV: assessment of risk factors. Pediatr Infect Dis J. 2014 Jun;33(6):e151–7. doi: 10.1097/INF.0000000000000199. PMID: 24836756. Excluded: did not adjust for confounders and/or did not provide adequate data.24836756
Dinh TH, Delaney KP, Goga A, . Impact of maternal HIV seroconversion during pregnancy on early mother to child transmission of HIV (MTCT) measured at 4-8 weeks postpartum in South Africa 2011-2012: A national population-based evaluation. PLoS One. 2015;10(5):e0125525. doi: 10.1371/journal.pone.0125525. PMID: 25942423. Excluded: wrong country.25942423
Domingues R, Saraceni V, Leal MDC. Mother to child transmission of HIV in Brazil: Data from the “Birth in Brazil study”, a national hospital-based study. PLoS ONE. 2018;13(2):e0192985. doi: 10.1371/journal.pone.0192985. PMID: 29438439. Excluded: wrong country.29438439
Downie J, Mactier H, Bland RM. Should pregnant women with unknown HIV status be offered rapid HIV testing in labour? Arch Dis Child Fetal Neonatal Ed. 2016 Jan;101(1):F79–84. doi: 10.1136/archdischild-2014-307226. PMID: 26668051. Excluded: wrong intervention.26668051
Drake AL, Wagner A, Richardson B, . Incident HIV during pregnancy and postpartum and risk of mother-to-child HIV transmission: a systematic review and meta-analysis. PLoS Med. 2014 Feb;11(2):e1001608. doi: 10.1371/journal.pmed.1001608. PMID: 24586123. Excluded: wrong study design for Key Question.24586123
Eleje GU, Edokwe ES, Ikechebelu JI, . Mother-to-child transmission of human immunodeficiency virus (HIV) among HIV-infected pregnant women on highly active anti-retroviral therapy with premature rupture of membranes at term. J Matern Fetal Neonatal Med. 2018 Jan;31(2):184–90. doi: 10.1080/14767058.2017.1279600. PMID: 28064549. Excluded: wrong population.28064549
Faghih S, Secord E. Increased adolescent HIV infection during pregnancy leads to increase in perinatal transmission at urban referral center. J Int Assoc Physicians AIDS Care (Chic). 2012 Sep-Oct;11(5):293–5. doi: 10.1177/1545109712446175. PMID: 22628370. Excluded: wrong study design for Key Question.22628370
Fitz Harris LF, Taylor AW, Zhang F, . Factors associated with human immunodeficiency virus screening of women during pregnancy, labor and delivery, United States, 2005-2006. Matern Child Health J. 2014 Apr;18(3):648–56. doi: 10.1007/s10995-013-1289-7. PMID: 23836013. Excluded: wrong outcome.23836013
Frederick T, Homans J, Spencer L, . The effect of prenatal highly active antiretroviral therapy on the transmission of congenital and perinatal/early postnatal cytomegalovirus among HIV-infected and HIV-exposed infants. Clin Infect Dis. 2012 Sep;55(6):877–84. doi: 10.1093/cid/cis535. PMID: 22675157. Excluded: wrong study design for Key Question.22675157
Gertsch A, Michel O, Locatelli I, . Adherence to antiretroviral treatment decreases during postpartum compared to pregnancy: a longitudinal electronic monitoring study. Aids Patient Care STDS. 2013 Apr;27(4):208–10. doi: 10.1089/apc.2013.0005. PMID: 23506310. Excluded: wrong outcome.23506310
Gibb DM, Kizito H, Russell EC, . Pregnancy and infant outcomes among HIV-infected women taking long-term ART with and without tenofovir in the DART trial. PLoS Med. 2012;9(5):e1001217. doi: 10.1371/journal.pmed.1001217. PMID: 22615543. Excluded: wrong country.22615543
Gill MM, Hoffman HJ, Ndatimana D, . 24-month HIV-free survival among infants born to HIV-positive women enrolled in Option B+ program in Kigali, Rwanda: The Kabeho Study. Medicine (Baltimore). 2017 Dec;96(51):e9445. doi: 10.1097/MD.0000000000009445. PMID: 29390577. Excluded: wrong population.29390577
Gonzalez R, Ruperez M, Sevene E, . Effects of HIV infection on maternal and neonatal health in southern Mozambique: A prospective cohort study after a decade of antiretroviral drugs roll out. PLoS One. 2017;12(6):e0178134. doi: 10.1371/journal.pone.0178134. PMID: 28575010. Excluded: wrong comparator.28575010
Harmsen MJ, Browne JL, Venter F, . The association between HIV (treatment), pregnancy serum lipid concentrations and pregnancy outcomes: a systematic review. BMC Infect Dis. 2017 Jul 11;17(1):489. doi: 10.1186/s12879-017-2581-8. PMID: 28697741. Excluded: wrong outcome.28697741
Heemelaar S, Habets N, Makukula Z, . Repeat HIV testing during pregnancy and delivery: missed opportunities in a rural district hospital in Zambia. Trop Med Int Health. 2015 Mar;20(3):277–83. doi: 10.1111/tmi.12432. PMID: 25418130. Excluded: did not adjust for confounders and/or did not provide adequate data.25418130
Hernandez S, Catalan-Garcia M, Moren C, . Placental mitochondrial toxicity, oxidative stress, apoptosis, and adverse perinatal outcomes in HIV pregnancies under antiretroviral treatment containing zidovudine. J Acquir Immune Defic Syndr. 2017 Aug 01;75(4):e113–e9. doi: 10.1097/QAI.0000000000001334. PMID: 28234688. Excluded: wrong comparator.28234688
Huang X, Xu Y, Yang Q, . Efficacy and biological safety of lopinavir/ritonavir based anti-retroviral therapy in HIV-1-infected patients: a meta-analysis of randomized controlled trials. Sci Rep. 2015;5 PMID: 25704206. Excluded: wrong study design for Key Question.25704206
Inzaule SC, Osi SJ, Akinbiyi G, . High prevalence of HIV drug resistance among newly diagnosed infants aged <18 months: results from a nationwide surveillance in Nigeria. J Acquir Immune Defic Syndr. 2018 01 01;77(1):e1–e7. doi: 10.1097/QAI.0000000000001553. PMID: 28961680. Excluded: wrong outcome.28961680
Jao J, Abrams EJ. Metabolic complications of in utero maternal HIV and antiretroviral exposure in HIV-exposed infants. Pediatr Infect Dis J. 2014 Jul;33(7):734–40. doi: 10.1097/INF.0000000000000224. PMID: 24378947. Excluded: wrong study design for Key Question.24378947
Johnson M, Afonina L, Haanyama O. The challenges of testing for HIV in women: experience from the UK and other European countries. Antivir Ther. 2013;18: Suppl 2:19–25. doi: 10.3851/IMP2637. PMID: 23784671. Excluded: not a study (letter, editorial, non-systematic review article, no original data).23784671
Kakkar FW, Samson L, Vaudry W, . Safety of combination antiretroviral prophylaxis in high-risk HIV-exposed newborns: a retrospective review of the Canadian experience. J Int AIDS Soc. 2016;19(1):20520. doi: 10.7448/IAS.19.1.20520. PMID: 26880241. Excluded: wrong population.26880241
Kim LH, Cohan DL, Sparks TN, . The cost-effectiveness of repeat HIV testing during pregnancy in a resource-limited setting. JAIDS. 2013 Jun 1;63(2):195–200. doi: 10.1097/QAI.0b013e3182895565. PMID: 23392461. Excluded: wrong country.23392461
Koss CA, Natureeba P, Plenty A, . Risk factors for preterm birth among HIV-infected pregnant Ugandan women randomized to lopinavir/ritonavir- or efavirenz-based antiretroviral therapy. J Acquir Immune Defic Syndr. 2014 Oct 01;67(2):128–35. doi: 10.1097/qai.0000000000000281. PMID: 25072616. Excluded: did not adjust for confounders and/or did not provide adequate data.25072616
Lassi ZS, Imam AM, Dean SV, . Preconception care: preventing and treating infections. Reprod Health. 2014 Sep 26;11 Suppl 3:S4. doi: 10.1186/1742-4755-11-S3-S4. PMID: 25415557. Excluded: wrong outcome.25415557
le Roux SM, Jao J, Brittain K, . Tenofovir exposure in utero and linear growth in HIV-exposed, uninfected infants. AIDS. 2017 Jan 02;31(1):97–104. doi: 10.1097/QAD.0000000000001302. PMID: 27898591. Excluded: wrong outcome.27898591
Liao C, Golden WC, Anderson JR, . Missed opportunities for repeat HIV testing in pregnancy: Implications for elimination of mother-to-child transmission in the United States. Aids Patient Care STDS. 2017 Jan;31(1):20–6. doi: 10.1089/apc.2016.0204. PMID: 27936863. Excluded: wrong study design for Key Question.27936863
Lin AW, Wong KH, Chan K, . Accelerating prevention of mother-to-child transmission of HIV: ten-year experience of universal antenatal HIV testing programme in a low HIV prevalence setting in Hong Kong. AIDS Care. 2014 Feb;26(2):169–75. doi: 10.1080/09540121.2013.819402. PMID: 23869699. Excluded: wrong outcome.23869699
Liotta G, Mancinelli S, Nielsen-Saines K, . Reduction of maternal mortality with highly active antiretroviral therapy in a large cohort of HIV-infected pregnant women in Malawi and Mozambique. PLoS One. 2013;8(8):e71653. doi: 10.1371/journal.pone.0071653. PMID: 23990966. Excluded: wrong comparator.23990966
Little KM, Taylor AW, Borkowf CB, . Perinatal antiretroviral exposure and prevented mother-to-child HIV infections in the era of antiretroviral prophylaxis in the United States, 1994-2010. Pediatr Infect Dis J. 2017 Jan;36(1):66–71. doi: 10.1097/INF.0000000000001355. PMID: 27749662. Excluded: wrong study design for Key Question.27749662
Liu KC, Chibwesha CJ. Intrapartum management for prevention of mother-to-child transmission of HIV in resource-limited settings: a review of the literature. Afr J Reprod Health. 2013 Dec;17(4 Spec No):107–17. PMID: 24689322. Excluded: not a study (letter, editorial, non-systematic review article, no original data).24689322
Malaba TR, Phillips T, Le Roux S, . Antiretroviral therapy use during pregnancy and adverse birth outcomes in South African women. Int J Epidemiol. 2017 Oct 01;46(5):1678–89. doi: 10.1093/ije/dyx136. PMID: 29040569. Excluded: wrong comparator.29040569
Mesfin YM, Kibret KT, Taye A. Is protease inhibitors based antiretroviral therapy during pregnancy associated with an increased risk of preterm birth? Systematic review and a meta-analysis. Reprod Health. 2016 Apr 5;13:30. doi: 10.1186/s12978-016-0149-5. PMID: 27048501. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.27048501
Minniear TD, Girde S, Angira F, . Outcomes in a cohort of women who discontinued maternal triple-antiretroviral regimens initially used to prevent mother-to-child transmission during pregnancy and breastfeeding-Kenya, 2003-2009. PLoS One. 2014;9(4):e93556. doi: 10.1371/journal.pone.0093556. PMID: 24733021. Excluded: wrong study design for Key Question.24733021
Moodley D, Esterhuizen TM, Pather T, . High HIV incidence during pregnancy: compelling reason for repeat HIV testing. AIDS. 2009 Jun 19;23(10):1255–9. doi: 10.1097/QAD.0b013e32832a5934. PMID: 19455017. Excluded: wrong country.19455017
Mora S, Diceglie C, Vigano A, . Antiretroviral therapy and pregnancy: effect on cortical bone status of human immunodeficiency virus-infected Caucasian women as assessed by quantitative ultrasonography. Calcif Tissue Int. 2013 Apr;92(4):394–8. doi: 10.1007/s00223-013-9696-8. PMID: 23307187. Excluded: wrong comparator.23307187
Mora S, Giacomet V, Vigano A, . Exposure to antiretroviral agents during pregnancy does not alter bone status in infants. Bone. 2012 Jan;50(1):255–8. doi: 10.1016/j.bone.2011.10.030. PMID: 22080170. Excluded: wrong comparator.22080170
Myer L, Zulliger R, Bekker LG, . Systemic delays in the initiation of antiretroviral therapy during pregnancy do not improve outcomes of HIV-positive mothers: a cohort study. BMC Pregnancy Childbirth. 2012;12:94. doi: 10.1186/1471-2393-12-94. PMID: 22963318. Excluded: wrong country.22963318
Nachega JB, Uthman OA, Mofenson LM, . Safety of tenofovir disoproxil fumarate-based antiretroviral therapy regimens in pregnancy for HIV-infected women and their Infants: a systematic review and meta-analysis. J Acquir Immune Defic Syndr. 2017 Sep 01;76(1):1–12. doi: 10.1097/QAI.0000000000001359. PMID: 28291053. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.28291053
Nesheim SR, Wiener J, Fitz Harris LF, . Brief report: estimated incidence of perinatally acquired HIV infection in the United States, 1978-2013. J Acquir Immune Defic Syndr. 2017 Dec 15;76(5):461–4. doi: 10.1097/QAI.0000000000001552. PMID: 28991886. Excluded: wrong study design for Key Question.28991886
Ngoma MS, Hunter JA, Harper JA, . Cognitive and language outcomes in HIV-uninfected infants exposed to combined antiretroviral therapy in utero and through extended breast-feeding. AIDS. 2014 Jul;28: Suppl 3:S323–30. doi: 10.1097/QAD.0000000000000357. PMID: 24991905. Excluded: wrong intervention.24991905
Nielsen-Saines K, Watts DH, Veloso VG, . Three postpartum antiretroviral regimens to prevent intrapartum HIV infection. N Engl J Med. 2012;366(25):2368–79. PMID: 22716975. Excluded: wrong intervention.22716975
Parekh N, Ribaudo H, Souda S, . Risk factors for very preterm delivery and delivery of very-small-for-gestational-age infants among HIV-exposed and HIV-unexposed infants in Botswana. Int J Gynaecol Obstet. 2011 Oct;115(1):20–5. doi: 10.1016/j.ijgo.2011.04.008. PMID: 21767835. Excluded: not a study (letter, editorial, non-systematic review article, no original data).21767835
Patel K, Van Dyke RB, Mittleman MA, . The impact of HAART on cardiomyopathy among children and adolescents perinatally infected with HIV-1. AIDS. 2012 Oct 23;26(16):2027–37. doi: 10.1097/QAD.0b013e3283578bfa. PMID: 22781228. Excluded: wrong intervention.22781228
Perry ME, Taylor GP, Sabin CA, . Lopinavir and atazanavir in pregnancy: comparable infant outcomes, virological efficacies and preterm delivery rates. HIV Med. 2016 Jan;17(1):28–35. doi: 10.1111/hiv.12277. PMID: 26200570. Excluded: did not adjust for confounders and/or did not provide adequate data.26200570
Poliquin V, Yudin MH, Murphy KE, . Antepartum screening for maternal infection and immune status: is it time to broaden our routine? J Obstet Gynaecol Can. 2015 Dec;37(12):1118–21. PMID: 26637086. Excluded: not a study (letter, editorial, non-systematic review article, no original data).26637086
Prieto LM, Fernandez McPhee C, Rojas P, . Pregnancy outcomes in perinatally HIV-infected young women in Madrid, Spain: 2000-2015. PLoS One. 2017;12(8):e0183558. doi: 10.1371/journal.pone.0183558. PMID: 28841701. Excluded: wrong population.28841701
Prosperi MC, Fabbiani M, Fanti I, . Predictors of first-line antiretroviral therapy discontinuation due to drug-related adverse events in HIV-infected patients: a retrospective cohort study. BMC Infect Dis. 2012;12:296. doi: 10.1186/1471-2334-12-296. PMID: 23145925. Excluded: wrong outcome.23145925
Radon-Pokracka M, Piasecki M, Lachowska A, . Assessment of the implementation of the infectious diseases screening programmes among pregnant women in the Lesser Poland region and comparison with similar programmes conducted in other European Union countries. Ginekol Pol. 2017;88(3):151–5. doi: 10.5603/GP.a2017.0029. PMID: 28397205. Excluded: wrong outcome.28397205
Raffe SF, Savage C, Perry LA, . The management of HIV in pregnancy: A 10-year experience. Eur J Obstet Gynecol Reprod Biol. 2017 Mar;210:310–3. doi: 10.1016/j.ejogrb.2016.12.021. PMID: 28110176. Excluded: did not adjust for confounders and/or did not provide adequate data.28110176
Ransom CE, Huo Y, Patel K, . Infant growth outcomes after maternal tenofovir disoproxil fumarate use during pregnancy. J Acquir Immune Defic Syndr. 2013 Dec 1;64(4):374–81. doi: 10.1097/QAI.0b013e3182a7adb2. PMID: 24169122. Excluded: wrong outcome.24169122
Rawizza H. Triple-drug antiretroviral therapy results in lower HIV maternal-fetal transmission rates but increased adverse effects compared with zidovudine alone. J Pediatr. 2017 Mar;182:401–4. doi: 10.1016/j.jpeds.2016.12.068. PMID: 28237453. Excluded: did not adjust for confounders and/or did not provide adequate data.28237453
Regan S, Losina E, Chetty S, . Factors associated with self-reported repeat HIV testing after a negative result in Durban, South Africa. PLoS One. 2013;8(4):e62362. doi: 10.1371/journal.pone.0062362. PMID: 23626808. Excluded: wrong population.23626808
Rough K, Sun JW, Seage GR, 3rd, . Zidovudine use in pregnancy and congenital malformations. AIDS. 2017 Jul 31;31(12):1733–43. doi: 10.1097/QAD.0000000000001549. PMID: 28537936. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.28537936
Scott RK, Chakhtoura N, Burke MM, . Delivery after 40 weeks of gestation in pregnant women with well-controlled human immunodeficiency virus. Obstet Gynecol. 2017 Sep;130(3):502–10. doi: 10.1097/AOG.0000000000002186. PMID: 28796679. Excluded: did not adjust for confounders and/or did not provide adequate data.28796679
Siemieniuk RAC, Lytvyn L, Mah Ming J, . Antiretroviral therapy in pregnant women living with HIV: a clinical practice guideline. BMJ. 2017 09 11;358:j3961. doi: 10.1136/bmj.j3961. PMID: 28893728. Excluded: not a study (letter, editorial, non-systematic review article, no original data).28893728
Sirois PA, Huo Y, Williams PL, . Safety of perinatal exposure to antiretroviral medications: developmental outcomes in infants. Pediatr Infect Dis J. 2013 Jun;32(6):648–55. doi: 10.1097/INF.0b013e318284129a. PMID: 23340561. Excluded: inadequate duration.23340561
Smith C, Forster JE, Levin MJ, . Serious adverse events are uncommon with combination neonatal antiretroviral prophylaxis: a retrospective case review. PLoS One. 2015;10(5):e0127062. doi: 10.1371/journal.pone.0127062. PMID: 26000984. Excluded: wrong population.26000984
Taron-Brocard C, Le Chenadec J, Faye A, . Increased risk of serious bacterial infections due to maternal immunosuppression in HIV-exposed uninfected infants in a European country. Clin Infect Dis. 2014 Nov 1;59(9):1332–45. doi: 10.1093/cid/ciu586. PMID: 25053719. Excluded: wrong outcome.25053719
Thorne C, Semenenko I, Malyuta R, . Prevention of mother-to-child transmission of human immunodeficiency virus among pregnant women using injecting drugs in Ukraine, 2000-10. Addiction. 2012 Jan;107(1):118–28. doi: 10.1111/j.1360-0443.2011.03609.x. PMID: 21819473. Excluded: did not adjust for confounders and/or did not provide adequate data.21819473
Tricco AC, Antony J, Angeliki VA, . Safety and effectiveness of antiretroviral therapies for HIV-infected women and their infants and children: protocol for a systematic review and network meta-analysis. Syst Rev. 2014;3:51. doi: 10.1186/2046-4053-3-51. PMID: 24887455. Excluded: not a study (letter, editorial, non-systematic review article, no original data).24887455
Uthman OA, Nachega JB, Anderson J, . Timing of initiation of antiretroviral therapy and adverse pregnancy outcomes: a systematic review and meta-analysis. Lancet HIV. 2017 Jan;4(1):e21–e30. doi: 10.1016/S2352-3018(16)30195-3. PMID: 27864000. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.27864000
Van Dyke RB, Chadwick EG, Hazra R, . The PHACS SMARTT study: Assessment of the safety of in utero exposure to antiretroviral drugs. Front Immunol. 2016;7:199. doi: 10.3389/fimmu.2016.00199. PMID: 27242802. Excluded: did not adjust for confounders and/or did not provide adequate data.27242802
Vannappagari V, Koram N, Albano J, . Abacavir and lamivudine exposures during pregnancy and non-defect adverse pregnancy outcomes: data from the antiretroviral pregnancy registry. J Acquir Immune Defic Syndr. 2015 Mar 1;68(3):359–64. doi: 10.1097/QAI.0000000000000465. PMID: 25469525. Excluded: did not adjust for confounders and/or did not provide adequate data.25469525
Villatoro CM, Luarte ME, Natareno GV, . Highly active antiretroviral treatment (HAART) for the prevention of HIV mother to child transmission (PMTCT) at Roosevelt Hospital’s Infectious Diseases Clinic in Guatemala: the role of (LPV/r) standard dose. World J AIDS. 2012;2(03):259. Excluded: did not adjust for confounders and/or did not provide adequate data.
Whitehead N, Potterton J, Coovadia A. The neurodevelopment of HIV-infected infants on HAART compared to HIV-exposed but uninfected infants. AIDS Care. 2014 Apr;26(4):497–504. doi: 10.1080/09540121.2013.841828. PMID: 24125015. Excluded: wrong population.24125015
Williams B, Costello M, McHugh E, . Repeat antenatal HIV testing in the third trimester: a study of feasibility and maternal uptake rates. HIV Med. 2014 Jul;15(6):362–6. doi: 10.1111/hiv.12110. PMID: 24215444. Excluded: wrong study design for Key Question.24215444

## Appendix A6 Criteria for Assessing Internal Validity of Individual Studies

### Systematic Reviews

Criteria:

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

Definition of ratings based on above criteria:

- Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions
- Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies
- Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

### Case-Control Studies

Criteria:

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls, with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

Definition of ratings based on above criteria:

- Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; accurate diagnostic procedures and measurements applied equally to cases and controls; and appropriate attention to confounding variables
- Fair: Recent, relevant, and without major apparent selection or diagnostic workup bias, but response rate less than 80 percent or attention to some but not all important confounding variables
- Poor: Major selection or diagnostic workup bias, response rate less than 50 percent, or inattention to confounding variables

### RCTs and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  ○ For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Definition of ratings based on above criteria:

- Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
- Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
- Poor: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of ratings based on above criteria:

- Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease
- Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients
- Poor: Has a fatal flaw, such as: Uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

Source: U.S. Preventive Services Task Force Procedure Manual. Accessed at https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes

## Appendix A7 Expert Reviewers of the Draft Report

❖ Maggie Czarnogorski, MD, MPH, Deputy Director, Comprehensive Women’s Health, U.S. Department of Veterans Affairs
❖ Brenna Hughes, MD, MSc, Division of Maternal Fetal Medicine, Duke University
❖ Margaret Lampe, RN, MPH, Centers for Disease Control and Prevention
❖ Lynne Mofenson, MD, Elizabeth Glaser Pediatric AIDS Foundation
❖ Brandy Peaker, MD, MPH, Centers for Disease Control and Prevention
❖ George Siberry, MD, Pediatric Technical Advisor for the U.S. President’s Emergency Plan for AIDS Relief, State Department

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the report findings.