# References

1 Chou R, Selph S, Dana T, . Screening for HIV: systematic review to update the U.S. Preventive Services Task Force recommendation. Evidence synthesis No. 95. AHRQ publication No. 12-05173-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; November 2012.
2 Chou R, Shelley S, Dana T, . Screening for HIV: Systematic review to update the 2005 U.S. Preventive Services Task Force recommendation. Ann Intern Med. 2012;157:706–18. PMID: 23165662.23165662
3 Moyer VA, on behalf of the U.S. Preventive Services Task Force. Screening for HIV: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2013;159(1):51–60. doi: 10.7326/0003-4819-159-1-201307020-00645. PMID: 23698354.23698354
4 Selph SS, Bougatsos C, Dana T, Grusing S, Chou R. Screening for HIV Infection in Pregnant Women: A Systematic Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 177. AHRQ Publication No. 18-05246-EF-2. Rockville, MD: Agency for Healthcare Research and Quality; 2019.
5 US Preventive Services Task Force. Screening for HIV: Recommendation statement. Ann Intern Med. 2005 Jul 5;143(1):32–7. PMID: 15998753.15998753
6 Sanders GD, Bayoumi AM, Holodniy M, . Cost-effectiveness of HIV screening in patients older than 55 years of age. Ann Intern Med. 2008 Jun 17;148(12):889–903. PMID: 18559840.18559840
7 Paltiel AD, Walensky RP, Schackman BR, . Expanded HIV screening in the United States: effect on clinical outcomes, HIV transmission, and costs.. Ann Intern Med. 2006 Dec 5;145(11):797–806. PMID: 17146064.17146064
8 Centers for Disease Control and Prevention. 1993 Revised classification system for HIV infection and expanded surveillance case definition for AIDS among adolescents and adults. MMWR Recomm Rep. 1992 December 18;41(RR-17). PMID: 1361652.1361652
9 Centers for Disease Control and Prevention. HIV-2 surveillance- United States, 1987-2009. 2011. www.cdc.gov/mmwr/preview/mmwrhtml/mm6029a3.htm. Accessed October 31, 2016.
10 Centers for Disease Control and Prevention. HIV Surveillance Report. Volume 28. Diagnoses of HIV Infection in the United States and Dependent Areas, 2016. 2016. www.cdc.gov/hiv/pdf/library/reports/surveillance/cdc-hiv-surveillance-report-2016-vol-28.pdf. Accessed December 8, 2017.
11 Centers for Disease Control and Prevention. HIV Surveillance Report - Diagnoses of HIV Infection in the United States and Dependent Areas, 2017. 2017. https://www.cdc.gov/hiv/pdf/library/reports/surveillance/cdc-hiv-surveillance-report-2017-vol-29.pdf. Accessed January 31, 2019.
12 Dailey AF, Hoots BE, Hall HI, . Vital signs: Human immunodeficiency virus testing and diagnosis delays - United States. MMWR. 2017 Dec 1;66(47):1300–6. doi: 10.15585/mmwr.mm6647e1. PMID: 29190267.29190267
13 Centers for Disease Control and Prevention. HIV in the United States. 2011. www.cdc.gov/hiv/resources/factsheets/us.htm. Accessed October 31, 2016.
14 Centers for Disease Control and Prevention. HIV surveillance - United States, 1981-2008. MMWR. 2011;60(21):689–93. PMID: 21637182.21637182
15 Campsmith ML, Rhodes PH, Hall I, . Undiagnosed HIV prevalence among adults and adolescents in the United States at the end of 2006. J Acquir Immune Defic Syndr. 2010;53:619–24. PMID: 1983812419838124
16 Satcher Johnson A, Song R, Hall HI. Estimated HIV incidence, prevalence, and undiagnosed infections in US states and Washington, DC, 2010-2014. J Acquir Immune Defic Syndr. 2017 Oct 1;76(2):116–22. doi: 10.1097/qai.0000000000001495. PMID: 28700407.28700407
17 Prejean J, Song R, Hernandez A, . Estimated HIV incidence in the United States, 2006–2009. PLoS One. 2011 Aug 3;6(8):e17502. doi:10.1371/journal.pone.0017502. PMID: 21826193.21826193
18 Quinn TC, Wawer MJ, Sewankambo NK, . Viral load and heterosexual transmission of human immunodeficiency virus type 1. N Engl J Med. 2000;342(13):921–9. PMID: 10738050.10738050
19 Gray RH, Wawer MJ, Brookmeyer R, . Probability of HIV-1 transmission per coital act in monogamous, heterosexual, HIV-1-discordant couples in Rakai, Uganda. Lancet. 2001;357(9263):1149–53. doi: 10.1016/s0140-6736(00)04331-2. PMID: 11323041.11323041
20 Doherty MC, Garfein RS, Monterroso E, . Correlates of HIV infection among young adult short-term injection drug users. AIDS. 2000 Apr 14;14(6):717–26. PMID: 10807195.10807195
21 Kahn JO, Walker BD. Acute human immunodeficiency virus type 1 infection. N Engl J Med. 1998;339(1):33–9. doi: 10.1056/NEJM199807023390107. PMID: 9647878.9647878
22 Schacker T, Collier AC, Hughes J, . Clinical and epidemiologic features of primary HIV infection. Ann Intern Med. 1996 Aug 15;125(4):257–64. PMID: 8678387.8678387
23 Vanhems P, Allard R, Cooper DA, . Acute human immunodeficiency virus type 1 disease as a mononucleosis-like illness: is the diagnosis too restrictive? Clin Infect Dis. 1997;24(5):965–70. doi: 10.1093/clinids/24.5.965. PMID: 9142802.9142802
24 Daar ES, Moudgil T, Meyer RD, . Transient high levels of viremia in patients with primary human immunodeficiency virus type 1 infection. N Engl J Med. 1991;324(14):961–4. doi: 10.1056/NEJM199104043241405. PMID: 1823118.1823118
25 Henrard DR, Phillips JF, Muenz LR, . Natural history of HIV-1 cell-free viremia. JAMA. 1995 Aug 16;274(7):554–8. PMID: 7629984.7629984
26 Ho DD, Neumann AU, Perelson AS, . Rapid turnover of plasma virions and CD4 lymphocytes in HIV-1 infection. Nature. 1995 Jan 12;373(6510):123–6. doi: 10.1038/373123a0. PMID: 7816094.7816094
27 Schacker TW, Hughes JP, Shea T, . Biological and virologic characteristics of primary HIV infection. Ann Intern Med. 1998 Apr 15;128(8):613–20. PMID: 9537934.9537934
28 Touloumi G, Pantazis N, Babiker AG, . Differences in HIV RNA levels before the initiation of antiretroviral therapy among 1864 individuals with known HIV-1 seroconversion dates. AIDS. 2004 Aug 20;18(12):1697–705. PMID: 15280781.15280781
29 Wei X, Ghosh SK, Taylor ME, . Viral dynamics in human immunodeficiency virus type 1 infection. Nature. 1995 Jan 12;373(6510):117–22. doi: 10.1038/373117a0. PMID: 7529365.7529365
30 Collaborative Group on AIDS Incubation and HIV Survival including the CASCADE EU Concerted Action. Time from HIV-1 seroconversion to AIDS and death before widespread use of highly-active antiretroviral therapy: a collaborative re-analysis. Lancet. 2000 Apr 1;355(9210):1131–7. PMID: 10791375.10791375
31 Koblin B, van Benthem B, Buchbinder S, . Long-term survival after infection with human immunodeficiency virus type 1 (HIV-1) among homosexual hen in hepatitis B vaccine trial cohorts in Amsterdam, New York City, and San Francisco, 1978–1995. Am J Epidemiol. 1999 November 15, 1999;150(10):1026–30. PMID: 10568617.10568617
32 Stein DS, Korvick JA, Vermund SH. CD4+ lymphocyte cell enumeration for prediction of clinical course of human immunodeficiency virus disease: a review. J Infect Dis. 1992 Feb;165(2):352–63. PMID: 1346152.1346152
33 Kaslow RA, Phair JP, Friedman HB, . Infection with the human immunodeficiency virus: clinical manifestations and their relationship to immune deficiency. A report from the Multicenter AIDS Cohort Study. Ann Intern Med. 1987 Oct;107(4):474–80. PMID: 2957944.2957944
34 Phillips A, Gazzard B, Gilson R, . Rate of AIDS diseases or death in HIV-infected antiretroviral therapy-naive individuals with high CD4 cell count. AIDS. 2007;21(13):1717–21. PMID: 17690569.17690569
35 Egger M, May M, Chene G, . Prognosis of HIV-1-infected patients starting highly active antiretroviral therapy: a collaborative analysis of prospective studies. Lancet. 2002 Jul 13;360(9327):119–29. PMID: 12126821.12126821
36 Phillips A, Pezzotti P. Short-term risk of AIDS according to current CD4 cell count and viral load in antiretroviral drug-naive individuals and those treated in the monotherapy era. AIDS. 2004 Jan 2;18(1):51–8. PMID: 15090829.15090829
37 Phillips AN, Lee CA, Elford J, . Serial CD4 lymphocyte counts and development of AIDS. Lancet. 1991 Feb 16;337(8738):389–92. PMID: 1671424.1671424
38 Mellors JW, Kingsley LA, Rinaldo CR, Jr., . Quantitation of HIV-1 RNA in plasma predicts outcome after seroconversion. Ann Intern Med. 1995 Apr 15;122(8):573–9. PMID: 7887550.7887550
39 Mellors JW, Munoz A, Giorgi JV, . Plasma viral load and CD4+ lymphocytes as prognostic markers of HIV-1 infection. Ann Intern Med. 1997 Jun 15;126(12):946–54. PMID: 9182471.9182471
40 Phair JP, Mellors JW, Detels R, . Virologic and immunologic values allowing safe deferral of antiretroviral therapy. AIDS. 2002 Dec 6;16(18):2455–9. PMID: 12461420.12461420
41 Babiker AG, Peto T, Porter K, . Age as a determinant of survival in HIV infection. J Clin Epidemiol. 2001 Dec;54 Suppl 1:S16–21. PMID: 11750205.11750205
42 Vella S, Giuliano M, Floridia M, . Effect of sex, age and transmission category on the progression to AIDS and survival of zidovudine-treated symptomatic patients. AIDS. 1995 Jan;9(1):51–6. PMID: 7893441.7893441
43 Pedersen C, Lindhardt BO, Jensen BL, . Clinical course of primary HIV infection: consequences for subsequent course of infection. BMJ. 1989;299(6692):154–7. PMID: 2569901.2569901
44 de Roda Husman A-M, Koot M, Cornelissen M, . Association between CCR5 genotype and the clinical course of HIV-1 Infection. Ann Intern Med. 1997 November 15, 1997;127(10):882–90. PMID: 9382366.9382366
45 Ioannidis JP, Rosenberg PS, Goedert JJ, . Effects of CCR5-Delta32, CCR2-64I, and SDF-1 3’A alleles on HIV-1 disease progression: an international meta-analysis of individual-patient data. Ann Intern Med. 2001 Nov 6;135(9):782–95. PMID: 11694103.11694103
46 Lathey JL, Tierney C, Chang SY, . Associations of CCR5, CCR2, and stromal cell-derived factor 1 genotypes with human immunodeficiency virus disease progression in patients receiving nucleoside therapy. J Infect Dis. 2001 Dec 1;184(11):1402–11. doi: 10.1086/324427. PMID: 11709782.11709782
47 Marmor M, Sheppard HW, Donnell D, . Homozygous and heterozygous CCR5-Delta32 genotypes are associated with resistance to HIV infection. J Acquir Immune Defic Syndr. 2001 Aug 15;27(5):472–81. PMID: 11511825.11511825
48 Nolan D, Gaudieri S, John M, . Impact of host genetics on HIV disease progression and treatment: new conflicts on an ancient battleground. AIDS. 2004 Jun 18;18(9):1231–40. PMID: 15362655.15362655
49 Baggaley RF, Boily MC, White RG, . Risk of HIV-1 transmission for parenteral exposure and blood transfusion: a systematic review and meta-analysis. AIDS. 2006 Apr 4;20(6):805–12. doi: 10.1097/01.aids.0000218543.46963.6d. PMID: 16549963.16549963
50 Moore RD. Epidemiology of HIV infection in the United States: implications for linkage to care. Clin Infect Dis. 2011 Jan 15;52 Suppl 2:S208–13. doi: 10.1093/cid/ciq044. PMID: 21342909.21342909
51 US Public Health Service. Preexposure prophylaxis for the prevention of HIV infection in the United States - 2017 update: A clinical practice guideline. 2017. https://www.cdc.gov/hiv/pdf/risk/prep/cdc-hiv-prep-guidelines-2017.pdf. Accessed January 31, 2019.
52 Chou R, Huffman LH, Fu R, . Screening for HIV: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2005 Jul 5;143(1):55–73. PMID: 15998755.15998755
53 Zakher B, Blazina I, Chou R. Association between knowledge of HIV-positive status or use of antiretroviral therapy and high-risk transmission behaviors: Systematic review. AIDS Care. 2014 2014/04/03;26(4):514–21. doi: 10.1080/09540121.2013.832723. PMID: 24007512.24007512
54 Rodger AJ, Cambiano V, Bruun T, . Sexual activity without condoms and risk of HIV transmission in serodifferent couples when the HIV-positive partner is using suppressive antiretroviral therapy. JAMA. 2016 Jul 12;316(2):171–81. doi: 10.1001/jama.2016.5148. PMID: 27404185.27404185
55 Cohen MS, Chen YQ, McCauley M, . Prevention of HIV-1 infection with early antiretroviral therapy. N Engl J Med. 2011 Aug 11;365(6):493–505. doi: 10.1056/NEJMoa1105243. PMID: 21767103.21767103
56 Skarbinski J, Rosenberg E, Paz-Bailey G, . Human immunodeficiency virus transmission at each step of the care continuum in the United States. JAMA Intern Med. 2015 Apr;175(4):588–96. doi: 10.1001/jamainternmed.2014.8180. PMID: 25706928.25706928
57 Gopalappa C, Farnham PG, Chen YH, . Progression and transmission of HIV/AIDS (PATH 2.0). Med Decis Making. 2017 Feb;37(2):224–33. doi: 10.1177/0272989x16668509. PMID: 27646567.27646567
58 Centers for Disease Control and Prevention. Preexposure prophylaxis for the prevention of HIV infection in the United States—2014: a clinical practice guideline. www.cdc.gov/hiv/pdf/guidelines/PrEPguidelines2014.pdf Accessed October 31, 2016.
59 Chou R, Evans C, Hoverman A, Sun C, Dana T, Bougatsos C, Grusing S, Korthuis PT. Pre-Exposure Prophylaxis for the Prevention of HIV Infection: A Systematic Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 178. AHRQ Publication No. 18-05247-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2019.
60 U.S. Department of Health and Human Services. Guidelines for the Prevention and Treatment of Opportunistic Infections in HIV-Infected Adults and Adolescents. 2018. aidsinfo.nih.gov/guidelines/html/4/adult-and-adolescent-opportunistic-infection/0. Accessed January 3, 2018.
61 Panel on Antiretroviral Guidelines for Adults and Adolescents. Guidelines for the Use of Antiretroviral Agents in Adults and Adolescents Living with HIV. Department of Health and Human Services. Version October 25, 2018.; 2018. https://aidsinfo.nih.gov/contentfiles/lvguidelines/adultandadolescentgl.pdf. Accessed October 25, 2018.
62 McNaghten AD, Hanson DL, Jones JL, . Effects of antiretroviral therapy and opportunistic illness primary chemoprophylaxis on survival after AIDS diagnosis. AIDS. 1999;13(13):1687–95. PMID: 10509570.10509570
63 Panel on Opportunistic Infections in HIV-Infected Adults and Adolescents. Guidelines for the prevention and treatment of opportunistic infections in HIV-infected adults and adolescents: recommendations from the Centers for Disease Control and Prevention, the National Institutes of Health, and the HIV Medicine Association of the Infectious Diseases Society of America. aidsinfo.nih.gov/contentfiles/lvguidelines/adult_oi.pdf. Accessed December 21, 2017.
64 Centers for Disease Control and Prevention. Quick reference guide - Laboratory testing for the diagnosis of HIV infection: updated recommendations. 2014. stacks.cdc.gov/view/cdc/23447. Accessed October 31, 2016.
65 Delaney KP, Hanson DL, Masciotra S, . Time until emergence of HIV test reactivity following infection with HIV-1: Implications for interpreting test results and retesting after exposure. Clin Infect Dis. 2017 Jan 1;64(1):53–9. doi: 10.1093/cid/ciw666. PMID: 27737954.27737954
66 Bennett B, Neumann D, Fordan S, . Performance of the new HIV-1/2 diagnostic algorithm in Florida’s public health testing population: a review of the first five months of utilization. J Clin Virol. 2013 Dec;58 Suppl 1:e29–33. doi: 10.1016/j.jcv.2013.08.016. PMID: 24342476.24342476
67 Chen DJ, Yao JD. Comparison of turnaround time and total cost of HIV testing before and after implementation of the 2014 CDC/APHL Laboratory Testing Algorithm for diagnosis of HIV infection. J Clin Virol. 2017 Jun;91:69–72. doi: 10.1016/j.jcv.2017.04.004. PMID: 28461133.28461133
68 Centers for Disease Control and Prevention. Interpretation and use of the western blot assay for serodiagnosis of human immunodeficiency virus type 1 infections JAMA. 1989;262(24):3395–7. PMID: 2685380.2685380
69 Centers for Disease Control and Prevention. Update: serologic testing for HIV-1 antibody-United States, 1988 and 1989. M. 1990;39(22):380–3. PMID: 2111436.2111436
70 Centers for Disease Control and Prevention. Rapid HIV tests suitable for use in non-clinical settings (CLIA-waived). 2016. https://www.cdc.gov/hiv/pdf/testing/rapid-hiv-tests-non-clinical.pdf Accessed February 6, 2018.
71 Centers for Disease Control and Prevention. CDC Fact sheet: HIV testing in the United States. 2016. www.cdc.gov/nchhstp/newsroom/docs/factsheets/hiv-testing-us-508.pdf. Accessed October 31, 2016.
72 Van Handel M, Kann L, Olsen EO, . HIV testing among US high school students and young adults. Pediatrics. 2016 Feb;137(2):e20152700. doi: 10.1542/peds.2015-2700. PMID: 26787047.26787047
73 Branson BM, Handsfield HH, Lampe MA, . Revised recommendations for HIV testing of adults, adolescents, and pregnant women in health-care settings. MMWR Recomm Rep. 2006 Sep 22;55(RR-14):1–17. PMID: 16988643.16988643
74 DiNenno EA, Prejean J, Irwin K, . Recommendations for HIV screening of gay, bisexual, and other men who have sex with men - United States, 2017. MMWR. 2017 Aug 11;66(31):830–2. doi: 10.15585/mmwr.mm6631a3. PMID: 28796758.28796758
75 Qaseem A, Snow V, Shekelle P, . Screening for HIV in health care settings: a guidance statement from the American College of Physicians and HIV Medicine Association. Ann Intern Med. 2009;150(2):125–31. . PMID: 19047022.19047022
76 Lubinski C, Aberg J, Bardeguez AD, . HIV policy: the path forward-a joint position paper of the HIV Medicine Association of the Infectious Diseases Society of America and the American College of Physicians. Clin Infect Dis. 2009 May 15;48(10):1335–44. PMID: 19385087.19385087
77 American College of Obstetricians and Gynecologists. Committee opinion: routine HIV screening. 2014. www.acog.org/-/media/Committee-Opinions/Committee-on-Gynecologic-Practice/co596.pdf?dmc=1&ts=20161013T1844591209. Accessed October 31, 2016.
78 American Academy of Pediatrics. Policy statement: adolescents and HIV infection: The pediatrician’s role in promoting routine testing. Pediatrics. 2011;128(5):1023–9. PMID: 2204281622042816
79 American Academy of Family Physicians. Clinical preventive service recommendation: human immunodeficiency virus (HIV). 2013. www.aafp.org/patient-care/clinical-recommendations/all/hiv.html. Accessed October 31, 2016.
80 U.S. Preventive Services Task Force Procedure Manual. Rockville, MD; https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual Accessed December 8, 2018.
81 Kitahata MM, Gange SJ, Abraham AG, . Effect of early versus deferred antiretroviral therapy for HIV on survival. N Engl J Med. 2009 Apr 30;360(18):1815–26. doi: 10.1056/NEJMoa0807252. PMID: 19339714.19339714
82 Ray M, Logan R, Sterne J, . The effect of combined antiretroviral therapy on the overall mortality of HIV-infected individuals. AIDS. 2010;24(1):123–37. doi: 10.1097/QAD.0b013e3283324283. PMID: 19770621.19770621
83 Sterne JA, May M, Costagliola D, . Timing of initiation of antiretroviral therapy in AIDS-free HIV-1-infected patients: a collaborative analysis of 18 HIV cohort studies. Lancet. 2009 Apr 18;373(9672):1352–63. doi: 10.1016/s0140-6736(09)60612-7. PMID: 19361855.19361855
84 Writing Committee for the CASCADE Collaboration. Timing of HAART initiation and clinical outcomes in human immunodeficiency virus type 1 seroconverters. Arch Intern Med. 2011 Sep 26;171(17):1560–9. doi: 10.1001/archinternmed.2011.401. PMID: 21949165.21949165
85 Lundgren JD, Babiker AG, Gordin F, . Initiation of antiretroviral therapy in early asymptomatic HIV infection. N Engl J Med. 2015 Aug 27;373(9):795–807. doi: 10.1056/NEJMoa1506816. PMID: 26192873.26192873
86 TEMPRANO ANRS 12136 Study Group, Danel C, Moh R, . A trial of early antiretrovirals and isoniazid preventive therapy in Africa. N Engl J Med. 2015 Aug 27;373(9):808–22. doi: 10.1056/NEJMoa1507198. PMID: 26193126.26193126
87 Lodi S, Phillips A, Logan R, . Comparative effectiveness of immediate antiretroviral therapy versus CD4-based initiation in HIV-positive individuals in high-income countries: observational cohort study. Lancet HIV. 2015 Aug;2(8):e335–43. doi: 10.1016/S2352-3018(15)00108-3. PMID: 26423376.26423376
88 Edwards JK, Cole SR, Westreich D, . Age at entry into care, timing of antiretroviral therapy initiation, and 10-year mortality among HIV-seropositive adults in the United States. Clin Infect Dis. 2015 Oct 1;61(7):1189–95. doi: 10.1093/cid/civ463. PMID: 26082505.26082505
89 Emery S, Neuhaus JA, Phillips AN, . Major clinical outcomes in antiretroviral therapy (ART)-naive participants and in those not receiving ART at baseline in the SMART study. J Infect Dis. 2008;197(8):1133–44. doi: 10.1086/586713. PMID: 18476292.18476292
90 Grinsztejn B, Hosseinipour MC, Ribaudo HJ, . Effects of early versus delayed initiation of antiretroviral treatment on clinical outcomes of HIV-1 infection: results from the phase 3 HPTN 052 randomised controlled trial. Lancet Infect Dis. 2014 Apr;14(4):281–90. doi: 10.1016/s1473-3099(13)70692-3. PMID: 24602844.24602844
91 Severe P, Juste MA, Ambroise A, . Early versus standard antiretroviral therapy for HIV-infected adults in Haiti. N Engl J Med. 2010 Jul 15;363(3):257–65. doi: 10.1056/NEJMoa0910370. PMID: 20647201.20647201
92 May M, Sterne JA, Sabin C, . Prognosis of HIV-1-infected patients up to 5 years after initiation of HAART: collaborative analysis of prospective studies. AIDS. 2007 May 31;21(9):1185–97. doi: 10.1097/QAD.0b013e328133f285. PMID: 17502729.17502729
93 Cohen MS, Chen YQ, McCauley M, . Antiretroviral therapy for the prevention of HIV-1 transmission. N Engl J Med. 2016 Sep 1;375(9):830–9. doi: 10.1056/NEJMoa1600693. PMID: 27424812.27424812
94 O’Connor J, Vjecha MJ, Phillips AN, . Effect of immediate initiation of antiretroviral therapy on risk of severe bacterial infections in HIV-positive people with CD4 cell counts of more than 500 cells per muL: secondary outcome results from a randomised controlled trial. Lancet HIV. 2017 Mar;4(3):e105–e12. doi: 10.1016/s2352-3018(16)30216-8. PMID: 28063815.28063815
95 Lodi S, Costagliola D, Sabin C, . Effect of immediate initiation of antiretroviral treatment in HIV-positive individuals aged 50 years or older. J Acquir Immune Defic Syndr. 2017 Nov 01;76(3):311–8. doi: 10.1097/qai.0000000000001498. PMID: 28746165.28746165
96 Lima VD, Reuter A, Harrigan PR, . Initiation of antiretroviral therapy at high CD4+ cell counts is associated with positive treatment outcomes. AIDS. 2015 Sep 10;29(14):1871–82. doi: 10.1097/QAD.0000000000000790. PMID: 26165354.26165354
97 Worm SW, Sabin C, Weber R, . Risk of myocardial infarction in patients with HIV infection exposed to specific individual antiretroviral drugs from the 3 major drug classes: the data collection on adverse events of anti-HIV drugs (D:A:D) study. J Infect Dis. 2010 Feb 1;201(3):318–30. doi: 10.1086/649897. PMID: 20039804.20039804
98 Bedimo RJ, Westfall AO, Drechsler H, . Abacavir use and risk of acute myocardial infarction and cerebrovascular events in the highly active antiretroviral therapy era. Clin Infect Dis. 2011 Jul 1;53(1):84–91. doi: 10.1093/cid/cir269. PMID: 21653308.21653308
99 Obel N, Farkas DK, Kronborg G, . Abacavir and risk of myocardial infarction in HIV-infected patients on highly active antiretroviral therapy: a population-based nationwide cohort study. HIV Med. 2010 Feb;11(2):130–6. doi: 10.1111/j.1468-1293.2009.00751.x. PMID: 19682101.19682101
100 Ribaudo HJ, Benson CA, Zheng Y, . No risk of myocardial infarction associated with initial antiretroviral treatment containing abacavir: short and long-term results from ACTG A5001/ALLRT. Clin Infect Dis. 2011 Apr 1;52(7):929–40. doi: 10.1093/cid/ciq244. PMID: 21427402.21427402
101 Ding X, Andraca-Carrera E, Cooper C, . No association of abacavir use with myocardial infarction: findings of an FDA meta-analysis. J Acquir Immune Defic Syndr. 2012 Dec 1;61(4):441–7. doi: 10.1097/QAI.0b013e31826f993c. PMID: 22932321.22932321
102 Sabin CA, Reiss P, Ryom L, . Is there continued evidence for an association between abacavir usage and myocardial infarction risk in individuals with HIV? A cohort collaboration. BMC Med. 2016 Mar 31;14:61. doi: 10.1186/s12916-016-0588-4. PMID: 27036962.27036962
103 Desai M, Joyce V, Bendavid E, . Risk of cardiovascular events associated with current exposure to HIV antiretroviral therapies in a US veteran population. Clin Infect Dis. 2015 Aug 1;61(3):445–52. doi: 10.1093/cid/civ316. PMID: 25908684.25908684
104 Monforte A, Reiss P, Ryom L, . Atazanavir is not associated with an increased risk of cardio- or cerebrovascular disease events. AIDS. 2013 Jan 28;27(3):407–15. doi: 10.1097/QAD.0b013e32835b2ef1. PMID: 23291539.23291539
105 Ford N, Shubber Z, Pozniak A, . Comparative safety and neuropsychiatric adverse events associated with efavirenz use in first-line antiretroviral therapy: A systematic review and meta-analysis of randomized trials. J Acquir Immune Defic Syndr. 2015 Aug 1;69(4):422–9. doi: 10.1097/QAI.0000000000000606. PMID: 25850607.25850607
106 Nkhoma ET, Coumbis J, Farr AM, . No evidence of an association between efavirenz exposure and suicidality among HIV patients initiating antiretroviral therapy in a retrospective cohort study of real world data. Medicine (Baltimore). 2016;95(3):e2480. doi: 10.1097/MD.0000000000002480. PMID: 26817882.26817882
107 Smith C, Ryom L, d’Arminio Monforte A, . Lack of association between use of efavirenz and death from suicide: evidence from the D:A:D study. J Int AIDS Soc. 2014 11/02;17(4 Suppl 3):19512. doi: 10.7448/IAS.17.4.19512. PMID: 25394021.25394021
108 Chang JL, Tsai AC, Musinguzi N, . Depression and suicidal ideation among HIV-infected adults receiving efavirenz versus nevirapine in Uganda: A prospective cohort study. Ann Intern Med. 2018 Jun 26 doi: 10.7326/m17-2252. PMID: 29946683.29946683
109 Bruyand M, Ryom L, Shepherd L, . Cancer risk and use of protease inhibitor or nonnucleoside reverse transcriptase inhibitor-based combination antiretroviral therapy: the D: A: D study. J Acquir Immune Defic Syndr. 2015 Apr 15;68(5):568–77. doi: 10.1097/qai.0000000000000523. PMID: 25763785.25763785
110 Ryom L, Lundgren JD, De Wit S, . Use of antiretroviral therapy and risk of end-stage liver disease and hepatocellular carcinoma in HIV-positive persons. AIDS. 2016 Jul 17;30(11):1731–43. doi: 10.1097/qad.0000000000001018. PMID: 26752282.26752282
111 Mocroft A, Lundgren JD, Ross M, . Cumulative and current exposure to potentially nephrotoxic antiretrovirals and development of chronic kidney disease in HIV-positive individuals with a normal baseline estimated glomerular filtration rate: a prospective international cohort study. Lancet HIV. 2016 Jan;3(1):e23–32. doi: 10.1016/s2352-3018(15)00211-8. PMID: 26762990.26762990
112 Borges AH, Hoy J, Florence E, . Antiretrovirals, fractures, and osteonecrosis in a large international HIV cohort. Clin Infect Dis. 2017 May 15;64(10):1413–21. doi: 10.1093/cid/cix167. PMID: 28329090.28329090
113 Friis-Moller N, Reiss P, Sabin CA, . Class of antiretroviral drugs and the risk of myocardial infarction. N Engl J Med. 2007 Apr 26;356(17):1723–35. doi: 10.1056/NEJMoa062744. PMID: 17460226.17460226
114 Sabin CA, Worm SW, Weber R, . Use of nucleoside reverse transcriptase inhibitors and risk of myocardial infarction in HIV-infected patients enrolled in the D:A:D study: a multi-cohort collaboration. Lancet. 2008 Apr 26;371(9622):1417–26. doi: 10.1016/s0140-6736(08)60423-7. PMID: 18387667.18387667
115 Arribas JR, Thompson M, Sax PE, . Brief report: Randomized, double-blind comparison of tenofovir alafenamide (TAF) vs tenofovir disoproxil fumarate (TDF), each coformulated eith elvitegravir, cobicistat, and emtricitabine (E/C/F) for initial HIV-1 treatment: Week 144 results. J Acquir Immune Defic Syndr. 2017 Jun 01;75(2):211–8. doi: 10.1097/QAI.0000000000001350. PMID: 28282300.28282300
116 Rockstroh JK, DeJesus E, Lennox JL, . Durable efficacy and safety of raltegravir versus efavirenz when combined with tenofovir/emtricitabine in treatment-naive HIV-1-infected patients: final 5-year results from STARTMRK. J Acquir Immune Defic Syndr. 2013 May 1;63(1):77–85. doi: 10.1097/QAI.0b013e31828ace69. PMID: 23412015.23412015
117 Kovari H, Sabin CA, Ledergerber B, . Antiretroviral drug-related liver mortality among HIV-positive persons in the absence of hepatitis B or C virus coinfection: the data collection on adverse events of anti-HIV drugs study. Clin Infect Dis. 2013 Mar;56(6):870–9. doi: 10.1093/cid/cis919. PMID: 23090925.23090925
118 Laprise C, Baril J-G, Dufresne S, . Association between tenofovir exposure and reduced kidney function in a cohort of HIV-positive patients: results from 10 years of follow-up. Clin Infect Dis. 2013;56(4):567–75. doi: 10.1093/cid/cis937. PMID: 23143096.23143096
119 Scherzer R, Estrella M, Li Y, . Association of tenofovir exposure with kidney disease risk in HIV infection. AIDS. 2012 Apr 24;26(7):867–75. doi: 10.1097/QAD.0b013e328351f68f. PMID: 22313955.22313955
120 Nkhoma ET, Rosenblatt L, Myers J, . Real-world assessment of renal and bone safety among patients with HIV infection exposed to tenofovir disoproxil fumarate-containing single-tablet regimens. PLoS One. 2016;11(12):e0166982. doi: 10.1371/journal.pone.0166982. PMID: 27941989.27941989
121 Kowalska JD, Reekie J, Mocroft A, . Long-term exposure to combination antiretroviral therapy and risk of death from specific causes: no evidence for any previously unidentified increased risk due to antiretroviral therapy. AIDS. 2012 Jan 28;26(3):315–23. doi: 10.1097/QAD.0b013e32834e8805. PMID: 22112597.22112597
122 Mollan KR, Smurzynski M, Eron JJ, . Association between efavirenz as initial therapy for HIV-1 infection and increased risk for suicidal ideation or attempted or completed suicide: An analysis of trial data. Ann Intern Med. 2014;161(1):1–10. PMID: 24979445.24979445
123 Ryom L, Mocroft A, Kirk O, . Association between antiretroviral exposure and renal impairment among HIV-positive persons with normal baseline renal function: the D:A:D study. J Infect Dis. 2013 May 1;207(9):1359–69. doi: 10.1093/infdis/jit043. PMID: 23382571.23382571
124 Siegfried N, Uthman OA, Rutherford GW. Optimal time for initiation of antiretroviral therapy in asymptomatic, HIV-infected, treatment-naive adults. Cochrane Database Syst Rev. 2011(2)doi: 10.1002/14651858.CD008272.pub2. PMID: 20238364.20238364
125 Anglemyer A, Rutherford GW, Easterbrook PJ, . Early initiation of antiretroviral therapy in HIV-infected adults and adolescents: a systematic review. AIDS. 2014 Mar;28 Suppl 2:S105–18. doi: 10.1097/QAD.0000000000000232. PMID: 24849469.24849469
126 Bavinger C, Bendavid E, Niehaus K, . Risk of cardiovascular disease from antiretroviral therapy for HIV: a systematic review. PLoS One. 2013;8(3):e59551. doi: 10.1371/journal.pone.0059551. PMID: 23555704.23555704
127 Siedner MJ. START or SMART? Timing of antiretroviral therapy initiation and cardiovascular risk for people with human immunodeficiency virus infection. Open Forum Infect Dis. 2016 Jan;3(1):ofw032. doi: 10.1093/ofid/ofw032. PMID: 26989755.26989755
128 Bradley H, Hall HI, Wolitski RJ, . Vital Signs: HIV diagnosis, care, and treatment among persons living with HIV-United States, 2011. MMWR. 2014;63(47):1113–7. PMID: 25426654.25426654
129 Tillison AS, Avery AK. Evaluation of the impact of routine HIV screening in primary care. J Int Assoc Provid AIDS Care. 2017 Jan/Feb;16(1):18–22. doi: 10.1177/2325957416666677. PMID: 27596961.27596961
130 Hutchinson AB, Farnham PG, Sansom SL, . Cost-effectiveness of frequent HIV testing of high-risk populations in the United States. J Acquir Immune Defic Syndr. 2016 Mar 1;71(3):323–30. doi: 10.1097/qai.0000000000000838. PMID: 26361172.26361172
131 Lucas A, Armbruster B. The cost-effectiveness of expanded HIV screening in the United States. AIDS. 2013 Mar 13;27(5):795–801. doi: 10.1097/QAD.0b013e32835c54f9. PMID: 23169333.23169333
132 Long EF. HIV screening via fourth-generation immunoassay or nucleic acid amplification test in the United States: a cost-effectiveness analysis. PLoS One. 2011;6(11):e27625. doi: 10.1371/journal.pone.0027625. PMID: 22110698.22110698
133 U.S. Department of Health and Human Services. HIV Treatment. FDA-Approved HIV Medicines. 2017. aidsinfo.nih.gov/understanding-hiv-aids/fact-sheets/21/58/fda-approved-hiv-medicines. Accessed December 21, 2017.
134 Cid-Silva P, Llibre JM, Fernández-Bargiela N, . Clinical experience with the integrase inhibitors dolutegravir and elvitegravir in HIV-infected patients: Efficacy, safety and tolerance. Basic Clin Pharmacol Toxicol. 2017;121(5):442–6. doi: 10.1111/bcpt.12828. PMID: 28627771.28627771
135 Cailhol J, Rouyer C, Alloui C, . Dolutegravir and neuropsychiatric adverse events: a continuing debate. AIDS. 2017;31(14):2023–4. doi: 10.1097/qad.0000000000001596. PMID: 28857781.28857781
136 Hoffmann C, Welz T, Sabranski M, . Higher rates of neuropsychiatric adverse events leading to dolutegravir discontinuation in women and older patients. HIV Med. 2017 Jan;18(1):56–63. doi: 10.1111/hiv.12468. PMID: 27860104.27860104
137 Grulich A. HIV treatment prevents HIV transmission in male serodiscordant couples in Australia, Thailand and Brazil. 2017. programme.ias2017.org/Abstract/Abstract/5469. Accessed February 6, 2018.