# Acknowledgments

The authors thank AHRQ Medical Officer, Howard Tracer, MD; as well as the U.S. Preventive Services Task Force.