# Chapter 4 Discussion

## Summary of Review Findings

This report updates a 2012 USPSTF review^2^ on screening for HIV infection in nonpregnant adolescents and adults. As in previous USPSTF reviews,^2,52^ we found no direct evidence on clinical benefits and harms of screening for HIV infection versus no screening, or on the yield of repeat screening. Other evidence reviewed for this update is summarized in Table 5.

Table 5 Summary of Evidence

KQ | No. of studies (k) Number of participants (n) Study design | Summary of findings by outcome | Consistency/ precision/ reporting bias | Overall risk of bias/ quality | Body of evidence limitations | EPC Assessment of strength of evidence for KQ | Applicability
KQ 1. Benefits of HIV screening vs. no screening | No studies | -- | -- | -- | -- | -- | --
KQ 2. Yield of repeat vs. one-time HIV screening, or HIV screening at different intervals | No studies | -- | -- | -- | -- | -- | --
KQ 3. Harms of HIV screening vs. no screening | No studies | -- | -- | -- | -- | -- | --
KQ 4. Benefits of immediate vs. delayed ART; - CD4 count >500 cells/mm^3^ | 2012 USPSTF review: k=4 observational studies (n=74,563); New evidence: k=4 (2 RCTs [n=6,761] and 2 observational studies [n=59,946]) | Four observational studies in the prior USPSTF review found inconsistent evidence on effects of initiation of ART in patients with CD4 counts >500 cells/mm^3^ vs. delayed initiation.; Two new RCTs found initiation of ART in patients with CD4 counts >500 cells/mm^3^ associated with decreased risk of death, AIDS events, and serious non-AIDS events (RR, 0.44 [95% CI, 0.31 to 0.63] and RR, 0.57 [95% CI, 0.35 to 0.95]).; Two new observational studies also found initiation of ART at CD4 counts >500 cells/mm^3^ associated with lower risk of death and AIDS-related events than delayed initiation, although one study reported effects smaller than those observed in the randomized trials.; In one RCT, there was no association between early initiation of ART and increased risk of cardiovascular events (RR, 0.87 [95% CI, 0.40 to 1.88]). | Some inconsistency between RCTs and observational studies. Estimates in the RCTs precise for the primary composite outcome but some imprecision for some individual outcomes.; No reporting bias detected. | Fair | One new RCT reported that ART drugs were provided by industry. One new RCT was open label, changed criteria for initiation of ART in the delayed therapy group over the course of the trial to match revisions to WHO recommendations, and conducted a prespecified subgroup analysis of patients with baseline CD4 counts >500 cells/mm^3^ (41% of study population). | Moderate | One trial was conducted in a low-income setting and the other trial was international and partially conducted in low-/middle-income settings. Median CD4 count was 651 cells/mm^3^ in one trial and in the other trial baseline CD4 count ranged from 500 to 800 mm/cells^3^ (average CD4 count not reported in the subgroup of patients with a CD4 count >500 cells/mm^3^ at baseline). Patients were randomized between 2008 and 2013 in the trials. The observational studies were conducted in U.S. and European cohorts.
KQ 4. Benefits of immediate vs. delayed ART; - CD4 count >350 to <500 or 550 cells/mm^3^ | 2012 USPSTF review: k=6 (2 RCTs [n=2,012] and 4 observational studies [n=71,460]); New evidence: k=1 observational study (n=3,532), plus longer-term followup from RCT included in 2012 review | Two RCTs in the prior USPSTF review found initiation of ART at CD4 counts >350 cells/mm^3^ associated with decreased risk of death or AIDS events after ~1.5 years compared with initiation at CD4 counts <250 cells/mm^3^ (RR, 0.30 [95% CI, 0.11 to 0.81] and RR, 0.61 [95% CI, 0.42 to 0.89]) and one of the RCTs found early initiation of ART associated with decreased risk of HIV transmission (RR, 0.04 [95% CI, 0.005 to 0.27] for virologically-linked transmission). Four observational studies reported consistent findings on clinical outcomes. One RCT found a potential protective effect of early initiation of ART on risk of cardiovascular events (RR, 0.07 [95% CI, 0.004 to 1.24]).; Longer-term (2.1 years) followup from one RCT included in the prior review reported decreased risk of AIDS-related events (RR, 0.65 [95% CI, 0.44 to 0.95]); effects on the primary composite outcome (death, AIDS events, and non-AIDS events) favored early initiation of ART, but the effect was not statistically significant (RR, 0.73 [95% CI, 0.53 to 1.02]); beneficial effects on HIV transmission remained present at 5.5 years followup (RR, 0.07 [95% CI, 0.02 to 0.22] for virologically-linked transmission). One observational study reported consistent findings on clinical outcomes. | Consistent. Some imprecision in study estimates for certain outcomes.; No reporting bias detected. | Good | Study drugs were donated in one RCT. One RCT included in the prior USPSTF review conducted a post hoc subgroup analysis of patients with CD4 counts >350 cells/mm^3^ at baseline. | High | One trial was primarily conducted in high-income settings and one trial was primarily conducted in low-income settings. Median CD4 counts at baseline in the RCTs were 430 to 440 cells/mm^3^. Patients were randomized between the years 2002 to 2006 in one trial and from 2007 to 2010 in the other trial.
KQ 5. Long-term harms of ART | 2012 USPSTF review: k=4 observational studies (n>60,500^*^); New evidence: k=11 (2 systematic reviews [n=18,334], 2 trials [n=2,296], and 8 observational studies in 16 publications [n=~134,225^*^], including longer-term followup from a large observational study included in the prior review) | [underlined: Cardiovascular harms:] A meta-analysis of 26 trials found no association between ABC use and risk of myocardial infarction, but two observational studies found ABC associated with increased risk (RR, 1.98 [95% CI, 1.72 to 2.29] and OR, 1.50 [95% CI, 1.26 to 1.79]).; [underlined: Neuropsychiatric harms:] A systematic review of randomized and quasirandomized trials found EFV associated with increased risk of neuropsychiatric adverse events vs. other antiretroviral agents. Three observational studies found no association between use of EFV and death from suicide or suicidal ideation.; [underlined: Hepatic harms:] An observational study found tenofovir associated with increased risk of end-stage liver disease or hepatocellular carcinoma, and emtricitabine associated with decreased risk.; [underlined: Renal harms:] Two observational studies found tenofovir associated with increased risk of chronic kidney disease and two observational studies found ATV/r and protease inhibitors associated with renal adverse events.; [underlined: Fracture:] A cohort study found ever use of tenofovir associated with increased risk of fracture (IRR, 1.40 [95% CI, 1.15 to 1.70]), but no association between cumulative exposure to tenofovir and risk of fracture (IRR per 5 years of exposure, 1.08 [95% CI, 0.94 to 1.25]). | Some inconsistency between RCT and observational data regarding cardiovascular risks of ABC. Findings reasonably precise.; No reporting bias detected. | Fair | All studies were observational. | Low to moderate | Studies evaluated components of ART regimens rather than complete regimens, potentially limiting applicability to current regimens, and difficult to account for potential interactions between ART drugs and patients switching ART regimens in analyses. The largest study was conducted in the United States and Europe and began enrollment in 1999. Clinical importance of neuropsychiatric, renal, and hepatic harms likely to vary depending on reversibility following antiretroviral agent discontinuation and availability of alternative ART regimens.

* The number of participants in D:A:D cohort publications ranged from 23,905 to 49,717 depending on year of followup and outcome.

Abbreviations: ABC=abacavir; ART=antiretroviral therapy; ATV/r=ritonavir-boosted atazanavir; CD4=cluster of differentiation 4; CI=confidence interval; EFV=efavirenz; EPC=Evidence-based Practice Center; KQ=key question; OR=odds ratio; RCT=randomized, controlled trial; RR=relative risk; U.S.=United States; USPSTF=U.S. Preventive Services Task Force; WHO=World Health Organization.

New data extends evidence on effectiveness of ART to persons with CD4 counts greater than 500 cells/mm^3^, further expanding upon previous findings regarding estimated benefits of interventions as a result of HIV screening. In 2005, the USPSTF review found good evidence that HIV screening tests are accurate and that identification of undiagnosed HIV infection and treatment of immunologically advanced disease (CD4 count <200 cells/mm^3^) are associated with substantial clinical benefits.^52^ The 2012 USPSTF review found strong evidence of an association between initiation of ART at CD4 counts of 350 to 500 cells/mm^3^ and reduced risk of death or AIDS-related illness and substantially reduced risk of sexual transmission of HIV infection compared with initiation at lower CD4 counts; evidence on effectiveness of initiation of ART in patients with CD4 counts greater than 500 cells/mm^3^ was limited to observational studies and inconsistent.^2^ New evidence from the START and TEMPRANO ANRS 12136 randomized trials and the large observational HIV CAUSAL study found initiation of ART at CD4 counts greater than 500 cells/mm^3^ associated with decreased risk of death, AIDS events, and other clinical outcomes compared with delayed initiation or no ART.^85–87^ Effects were relatively modest in HIV CAUSAL (reduction in risk of death or AIDS events, 17%) compared with the randomized trials (reduction in risk, 43% to 53%). A factor that could explain the difference in magnitude of effects is that HIV CAUSAL was conducted in cohorts from the United States and Europe, whereas the RCTs were conducted entirely (TEMPRANO ANRS 12136) or partially (START) in low-income settings, where patients may benefit more from early initiation of ART due to higher incidence of certain infections (e.g., tuberculosis), reduced access to opportunistic infection prophylaxis, or other factors. However, estimates on effectiveness of ART in START were similar when analyses were stratified according to high- versus low-/moderate-income setting (HR for the primary outcome, 0.39 for high-income setting and 0.48 for low-income setting [95% CIs not reported]; p=0.55 for interaction). Residual confounding could explain the observed differences if HIV CAUSAL patients with favorable prognosis were less likely to start early ART than those with less favorable prognosis, and confounders associated with prognosis were not completely captured in the analysis. Our findings regarding the effectiveness of ART in patients with CD4 counts greater than 500 cells/mm^3^ differed from previously published systematic reviews on timing of ART, which found insufficient evidence in this population but were conducted prior to the publication of the TEMPRANO ANRS 12135 and START trials.^124,125^ Longer-term followup from the HPTN 052 trial was consistent in showing sustained effects of ART initiated at CD4 counts greater than 350 cells/mm^3^ on reduced risk of HIV transmission in heterosexual couples and AIDS-related clinical outcomes.^90,93^

Understanding long-term harms of ART is important because patients are started on ART earlier and typically continue it indefinitely. The 2012 USPSTF report found some evidence indicating increased risk of long-term cardiovascular harms with the NRTI abacavir, though data were somewhat inconsistent.^2^ New evidence regarding cardiovascular harms of abacavir remains mixed. A large meta-analysis of randomized trials found no association between abacavir use and increased risk,^101^ but longer-term followup from the large, ongoing D:A:D observational study and other observational studies continued to find an association between abacavir exposure and increased risk of myocardial infarction (risk approximately doubled).^102,103^ One explanation for the difference between randomized and observational data on abacavir cardiovascular risk is that patients in randomized trials might have been at lower baseline risk of cardiovascular events. However, estimates in D:A:D did not change when patients were stratified according to whether abacavir was started before or after March 2008, despite a decreased propensity to prescribe abacavir in persons at higher cardiovascular risk after 2008. The randomized trials were also shorter in duration (~1.5 years) compared with D:A:D (7 years). Our findings regarding the association between abacavir use and risk of cardiovascular events are consistent with a recent systematic review that also noted a discrepancy between randomized trials and observational studies.^126^ A new analysis from D:A:D found no association between the currently used protease inhibitor atazanavir and risk of cardiovascular events.^104^ Despite a potential association between certain antiretrovirals and increased risk of cardiovascular events, data from randomized trials found no association between early initiation of ART and increased risk of cardiovascular events.^85,89^ The SMART trial, in which ART was initiated at CD4 counts greater than 350 cells/mm^3^, found a potential protective effect on risk of cardiovascular events (RR, 0.07 [95% CI, 0.004 to 1.24]), but the START trial, in which ART was initiated at CD4 counts greater than 500 cells/mm^3^, found no protective effect (RR, 0.87 [95% CI, 0.40 to 1.88]). As HIV infection itself is associated with increased cardiovascular risk, effects of ART on mitigating cardiovascular risk may be greater in persons with more advanced disease.^127^

Data are also available on other long-term harms, including neuropsychiatric adverse events and hepatic and renal adverse events. Although a systematic review found efavirenz associated with an increased risk of severe neuropsychiatric adverse events compared with other antiretroviral medications,^105^ other studies found no clear association between efavirenz use and death from suicide or suicidal ideation.^106–108^ Long-term data on neuropsychiatric adverse events associated with integrase inhibitors are limited. Some new evidence also indicates long-term hepatic, renal, and bone (fracture) adverse events associated with certain antiretroviral medications.^111,112,117–120,123^ The clinical effects of neuropsychiatric, renal, hepatic, and bone adverse events will depend on the degree to which they are reversible, the severity of the event, and the availability and use of effective alternative ART regimens. Abacavir and efavirenz are not recommended as part of initial ART in most persons with HIV, but are recommended in certain clinical situations.^61^

Although no study directly evaluated effects of screening versus no screening on clinical outcomes, epidemiological and observational data indicate recent trends toward less delayed diagnosis, fewer patients with undiagnosed HIV infection, and lower incidence of HIV infection.^10,12,128,129^ The degree to which these trends are attributable to adoption of universal HIV screening or other factors, and the effects of such trends on clinical outcomes such as mortality, AIDS events, and quality of life, are uncertain.

No clinical study evaluated the yield of repeat versus one-time screening, or compared the yield of screening at different intervals. Modeling studies suggest that repeat screening as frequently as once every 3 months may be cost effective in high-risk persons, depending on the frequency of testing, incidence of new HIV infections, HIV risk category, assay used for testing, and other factors.^130–132^ A recent CDC systematic review found insufficient evidence to support general recommendations on screening more frequently than annually in men who have sex with men, but noted suggestive findings from mathematical models that screening more frequently than annually could prevent some new HIV infections and be cost effective.^74^

## Limitations

We excluded non–English-language articles, which could result in language bias, though we identified no non–English-language studies that would have met inclusion criteria. We did not search for studies published only as abstracts and could not formally assess for publication bias with graphical or statistical methods because of small numbers of studies for each Key Question and differences in study design, populations, and outcomes assessed. We included observational studies, which are more susceptible to bias and confounding than well-conducted randomized trials, although we focused on results from studies that performed statistical adjustment for potential confounding. When evidence from settings more applicable to U.S. practice and screening in low- and average-risk populations was sparse or unavailable, we included studies conducted in resource-limited and high-prevalence settings, which could reduce applicability to U.S. practice. However, as noted above, a subgroup analysis from the START trial found similar effects of initiation of ART at CD4 counts greater than 500 cells/mm^3^ when results were stratified according to enrollment from a high- or low-/middle-income setting.^85^ Studies of long-term harms of ART often did not specify the regimen used or analyzed effects of specific antiretroviral drugs rather than the regimen as a whole, making it difficult to determine applicability of results to current recommended ART regimens. In addition, analyzing long-term harms of ART regimens is a challenge due to potential interactions between ART drugs and difficulty in accounting for drug regimen switches.

## Emerging Issues/Next Steps

ART regimens and indications for initiating long-term ART continue to evolve and treatment guidelines are regularly updated.^61^ Since 2012, new antiretroviral agents approved by the U.S. Food and Drug Administration for treatment of HIV infection include the integrase inhibitors dolutegravir and elvitegravir, the pharmacokinetic enhancer cobicistat, and several ART combinations.^133^ Some short-term studies have reported potential neuropsychiatric effects of the integrase inhibitor dolutegravir, but longer-term studies are lacking.^134–136^

## Relevance for Priority Populations, Particularly Racial/Ethnic Minorities

HIV infection disproportionately affects racial/ethnic minorities. Evidence on benefits of early versus delayed initiation of ART was primarily limited to the START trial, which found similar effects in subgroups stratified according to age and race/ethnicity.^85^ Although testing rates of men who have sex with men, persons who inject drugs, and persons at increased risk of HIV infection due to heterosexual contact are similar or slightly higher in racial/ethnic minorities compared with white persons, diagnosis delays are greater in racial/ethnic minorities (median, 3.3 years in black persons vs. 3.3 years in Hispanic/Latino persons vs. 4.2 years in Asian persons) than in white persons (median, 2.2 years), and linkage to care is lower in black versus white persons (76% vs. 85%).^12,128^ However, rates of ART use and viral suppression appear similar across racial/ethnic groups.^128^ Diagnosis delay also increases with age (median, 4.5 years in persons age ≥55 years vs. 2.4 years in persons ages 13 to 24 years). Evidence on benefits of early initiation of ART in adolescents remains very sparse; limited data indicate that benefits of early initiation of ART are maintained in older (age >50 years) patients.^95^

## Future Research

Research is needed on the yield of repeat versus one-time screening and annual versus more frequent screening, to help inform optimal screening intervals. Continued followup of patients taking ART is needed to further understand effects of long-term exposure to ART, as the duration of exposure to ART continues to lengthen. Ideally, studies should report effects of currently recommended ART regimens, including newly approved agents, in addition to analyses based on individual components of ART regimens, to better inform considerations regarding applicability to current practice. Additional research is needed on the neuropsychiatric effects of integrase inhibitors, given their status as first-line agents for ART and potential associated clinical consequences (e.g., suicide attempts and decreased quality of life), as well as the extent to which these and other effects (e.g., hepatic, renal) are reversible with discontinuation of therapy. Evidence on effects of ART on risk of HIV transmission in men who have sex with men and persons who inject drugs is limited, but an observational study of serodiscordant male homosexual couples published as a conference abstract found no cases of virologically-linked transmission from men with undetectable viral loads, and few cases of transmission overall.^137^

## Conclusions

The USPSTF previously determined that HIV screening is accurate, ART is effective at reducing risk of mortality and AIDS-defining events in asymptomatic patients with CD4 counts less than 500 cells/mm^3^, and ART reduces risk of sexual transmission of HIV infection. New evidence extends effectiveness of ART to persons with CD4 counts greater than 500 cells/mm^3^. Certain ART regimens may be associated with long-term cardiovascular, neuropsychiatric, hepatic, bone, or renal harms, but early initiation of ART is not associated with increased risk of cardiovascular events. Research is needed to inform optimal screening intervals.