# Chapter 3 Results

A total of 4,886 references from electronic database searches and manual searches of recently published studies were reviewed for this update, and 361 full-text papers were evaluated for inclusion. Eighteen new studies (in 29 articles) were included, and 11 studies were carried forward from the prior USPSTF report. Included studies and quality ratings are described in Appendix B Tables 1–14.

## Key Question 1 What Are the Benefits of Screening for HIV Infection in Asymptomatic, Nonpregnant Adolescents and Adults on Mortality, AIDS and Opportunistic Infections, Quality of Life, Function, and Reduced Transmission of HIV and Other STIs?

As in the prior USPSTF review, no randomized trial or observational study compared clinical outcomes between adults and adolescents screened and not screened for HIV infection.

## Key Question 2 What Is the Yield of Screening for HIV Infection at Different Intervals in Asymptomatic, Nonpregnant Adolescents and Adults, and How Does the Screening Yield Vary in Different Risk Groups?

As in the prior USPSTF review, no randomized trial or observational study evaluated the yield of repeated HIV screening compared with one-time screening, or compared the yield of different strategies for repeat screening (e.g., risk-based repeat screening vs. a routine repeat test, or repeat screening at different intervals).

## Key Question 3 What Are the Harms of Screening for HIV Infection in Asymptomatic, Nonpregnant Adolescents and Adults?

No randomized trial or observational study compared harms between adults and adolescents screened and not screened for HIV infection.

## Key Question 4 What Are the Effects of Initiating ART in Adolescents and Adults With Chronic HIV Infection at a Higher Versus Lower CD4 Count on Mortality, AIDS and Opportunistic Infections, Quality of Life, Function, and Reduced Transmission of HIV and Other STIs?

### Summary

Initiation of ART at CD4 counts greater than 500 cells/mm^3^:

- The prior USPSTF review found inconsistent effects of initiation of ART in persons infected with HIV with CD4 counts greater than 500 cells/mm^3^ versus delayed initiation on clinical outcomes, based on four observational studies.^81–84^
- Two subsequent RCTs found immediate initiation of ART in persons infected with HIV with CD4 counts greater than 500 cells/mm^3^ associated with decreased risk of composite clinical outcomes (mortality, AIDS-defining events, or serious non-AIDS events [e.g., bacterial infection, cancer]) compared with delayed initiation (RR, 0.44 [95% confidence interval (CI), 0.31 to 0.63] and RR, 0.57 [95% CI, 0.35 to 0.95]).^85,86^ Effects on all-cause mortality (RR, 0.58 [95% CI, 0.29 to 1.18] and RR, 0.79 [95% CI, 0.24 to 2.57]) and AIDS-related events/progression to AIDS also favored immediate initiation of ART (RR, 0.28 [95% CI, 0.16 to 0.51] and RR, 0.55 [95% CI, 0.29 to 1.05]).
- Two new observational studies of U.S. and European cohorts found initiation of ART in persons infected with HIV with CD4 counts greater than 500 cells/mm^3^ associated with lower risk of death and AIDS-related events than delayed initiation, although one study reported effects smaller than those observed in the randomized trials.^87,88^

Initiation of ART at CD4 counts of 350 cells/mm^3^ or greater:

- The prior USPSTF review found initiation of ART at CD4 counts greater than 350 cells/mm^3^ associated with decreased risk of death or AIDS events after approximately 1.5 years compared with initiation at CD4 counts less than 250 cells/mm^3^, based on two RCTs (including one post hoc subgroup analysis) (RR, 0.31 [95% CI, 0.11 to 0.83] and RR, 0.61 [95% CI, 0.42 to 0.89]).^55,89^ One of the trials (HIV Prevention Trials Network [HPTN] 052) also found early initiation of ART associated with decreased risk of HIV transmission to uninfected partners after a median of 1.7 years (RR, 0.11 [95% CI, 0.04 to 0.32] for any transmission and RR, 0.04 [95% CI, 0.005 to 0.27] for virologically-linked transmission).^55^
- Longer (mean, 2.1 years) followup from one of the randomized trials (HPTN 052) included in the prior USPSTF review found initiation of ART at CD4 counts of 350 cells/mm^3^ or greater to less than 550 cells/mm^3^ associated with decreased risk of AIDS-related events versus initiation at CD4 counts less than 250 cells/mm^3^ (RR, 0.65 [95% CI, 0.44 to 0.95]); much of the difference in risk of AIDS-related events was related to effects on tuberculosis.^90^ Effects on all-cause (RR, 0.72 [95% CI, 0.33 to 1.57]) and AIDS-related mortality (RR, 0.25 [95% CI, 0.03 to 2.20]) favored early initiation of ART, but differences were not statistically significant.
- Longer (5.5 years) followup from the HPTN 052 trial also found early ART initiation associated with continued reduction in risk of HIV transmission to uninfected partners (RR, 0.32 [95% CI, 0.19 to 0.53] for any transmission and RR, 0.07 [95% CI, 0.02 to 0.22] for virologically-linked transmission).
- One cohort study published subsequent to the prior USPSTF review found initiation of ART at CD4 counts of 350 to 500 cells/mm^3^ associated with decreased risk of 5-year (RR, 0.87 [95% CI, 0.79 to 0.95]) and 10-year (RR, 0.93 [95% CI, 0.86 to 1.00]) mortality compared with delayed initiation.^88^
- Two RCTs found no association between early initiation of ART and increased risk of cardiovascular events, with one trial showing a potential protective effect (RR, 0.07 [95% CI, 0.004 to 1.24]^89^ and RR, 0.87 [95% CI, 0.40 to 1.88]).^85^

### Evidence

Effects of ART in reducing risk of mortality and AIDS-associated events in persons with advanced immunodeficiency (e.g., CD4 count <200 cells/mm^3^) are well established. The prior USPSTF review focused on effects of ART in persons with less advanced immunodeficiency.^1^ It included one randomized trial conducted in Haiti that found initiation of ART at CD4 counts greater than 200 to less than 350 cells/mm^3^ was associated with decreased risk of mortality versus initiation at CD4 counts of 200 cells/mm^3^ or less (RR, 0.26 [95% CI, 0.11 to 0.63]).^91^ Two trials in the prior USPSTF review found initiation of ART at CD4 counts greater than 350 cells/mm^3^ associated with decreased risk of death or AIDS events compared with initiation at CD4 counts less than 250 cells/mm^3^.^55,89^ A post hoc subgroup analysis of patients infected with HIV (n=477) enrolled in the open-label Strategies for Management of Antiretroviral Therapy (SMART) randomized trial with CD4 counts greater than 350 cells/mm^3^ at baseline (median, 447 cells/mm^3^) found immediate initiation of ART associated with decreased risk of death or AIDS events compared with delayed initiation after a mean of 18 months (RR, 0.31 [95% CI, 0.11 to 0.83]).^89^ The subgroup analysis focused on persons who were ART naïve or had not received ART recently (within 6 months). The SMART trial was conducted in 33 primarily high-income countries and enrolled patients from 2002 to 2006. The open-label HPTN 052 trial, which enrolled 1,763 persons infected with HIV between 2007 and 2010 from primarily low- and middle-income countries with baseline CD4 counts between 350 and 550 cells/mm^3^ (median, 428 to 442 cells/mm^3^), also found immediate initiation of ART associated with decreased risk of the combined endpoint of death or AIDS events after a median of 1.7 years (RR, 0.61 [95% CI, 0.42 to 0.89]).^55^ Results were strongly driven by effects on extrapulmonary tuberculosis (RR, 0.17 [95% CI, 0.05 to 0.59]), with no statistically significant effect on mortality (RR, 0.76 [95% CI, 0.34 to 1.72]). The HPTN 052 trial also found early initiation of ART associated with decreased risk of HIV transmission to partners who were not infected at baseline (RR, 0.11 [95% CI, 0.04 to 0.32] for any transmission and RR, 0.04 [95% CI, 0.005 to 0.27] for virologically-linked transmission). Neither study reported industry funding, other than donation of study drugs in the HPTN 052 trial. The prior USPSTF review also included four observational studies that consistently found an association between initiation of ART at CD4 counts between 350 and 500 cells/mm^3^ and decreased risk of mortality, or a trend toward decreased risk, compared with deferred or no ART (Table 1).^81,82,84,92^ Evidence on initiation of ART at CD4 counts greater than 500 cells/mm^3^ was only available from observational studies and did not consistently demonstrate beneficial effects on clinical outcomes (Table 1).^81–84^ Neither the prior report nor this update found evidence on the effect of early versus later ART initiation on quality of life or function.

Table 1 Cohort Studies of Early vs. Delayed Antiretroviral Therapy

Study | Mortality | AIDS-related events
CASCADE Collaboration 2011^84^; Included in prior report | ≥350 to <500 cells/mm^3^ vs. no treatment initiation; All-cause mortality: HR, 0.51 (95% CI, 0.33 to 0.80); ≥500 cells/mm^3^ vs. no treatment initiation; All-cause mortality: HR, 1.02 (95% CI, 0.49 to 2.12) | ≥350 to <500 cells/mm^3^ vs. no treatment initiation; Progression to AIDS or death: HR, 0.75 (95% CI, 0.49 to 1.14); ≥500 cells/mm^3^ vs. no treatment initiation; Progression to AIDS or death: HR, 1.10 (95% CI, 0.67 to 1.79)
Kitahata 2009^81^; Included in prior report | ≥350 to 500 vs. <350 cells/mm^3^; All-cause mortality: RR, 0.61 (95% CI, 0.46 to 0.83); >500 vs. ≤500 cells/mm^3^; All-cause mortality: RR, 0.54 (95% CI, 0.35 to 0.83) | NR
May 2007^92^; Included in prior report | ≥350 vs <250 cells/mm^3^; All-cause mortality: HR, 0.34 (95% CI, 0.27 to 0.44) | ≥350 vs. <250 cells/mm^3^; Progression to AIDS or death: HR, 0.23 (95% CI, 0.19 to 0.27)
Ray 2010^82^; Included in prior report | 500 vs. 350 cells/mm^3^; All-cause mortality: HR, 0.99 (95% CI, 0.82 to 1.19) | 500 vs. 350 cells/mm^3^; Progression to AIDS or death: HR, 0.72 (95% CI, 0.64 to 0.81)
Sterne 2009^83^; Included in prior report | >450 to 550 vs. ≥350 to 450 cells/mm^3^; All-cause mortality: HR, 0.93 (95% CI, 0.6 to 1.40) | >450 to 550 vs. ≥350 to 450 cells/mm^3^; Progression to AIDS or death: HR, 0.90 (95% CI, 0.76 to 1.29)
Lodi 2015^87^ | ≥500 vs. <500 cells/mm^3^; All-cause mortality: RR, 0.98 (95% CI, 0.97 to 0.99); ≥500 vs. <350 cells/mm^3^; All-cause mortality: RR, 0.94 (95% CI, 0.91 to 0.97) | ≥500 vs. <500 cells/mm^3^; Progression to AIDS or death: RR, 0.94 (95% CI, 0.93 to 0.94); ≥500 vs. <350 cells/mm^3^; Progression to AIDS or death: RR, 0.83 (95% CI, 0.81 to 0.85); Subgroup of patients with baseline CD4 count >500 cells/mm^3^ vs. entire sample; Progression to AIDS or death: 7.1% vs. 4.9%; RR, 1.52 (95% CI, 1.34 to 1.77)
Lodi 2017^95^ | ≥500 vs. <500 cells/mm^3^; All-cause mortality, general HIV population: RR, 0.97 (95% CI, 0.94 to 0.99); All-cause mortality, general HIV population patients with CD4 ≥500 cells/mm^3^: RR, 0.76 (95% CI, 0.58 to 0.97); All-cause mortality, VA population: RR, 0.95 (95% CI, 0.93 to 0.98); ≥500 vs. <350 cells/mm^3^; All-cause mortality, general HIV population: RR, 0.93 (95% CI, 0.87 to 0.98); All-cause mortality, general HIV population patients with CD4 ≥500 cells/mm^3^: RR, 0.64 (95% CI, 0.41 to 0.95); All-cause mortality, VA population: RR, 0.90 (95% CI, 0.85 to 0.95) | NR
Lima 2015^96^ | All-cause mortality, probability (IQR):; CD4 <350 cells/mm^3^, 2007–2012: 0.05 (0.03 to 0.08); CD4 ≥350 cells/mm^3^, 2007–2012: 0.02 (0.01 to 0.04); CD4 <500 cells/mm^3^, 2007–2012: 0.05 (0.03 to 0.02); CD4 ≥500 cells/mm^3^, 2007–2012: 0.01 (0.01 to 0.02) | AIDS-defining illness, probability (IQR):; CD4 <350 cells/mm^3^, 2007–2012: 0.05 (0.03 to 0.08); CD4 ≥350 cells/mm^3^, 2007–2012: 0.03 (0.01 to 0.05); CD4 <500 cells/mm^3^, 2007–2012: 0.03 (0.01 to 0.04); CD4 ≥500 cells/mm^3^, 2007–2012: 0.01 (0.00 to 0.01)
Edwards 2015^88^ | <500 vs. <350 cells/mm^3^; All-cause mortality, 5 years: RR, 0.87 (95% CI, 0.79 to 0.95); - Ages 18 to 34 years: RR, 0.95 (95% CI, 0.79 to 1.15); - Ages 35 to 44 years: RR, 0.93 (95% CI, 0.82 to 1.05); - Ages 45 to 65 years: RR, 0.81 (95% CI, 0.71 to 0.93); All-cause mortality, 10 years: RR, 0.93 (95% CI, 0.86 to 1.00); - Ages 18 to 34 years: RR, 1.00 (95% CI, 0.87 to 1.15); - Ages 35 to 44 years: RR, 0.92 (95% CI, 0.83 to 1.01); - Ages 45 to 65 years: RR, 0.89 (95% CI, 0.80 to 0.99) | NR

Abbreviations: CASCADE=Concerted Action on Seroconversion to AIDS and Death in Europe; CD4=cluster of differentiation 4; CI=confidence interval; HR=hazard ratio; IQR=interquartile range; NR=not reported; RR=relative risk; VA=U.S. Department of Veterans Affairs.

This update focuses on evidence on effects of initiation of ART in persons with CD4 counts greater than 350 cells/mm^3^. We identified longer-term (up to 5.5 years) followup data from the HPTN 052 trial,^90,93^ two new RCTs,^85,86,94^ and three large (n ≥1,000) fair-quality cohort studies (reported in four publications) conducted in the United States, Europe, and Canada^87,88,95,96^ on effects of initiating ART at higher versus lower CD4 counts (Table 2; Appendix B Tables 1–6).

Table 2 Characteristics of Studies Published Since the Prior USPSTF Review of Immediate vs. Delayed Antiretroviral Therapy

Study design | Study name Author, year Duration Geographic setting N | Intervention groups | Population
RCT | START; Lundgren 2015^85^; 3 years; Africa, Europe, Israel, North America, South America, Mexico, Australia; n=4,685 | A. Immediate ART (n=2,326): CD4 >500 cells/mm^3^; B. Deferred ART (n-2,359): CD4 <350 cells/mm^3^ | A vs. B; Mean age 36 vs. 36 years; 27% vs. 27% female; 9% vs. 8% Asian; 30% vs. 30% black; 14% vs. 14% Latino/Hispanic; 44% vs. 45% white; 4% vs. 3% other; CD4 count (median): 651 vs. 651 cells/mm^3^
RCT | HPTN 052; Grinsztejn 2014^90^; 2 to 5.5 years^*^; Botswana, Brazil, India, Kenya, Malawi, South Africa, Thailand, United States, Zimbabwe; n=1,763 | A. Immediate ART (n=886): CD4 ≥350 to <550 cells/mm^3^; B. Delayed ART (n=877): CD4 ≤250 cells/mm^3^ | A vs. B; Mean age <25 years 13% vs. 13%; 25 to 39 years, 64% vs. 64%; ≥40 years, 24% vs. 23%; 49% vs. 50% female; Race NR; 16% vs. 15% South America; 30% vs. 30% Africa; 54% vs. 55% Asia; CD4 count: 442 vs. 428 cells/mm^3^
RCT | TEMPRANO ANRS 12136 Study; TEMPRANO ANRS Study Group 2015^86^; 30 months; Ivory Coast; n=2,076 | A. Early ART (n=1,033): Immediate ART initiation upon study enrollment; B. Delayed ART (n=1,023): ART initiation according to the following criteria:; - From March 1, 2008 to November 30, 2009, the criteria for ART initiation were: one CD4 count <200 cells/mm^3^ or WHO clinical stage 4; or one CD4 count 200 to 350 cells/mm^3^ and WHO clinical stage 2 or 3.; - From December 1, 2009 to July 31, 2013, the criteria for ART initiation were: two consecutive CD4 counts <350 cells/mm^3^ regardless of WHO clinical stage; or WHO clinical stage 3 or 4.; - From August 1, 2013 to study cessation, two consecutive CD4 counts <350 cells/mm^3^, regardless of WHO clinical stage; or WHO clinical stage 3 or 4; or ART may be proposed to persons who have not yet reached the WHO criteria, if their partner is known to be HIV seronegative | A vs. B; Median age 35 vs. 35 years; 80% vs. 77% female; Race NR; study conducted in Africa; CD4 count 459 (IQR, 359 to 575) vs. 466 cells/mm^3^ (IQR, 369 to 584)
Cohort | HIV CAUSAL Collaboration; Lodi 2015^87^; France, Greece, The Netherlands, Spain, Switzerland, United Kingdom, United States; 7 years; n=55,826 | A. Initiation of ART at ≥500 cells/mm^3^; B. Initiation of ART at <500 cells/mm^3^; C. Initiation of ART at <350 cells/mm^3^ | A vs. B; Mean age 35 (IQR, 28 to 44) vs. 38 years (IQR, 31 to 46); 22% vs. 24% female; 30% vs. 40% heterosexual; 56% vs. 44% homosexual or bisexual; 2% vs. 3% PWID; 11% vs 14% other/unknown 78% vs. 67% Western country; 11% vs. 20% sub-Saharan Africa; 8% vs. 9% rest of the world; 4% vs. 5% unknown
Cohort | HIV CAUSAL Collaboration; Lodi 2017^95^; Brazil, Canada, France, Greece, The Netherlands, Spain, Switzerland, United Kingdom, United States; 5 years; n=9,599 | A. Initiation of ART at ≥500 cells/mm^3^; B. Initiation of ART at <500 cells/mm^3^; C. Initiation of ART at <350 cells/mm^3^ | Data not stratified according to intervention group; General HIV population; Age 55 years (IQR, 52 to 59); 21% female; 45% heterosexual; 43% homosexual; 2% PWID; 9% unknown 63% Western country; 6% sub-Saharan Africa; 9% rest of the world; 22% unknown; CD4 count (cells/mm^3^): 12% <100; 13% 100 to 200; 25% 200 to 349; 22% 350 to 499; 29% ≥500; HIV RNA: 23% <10,000; 41% 10,000 to 100,000; 36% >100,000 log_10_ copies/mL; VA population; Age 56 years (IQR, 53 to 60); 2% female; CD4 count (cells/mm^3^): 20% <100; 16% 100 to 200; 23% 200 to 349; 19% 350 to 499; 22% ≥500; HIV RNA: 26% <10,000; 47% 10,000 to 100,000; 27% >100,000 log_10_ copies/mL
Cohort | Lima 2015^96^; Canada; 5 years; n=4,120 | A. Initiation of ART at ≥500 cells/mm^3^; B. Initiation of ART at <500 cells/mm^3^; C. Initiation of ART at ≥350 cells/mm^3^; D. Initiation of ART at <350 cells/mm^3^ | Data not stratified according to intervention group; Mean age 42 years (IQR, 35 to 49); 20% female; Race/ethnicity NR; 36% history of PWID; CD4 count (cells/mm^3^): 44% <200; 32% 200 to 349; 14% 350 to 499; 10% ≥500
Cohort | Edwards 2015^88^; United States; 10 years; n=3,532 | A. Initiation of ART at <500 cells/mm^3^; B. Initiation of ART at <350 cells/mm^3^ | Data not stratified according to intervention group; Mean age NR; 49% 18 to 34 years; 32% 35 to 44 years; 19% 45 to 65 years; 18% female; 9% Hispanic; other race/ethnicity NR; MSM: 67%; PWID: 17%; Median CD4 count 646 cells/mm^3^

* Duration varied according to outcome; 1.7-year results from HPTN 052 trial included in prior report.

Abbreviations: ANRS=Agence Nationale de Recherche sur le SIDA; ART=antiretroviral therapy; CD4=cluster of differentiation 4; HTPN=HIV Prevention Trials Network; NR=not reported; IQR=interquartile range; MSM=men who have sex with men; PWID=persons who inject drugs; RCT=randomized, controlled trial; RNA=ribonucleic acid; START=Strategic Timing of Antiretroviral Treatment; USPSTF=U.S. Preventive Services Task Force; VA=U.S. Department of Veterans Affairs; WHO=World Health Organization.

The new International Network for Strategic Initiatives in Global HIV Trials Strategic Timing of Antiretroviral Treatment (INSIGHT START, or START) trial (n=4,685) randomized ART-naïve, HIV-positive participants with CD4 counts greater than 500 cells/mm^3^ (median, 651 cells/mm^3^) at baseline to immediate initiation of ART versus deferred initiation at CD4 counts less than 350 cells/mm^3^.^85^ Randomization occurred between 2009 and 2013. Mean age was 36 years and 26 percent of participants were female. START was an international study, with about half of participants enrolled from high-income geographic regions (United States, Europe, and Australia). Mean duration of followup was 3 years. The other new RCT, the African TEMPRANO ANRS 12136 trial (n=2,056), enrolled persons between 2008 and 2012 with baseline CD4 counts less than 800 cells/mm^3^ without an indication for ART, based on then-current World Health Organization (WHO) guidelines.^86^ Followup was 2.5 years. A prespecified subgroup analysis was conducted in persons with a CD4 count of 500 cells/mm^3^ or greater at baseline (~40% of trial population). About three-quarters of participants were women. TEMPRANO ANRS 12136 utilized a 2×2 factorial design in which patients were randomized to isoniazid versus no isoniazid and to immediate or delayed initiation of ART; in addition, the treatment initiation thresholds for delayed ART varied over the course of the study, based on changing WHO guidance. At the beginning of the trial, criteria for delayed initiation of ART were a CD4 count less than 200 cells/mm^3^, WHO clinical stage 4, or a CD4 count of 200 to 350 cells/mm^3^ and WHO clinical stage 2 or 3. At the end of the trial, the criteria were a CD4 count less than 350 cells/mm^3^ regardless of WHO clinical stage, WHO clinical stage 2 or 3, or any CD4 count in patients with a seronegative partner (Table 2). Both the START and TEMPRANO ANRS 12136 trials evaluated a composite primary outcome consisting of mortality, AIDS-defining events, and serious non-AIDS events (e.g., bacterial infection, cancer); neither trial evaluated effects on quality of life, function, risk of HIV transmission, or other STIs. Neither of the new trials reported industry funding, other than donation of study drugs in the START trial. The START trial was rated good quality and TEMPRANO ANRS 12136 was rated fair quality due to open-label design and changing criteria for delayed initiation of ART. The HPTN 052 trial was previously rated good-quality (Appendix B Table 3).^1^

In the three new fair-quality cohort studies, sample sizes ranged from 3,532 to 55,826 (total n=63,478) (Table 2; Appendix B Tables 4–6).^87,88,95,96^ Two publications were based on data from the large HIV Cohorts Analyzed Using Structural Approaches to Longitudinal (HIV CAUSAL) Collaboration (n=55,826).^87,95^ HIV CAUSAL is a collaboration of 12 cohort studies in the United States and Europe with more than 70,000 participants (mean age, 35 years). Three-year data from the HIV CAUSAL Collaboration were included in the prior USPSTF report.^82^ New publications from the HIV CAUSAL Collaboration report 7-year outcomes^87^ and subgroup analyses for adults older than age 50 years.^95^ The other two studies evaluated cohorts from Canada (n=4,120; mean age, 42 years)^96^ and the United States (n=3,532; approximately half of subjects ages 18 to 34 years).^88^ All studies reported analyses adjusted for confounders, most commonly age, sex, and HIV viral load at baseline, and focused on effects of ART on mortality and AIDS-associated events.

#### Immediate Versus Delayed Initiation of ART in Persons With Baseline CD4 Counts Greater Than 500 cells/mm^3^

In the prior review, evidence on effects of initiating ART at CD4 counts greater than 500 cells/mm^3^ versus delayed initiation was limited to observational studies and inconsistent in showing beneficial effects.^81–84^ Two new RCTs found early initiation of ART associated with beneficial effects on clinical outcomes in this population (Table 3; Appendix B Table 2).^85,86^ In the START trial, immediate initiation of ART in persons with CD4 counts greater than 500 cells/mm^3^ at baseline was associated with decreased risk of the primary composite outcome of all-cause mortality, serious AIDS-related events, and serious non–AIDS-related events after a mean of 3 years (1.8% vs. 4.1%; RR, 0.44 [95% CI, 0.31 to 0.63]; adjusted risk difference [ARD], -2.3% [95% CI, -3.2 to -1.3]), compared with delayed initiation at CD4 counts less than 350 cells/mm^3^.^85^ When outcomes were disaggregated, immediate initiation of ART was associated with reduced risk of serious AIDS-related events (0.6% vs. 2.1%; RR, 0.28 [95% CI, 0.16 to 0.51]; ARD, -1.52% [95% CI, -2.18 to -0.86]), tuberculosis (0.3% vs. 0.8%; RR, 0.30 [95% CI, 0.12 to 0.76]; ARD,-0.59% [95% CI, -1.01 to -0.17]), and serious bacterial infection (0.6% vs. 1.5%; RR, 0.39 [95% CI, 0.21 to 0.73]; ARD, -0.92% [95% CI, -1.51 to -0.34]). Effects on all-cause mortality (0.5% vs. 0.9%; RR, 0.58 [95% CI, 0.29 to 1.18]) and AIDS-related mortality (0.04% vs. 0.2%; RR, 0.25 [95% CI, 0.03 to 2.27]) favored immediate initiation of ART, but effects were not statistically significant and there were only 5 cases of AIDS-related mortality (Table 3).^85^ Results for the primary outcome were similar when patients were stratified according to whether they were from a high- or low-income geographic region (HR, 0.39 vs. 0.48; p=0.55 for interaction), and in subgroup analyses based on age (older or younger than age 35 years), sex, race/ethnicity, baseline HIV viral load, smoking status, and Framingham 10-year cardiovascular risk. In the TEMPRANO ANRS 12136 trial, in a prespecified subgroup analysis of patients with CD4 counts of 500 cells/mm^3^ or greater at baseline, immediate initiation of ART was associated with decreased risk of the primary composite outcome of all-cause mortality, progression to AIDS, AIDS-defining cancer, or non–AIDS-defining invasive bacterial disease after 2.5 years (5.3% vs. 9.2%; RR, 0.57 [95% CI, 0.35 to 0.95]; ARD, -3.9% [95% CI, -7.4 to -0.4]).^86^ Effects on all-cause mortality (1.1% vs. 1.5%; RR, 0.79 [95% CI, 0.24 to 2.57]), progression to AIDS (3.2% vs. 5.8%; RR, 0.55 [95% CI, 0.29 to 1.05]), tuberculosis (2.8% vs. 5.1%; RR, 0.54 [95% CI, 0.27 to 1.09]) and invasive bacterial disease (1.1% vs. 1.9%; RR, 0.59 [95% CI, 0.20 to 1.80]) also favored immediate initiation of ART, but effects were not statistically significant (Table 3). Results were similar when adjusted for study center and concomitant isoniazid use (Appendix B Table 2).

Table 3 Randomized, Controlled Trials of Immediate vs. Delayed Antiretroviral Therapy

Baseline CD4 count | Study name | Primary composite outcome | Mortality | AIDS-related events | Tuberculosis or bacterial infection | HIV transmission
>500 cells/mm^3^ | START^85^ | All-cause mortality, serious AIDS-related events, and serious non–AIDS-related events: RR, 0.44 (95% CI, 0.31 to 0.63) | All-cause mortality: RR, 0.58 (95% CI, 0.29 to 1.18); Mortality due to AIDS-related event: RR, 0.25 (95% CI, 0.03 to 2.27) | Serious AIDS-related event: RR, 0.28 (95% CI, 0.16 to 0.51) | Tuberculosis: RR, 0.30 (95% CI, 0.12 to 0.76); Grade 4 bacterial infection: RR, 0.39 (95% CI, 0.21 to 0.73) | NR
>500 cells/mm^3^ | TEMPRANO ANRS^86^ | All-cause mortality, progression to AIDS, AIDS-defining cancer, or non–AIDS-defining invasive bacterial disease: RR, 0.57 (95% CI, 0.35 to 0.95) | All-cause mortality: RR, 0.79 (95% CI, 0.24 to 2.57) | Progression to AIDS: RR, 0.55 (95% CI, 0.29 to 1.05) | Tuberculosis: RR, 0.54 (95% CI, 0.27 to 1.09); Invasive bacterial disease: RR, 0.59 (95% CI, 0.20 to 1.80) | NR
≥350 to 550 cells/mm^3^ | HPTN 052, 2011^*^,^55,90^ | All-cause mortality, serious AIDS-related events, and serious non–AIDS-related events: RR, 0.73 (95% CI, 0.53 to 1.02) | All-cause mortality, 1.7-year followup: RR, 0.76 (95% CI, 0.34 to 1.73); All-cause mortality, 2.1-year followup: RR, 0.72 (95% CI, 0.33 to 1.57); Mortality due to AIDS-related event: RR, 0.25 (95% CI, 0.03 to 2.20) | Any AIDS-related event: RR, 0.65 (95% CI, 0.4 to 0.95) | Tuberculosis: RR, 0.49 (95% CI, 0.28 to 0.88); Serious bacterial infection: RR, 1.52 (95% CI, 0.76 to 3.04) | Any HIV transmission, 1.7-year followup: RR, 0.11 (95% CI, 0.04 to 0.32); 5.5-year followup: RR, 0.32 (95% CI, 0.19 to 0.53); Linked HIV transmission, 1.7-year followup: RR, 0.04 (95% CI, 0.005 to 0.27); 5.5-year followup: RR, 0.07 (95% CI, 0.02 to 0.22)
≥350 to 500 cells/mm^3^ | SMART^*^,^89^ | All-cause mortality or opportunistic disease: RR, 0.31 (95% CI, 0.11 to 0.83) | All-cause mortality: RR, 0.26 (95% CI, 0.05 to 1.25) | Any opportunistic disease: RR, 0.33 (95% CI, 0.11 to 1.03) | Tuberculosis: RR, 0.46 (95% CI, 0.04 to 5.02) | NR

* Included in prior USPSTF report.

Abbreviations: ANRS=Agence Nationale de Recherche sur le SIDA; CD4=cluster of differentiation 4; CI=confidence interval; HPTN=HIV Prevention Trials Network; NR=not reported; RR=relative risk; SMART=Strategies for Managment of Antiretroviral Therapy; START=Strategic Timing of Antiretroviral Treatment.

Results from cohort studies published subsequent to the prior USPSTF report were consistent with the RCTs in showing effectiveness of initiating ART at CD4 counts greater than 500 cells/mm^3^. An analysis of the HIV CAUSAL Collaboration (n=55,826; median baseline CD4 count, 376 cells/mm^3^) found ART initiation at CD4 counts less than 350 cells/mm^3^ associated with increased risk of all-cause mortality (4.2% vs. 4.0%; RR, 1.06 [95% CI, 1.03 to 1.10]) or the composite endpoint of progression to AIDS or death (8.5% vs. 7.1%; RR, 1.20 [95% CI, 1.17 to 1.23]) after 7 years, compared with initiation of ART at CD4 counts greater than 500 cells/mm^3^ (Table 1; Appendix B Table 5), although effects were smaller than those observed in the START and TEMPRANO ANRS 12136 trials.^87^ Effects of immediate initiation of ART were stronger in the subgroup of patients with baseline CD4 counts greater than 500 cells/mm^3^ (7.1% vs. 4.9%; RR, 1.52 [95% CI, 1.34 to 1.77]). Analyses were adjusted for CD4 count, HIV-ribonucleic acid viral load, AIDS diagnosis, age, HIV risk group, sex, geographical origin, and racial/ethnic origin. Results were similar in a subgroup analysis from HIV CAUSAL of patients older than age 50 years.^95^ Another cohort study (n=4,120) reported the probability of death or AIDS-related illness with use of early versus delayed ART, according to CD4 count and period of ART initiation (2000–2006 or 2007–2012) (Table 1; Appendix B Table 5).^96^ From 2007 to 2012, initiation of ART at CD4 counts of 500 cells/mm^3^ or greater was associated with lower probability of mortality (0.01; interquartile range [IQR], 0.01 to 0.02) and AIDS-related morbidity (0.01; IQR, 0.00 to 0.01) than initiation at CD4 counts less than 500 cells/mm^3^ (probability, 0.05; IQR, 0.03 to 0.08 and 0.03, IQR, 0.01 to 0.04, for mortality and AIDS-related mortality, respectively) or less than 350 cells/mm^3^ (probability, 0.05, 0.03 to 0.08 and 0.05, IQR, 0.03 to 0.08, for mortality and AIDS-related mortality, respectively). From 2000 to 2006, patients with ART initiation at CD4 counts of 500 cells/mm^3^ or greater had a slightly higher probability of mortality than those with CD4 counts less than 500 cells/mm^3^ (0.16 vs. 0.13), although the probability of AIDS-related illness remained lower (0.02 vs. 0.04). Analyses were based on a small number of patients (n=50) with CD4 counts of 500 cells/mm^3^ or greater.

#### Immediate Versus Delayed Initiation of ART in Persons With Baseline CD4 Counts of 350 or Greater to 500 or 550 cells/mm^3^

The prior USPSTF review included two randomized trials (HPTN 052 and a subgroup analysis from SMART) that found initiation of ART in patients infected with HIV with CD4 counts greater than 350 cells/mm^3^ associated with decreased risk of mortality or AIDS events compared with delayed initiation at CD4 counts less than 250 cells/mm^3^ after 18 to 19 months; the HPTN 052 trial also found early initiation of ART associated with decreased risk of HIV transmission to an uninfected partner (Table 3).^55,89^ There was also consistent evidence from four observational studies of an association between initiation of ART at CD4 counts between 350 and 500 cells/mm^3^ and decreased risk of mortality, or trend toward decreased risk, compared with deferred initiation or no ART (Table 1).^81,82,84,92^

Longer-term followup from the HPTN 052 trial (n=1,763) is now available (Table 3; Appendix B Table 2).^90,93^ At mean followup of 2.1 years, initiation of ART at CD4 counts of 350 cells/mm^3^ or greater to less than 550 cells/mm^3^ was associated with decreased risk of AIDS-related events (4.5% vs. 7.0%; RR, 0.65 [95% CI, 0.44 to 0.95]); much of the difference in risk of AIDS-related events was due to effects on tuberculosis (1.9% vs. 3.9%; RR, 0.49 [95% CI, 0.28 to 0.88]). Effects on the primary composite outcome (death, serious AIDS events, and serious non-AIDS events) (6.4% vs. 8.8%; RR, 0.73 [95% CI, 0.53 to 1.02]), all-cause mortality (1.2% vs. 1.7%; RR, 0.72 [95% CI, 0.33 to 1.57]), and AIDS-related mortality (0.1% vs 0.5%; RR, 0.25 [95% CI, 0.03 to 2.20]) favored early initiation of ART, but effects were not statistically significant. After 5.5 years, the HPTN 052 trial found early initiation of ART remained associated with decreased risk of any HIV transmission to uninfected partners (2.1% vs. 6.6%; RR, 0.32 [95% CI, 0.19 to 0.53]) as well as virologically-linked transmission (0.3% vs. 4.9%; RR, 0.07 [95% CI, 0.02 to 0.22]); almost all of the reduction in transmission risk was due to fewer virologically-linked cases (Table 3; Appendix B Table 2).^93^

A new U.S.-based cohort study (n=3,532) found that compared with initiation of ART at CD4 counts less than 500 cells/mm^3^, initiation at less than 200 cells/mm^3^ was associated with greater risk of 10-year all-cause mortality (RR, 1.25 [95% CI, 1.08 to 1.44]) than initiation at less than 350 cells/mm^3^ (RR, 1.08 [95% CI, 1.00 to 1.16]) (Table 1; Appendix B Table 5).^88^ However, the CIs for the risk estimates overlapped and there was no test for statistical significance for the difference. Risk estimates were generally similar for 5-year mortality and consistent across age groups.

#### Harms of Immediate Versus Delayed Initiation of ART

Two RCTs found no evidence of an increased risk of cardiovascular events with early versus delayed initiation of ART, although data were limited by small numbers of events. In the SMART trial subgroup of patients who were ART-naïve or not recently on ART, there was no statistically significant difference in risk of cardiovascular events between initiation at a CD4 count greater than 350 cells/mm^3^ versus initiation at less than 250 cells/mm^3^, but there were few events and the estimate was imprecise (0% vs. 2.4%; RR, 0.07 [95% CI, 0.004 to 1.24]).^89^ However, an analysis of the entire SMART cohort (including persons currently or recently on ART) found continuous use of ART associated with decreased risk of fatal or nonfatal cardiovascular disease compared with episodic use (initiate at CD4 count <250 cells/mm^3^ and discontinue when CD4 count >350 cells/mm^3^) (1.1% vs. 1.8%; RR, 0.64 [95% CI, 0.41 to 1.0]). In the START trial, there was also no clear difference between early and delayed initiation of ART in risk of cardiovascular disease (0.5% vs. 0.6%; RR, 0.87 [95% CI, 0.40 to 1.88]).^85^ The START, HPTN 052, and TEMPRANO ANRS 12136 trials also found no clear differences between early versus delayed initiation of ART and risk of other harms, such as liver disease, renal disease, and new-onset diabetes (Appendix B Table 2).^85,86,90^ However, few adverse events were reported and some risk estimates were imprecise.

## Key Question 5 What Are the Longer-Term Harms (2 Years or More) Associated With Currently Recommended ART Regimens?

### Summary

- The prior USPSTF report found mixed evidence on the risk of long-term cardiovascular events with abacavir use based on four studies,^97–100^ and no evidence of increased risk of cardiovascular events with efavirenz use.^97^
- A meta-analysis of 26 trials (total n=9,868) published since the prior report found no association between ART containing abacavir versus ART without abacavir and risk of myocardial infarction (risk difference, 0.008% [95% CI, -0.26 to 0.27]).^101^ This conflicts with longer-term (median, 7.0 years) followup from the large (n=49,717) D:A:D (Data Collection on Adverse Events of Anti-HIV Drugs) observational study, which found abacavir use associated with increased risk of myocardial infarction (RR, 1.98 [95% CI, 1.72 to 2.29]),^102^ and another cohort study, which found abacavir use associated with increased risk of cardiovascular events (odds ratio [OR], 1.50 [95% CI, 1.26 to 1.79]).^103^
- The D:A:D study found no association between long-term (>3 years) exposure to the protease inhibitor atazanavir and risk of myocardial infarction (RR, 0.95 [95% CI, 0.87 to 1.05]) or stroke (RR, 0.95 [95% CI, 0.87 to 1.05]).^104^ Another cohort study found efavirenz, lamivudine, and zidovudine associated with increased risk of cardiovascular events (OR range, 1.40 to 1.53).^103^
- A systematic review of 42 randomized and quasirandomized trials (n=8466 exposed to efavirenz; mean duration, 78 weeks) found efavirenz associated with an increased risk of severe neuropsychiatric adverse events versus ritonavir-boosted atazanavir (RR, 2.4 [95% CI, 1.5 to 3.8]), dolutegravir (RR, 16.7 [95% CI, 2.0 to 137.8]), and maraviroc (RR, 5.3 [95% CI, 1.6 to 18.1]).^105^
- Three observational studies, including D:A:D, found no association between use of efavirenz and death from suicide or suicidal ideation.^106–108^
- A D:A:D analysis found longer exposure to ART associated with lower risk of AIDS-defining cancer (rate ratio, 0.88/year [95% CI, 0.85 to 0.92]).^109^ Protease inhibitor use but not non-NRTI use was associated with higher risk of non–AIDS-defining cancer (rate ratio, 1.03/year [95% CI, 1.01 to 1.05]).
- A D:A:D analysis found long-term tenofovir disoproxil fumarate (TDF) (relative rate, 1.46 [95% CI, 1.11 to 1.93]) use associated with increased risk of end-stage liver disease or hepatocellular carcinoma, and emtricitabine associated with decreased risk (relative rate, 0.51 [95% CI, 0.32 to 0.83]).^110^
- A D:A:D analysis found an association between use of TDF (rate ratio, 1.14 per year of exposure [95% CI, 1.10 to 1.19]) or ritonavir-boosted atazanavir (rate ratio, 1.20 per year of exposure [95% CI, 1.13 to 1.26]) and increased risk of chronic kidney disease;^111^ other observational studies also found TDF and protease inhibitors associated with increased risk of renal adverse events.
- A cohort study found ever use of TDF associated with increased risk of fracture (incidence rate ratio [IRR], 1.40 [95% CI, 1.15 to 1.70]), but no association between cumulative exposure to TDF and risk of fracture (IRR per 5 years of exposure, 1.08 [95% CI, 0.94 to 1.25]).^112^

### Evidence

The prior USPSTF review included analyses from the D:A:D study (a large [n >49,000] ongoing international study of 11 prospective cohorts from Europe, Australia, and the United States that began enrolling patients in 1999)^97,113,114^ and three other cohort studies on cardiovascular harms associated with ART after 4 to 6 years of followup.^98–100^ In the D:A:D study, longer exposure to the protease inhibitors indinavir alone, ritonavir-boosted indinavir, and ritonavir-boosted lopinavir were each associated with increased risk of myocardial infarction compared with nonuse (adjusted RR per year of exposure, 1.1 to 1.2).^97^ However, these protease inhibitors are no longer recommended for use in ART regimens, and no other protease inhibitor was associated with increased myocardial infarction risk. The prior UPSTF review found mixed evidence on the association between NRTI use and risk of myocardial infarction. Two studies, including the D:A:D study, found abacavir exposure associated with increased risk of myocardial infarction (adjusted RR, 1.7 and 2.0),^97,99^ but two other studies found no association (adjusted HR, 0.6 and 1.2).^98,100^ There was no association between use of other NRTIs or the non-NRTI efavirenz and increased risk of cardiovascular events.^97^

Since the prior USPSTF review, we identified two new RCTs on longer-term harms of TDF,^115^ raltegravir, and efavirenz.^116^ There is also new evidence on cardiovascular risks from a meta-analysis of randomized trials of abacavir,^101^ longer-term followup data from the D:A:D study,^102,104^ and an analysis of Veterans Health Administration (VHA) data^103^ (Table 4). Other new evidence on longer-term harms include a systematic review,^105^ a D:A:D analysis,^107^ and two cohort studies^106,108^ on the association between efavirenz and neuropsychiatric adverse events, as well as analyses from D:A:D and other large cohort studies on risk of cancer,^109^ liver disease,^110,117^ renal adverse events,^110,111,118,119^ fracture,^112,120^ and non–AIDS-related deaths^121^ (Appendix B Tables 7–14).

Table 4 New Studies on the Association Between Antiretroviral Therapy and Long-Term Cardiovascular Harms

Author, Year Study Quality | Study details N Overall duration of followup | Intervention | Results
D:A:D Study Monforte, 2013^104^; Good | Prospective analysis of 11 cohorts; Europe, Australia, and United States; N=49,734; Participants were followed for a total of 301,907 person-years of followup for MI, and 303,118 person-years of followup for stroke | ATV, boosted or unboosted by RTV | MI:; Overall events: 844/49,734; incidence, 0.28/100 person-years followup (95% CI, 0.26 to 0.30); >3 years exposure to ATV: 0.20 (95% CI, 0.12 to 0.32)/100 person-years followup; No exposure to ATV: 0.28 (95% CI, 0.26 to 0.30)/100 person-years followup; No association between cumulative exposure to ATV and MI risk: univariate relative rate/year, 0.96 (95% CI, 0.88 to 1.04); multivariable relative rate/year, 0.95 (95% CI, 0.87 to 1.05); Stroke:; Overall events: 523/49,734, incidence 0.18/100 person years follow up, 95% CI 0.16 to 0.19; >3 years exposure to ATV: 0.17 (95% CI 0.10 to 0.27)/100 person years followup; No exposure to ATV: 0.17 (95% CI 0.16 to 0.19)/100 person years follow up; No association between cumulative exposure to ATV and stroke risk: univariate relative rate/year: 1.02 (95% CI 0.98 to 1.05), multivariable relative rate/year: 0.95 (95% CI 0.87 to 1.05)
D:A:D Study Sabin, 2016^102^; Good | Prospective analysis of 11 cohorts; Europe, Australia, United States; N=49,717; Median followup: 7 years | ABC vs. non-ABC | MI:; After adjustment for potential confounders, current ABC use was associated with a 98% increase in MI rate (aRR, 1.98 [95% CI, 1.72 to 2.29]), with no difference in the pre-2008 (aRR, 1.97 [95% CI, 1.68 to 2.33]) and post-2008 (aRR, 1.97 [95% CI, 1.43 to 2.72]) periods; p=0.74 for interaction; Overall: 941/367,559 person-years (rate, 0.26 [95% CI, 0.24 to 0.27])/100 person-years; Currently on ABC: 341/71,971 person-years (rate, 0.47 [95% CI, 0.42 to 0.52])/100 person-years; Currently not on ABC: 600/295,642 person-years (rate, 0.20 [95% CI, 0.19 to 0.22])/100 person-years; Stratified by calendar period (D:A:D publication from 2008 showed 90% increase in risk of MI for patients on ABC); Pre-March 2008:; Currently on ABC: 247/40,833 person-years (rate, 0.61 [95% CI, 0.53 to 0.68])/100 person-years; Currently not on ABC: 425/169,417 person-years (rate, 0.25 [95% CI, 0.23 to 0.28])/100 person-years; Post-March 2008; Currently on ABC: 94/31,084 person-years (rate, 0.30 [95% CI, 0.24 to 0.36])/100 person-years; Currently not on ABC: 175/126,225 person-years (rate, 0.14 [95% CI, 0.12 to 0.16])/100 person-years; Results unchanged after stratifying by Framingham risk group or after further adjusting for factors potentially on the causal pathway, including renal function, dyslipidemia, and hypertension
Desai 2015^103^ | Retrospective analysis of VA data; N=24,510; Mean duration of followup varied according to study drug (results for interventions with <2 years followup not shown) | Current ART exposure vs. nonexposure | Cardiovascular event (MI, stroke, or cardiovascular procedure); ABC: OR, 1.50 (95% CI, 1.26 to 1.79); EFV: OR, 1.40 (95% CI, 1.19 to 1.66); 3TC: OR, 1.53 (95% CI, 1.34 to 1.75); NVP: OR, 0.91 (95% CI, 0.70 to 1.18); D4T: OR, 1.14 (95% CI, 0.95 to 1.37); Tenofovir: OR, 1.10 (95% CI, 0.93 to 1.30); ZDV: OR, 1.41 (95% CI, 1.22 to 1.63)
Ding, 2012^101^; U.S. Food and Drug Administration; Fair | Systematic review of 26 RCTs included in meta-analysis; N=9,868; Mean followup (ABC vs. non-ABC): 1.43 vs. 1.49 person-years | ABC vs. non-ABC | MI events:; Overall: 0.48% (24/5,028) vs. 0.46% (22/4,840); RD, 0.008% (95% CI, -0.26% to 0.27%); OR, 1.02 (95% CI, 0.56 to 1.84); Glaxo-Smith Kline trials: 0.26% (6/2,341) vs. 0.38% (9/2,367); RD, -0.11% (95% CI, 0.43% to 0.21%); OR, 0.70 (95% CI, 0.25 to 2.00); AIDS Clinical Trials Group trials: 0.60% (12/1,985) vs. 0.89% (9/1,016); RD, 0.03% (95% CI, -0.45% to 0.51%); OR, 1.06 (95% CI, 0.43 to 2.61); Other trials: 0.85% (6/702) vs. 0.46% (4/863); RD, 0.31% (95% CI, -0.53% to 1.16%); OR, 1.60 (95% CI, 0.46 to 5.62)

Abbreviations: 3TC=lamivudine; ABC=abacavir; aRR=adjusted rate ratio; ART=antiretroviral therapy; ATV=atazanavir; CI=confidence interval; D4T=stavudine; D:A:D=Data Collection on Adverse Events of Anti-HIV Drugs; EFV=efavirenz; MI=myocardial infarction, NVP=nevirapine; OR=odds ratio; RCT=randomized, controlled trial; RD=risk difference; RTV=ritonavir; VA=U.S. Department of Veterans Affairs; ZDV=zidovudine.

Both new RCTs were rated as good quality. We previously rated the D:A:D study as good quality; other studies of harms had methodological shortcomings, including not reporting whether outcome assessors, data analysts, or both were blinded to the exposure being studied and high attrition rates, and were rated as fair quality (Appendix B Tables 9 and 12–14).

#### Cardiovascular Events

Two good-quality RCTs published since the prior USPSTF review evaluated serious cardiovascular or cerebrovascular events with tenofovir alafenamide versus TDF, each coformulated with elvitegravir, cobicistat, and emtricitabine (duration, 144 weeks),^115^ or raltegravir versus efavirenz, each in combination with TDF/emtricitabine (duration, 5 years) (Appendix B Tables 10 and 11).^116^ Neither trial found any difference between ART regimens in risk of cardiovascular events.

As in the prior USPSTF review, new evidence on the association between abacavir use and risk of cardiovascular events was somewhat inconsistent (Table 4). A meta-analysis conducted by the U.S. Food and Drug Administration of 26 randomized trials (total n=9,868) found no association between ART with versus without abacavir and risk of myocardial infarction (0.48% vs. 0.46%; risk difference, 0.008% [95% CI, -0.26 to 0.27]) after a mean of approximately 1.5 years.^101^ However, longer-term (median, 7.0 years) followup from the D:A:D study (n=49,717) was consistent with prior (5 to 6 year) analyses from D:A:D in finding an association between abacavir use and increased risk of myocardial infarction after adjustment for demographic factors, cardiovascular risk factors, and other potential confounders (RR, 1.98 [95% CI, 1.72 to 2.29]).^102^ The association remained present whether abacavir was initiated before or after March 2008, despite data indicating a trend over time toward decreased use of abacavir in persons at higher cardiovascular risk. A cohort study (n=24,510) of VHA data also found abacavir use increased the risk of combined cardiovascular events (myocardial infarction, stroke, or cardiovascular procedure) after 2.2 years (OR, 1.50 [95% CI, 1.26 to 1.79]).^103^

An analysis of the D:A:D cohort (n=49,734) published subsequent to the prior USPSTF review found no association between exposure to the protease inhibitor atazanavir for more than 3 years and risk of myocardial infarction (RR, 0.95 [95% CI, 0.87 to 1.05]) or stroke (RR, 0.95 [95% CI, 0.87 to 1.05]).^104^ In a VHA cohort, efavirenz (2.2 years followup; OR, 1.40 [95% CI, 1.19 to 1.66]), lamivudine (3.4 years followup; OR, 1.53 [95% CI, 1.34 to 1.75]), and zidovudine (2.6 years followup; OR, 1.41 [95% CI, 1.22 to 1.63]) were each associated with increased risk of a composite cardiovascular outcome (myocardial infarction, stroke, or cardiovascular procedure).^103^ For other antiretrovirals, there was no association with risk of cardiovascular events or duration of followup was less than 2 years.

#### Neuropsychiatric Adverse Events

The non-NRTI efavirenz has recently been linked to neuropsychiatric adverse events, including depression and suicidal ideation.^122^ A systematic review of 42 randomized and quasirandomized trials (n=8,466 exposed to efavirenz; mean duration, 78 weeks) reported neuropsychiatric adverse events of any grade in 29.6% (95% CI, 21.9 to 37.3) of patients prescribed efavirenz.^105^ The most frequent neuropsychiatric adverse events were dizziness (12.8% [95% CI, 9.1 to 16.5]) and abnormal dreams (8.4% [95% CI, 4.3% to 12.5%]). The rate of severe neuropsychiatric adverse events was 6.1% (95% CI, 4.3% to 7.9%), and efavirenz was associated with an increased risk of severe neuropsychiatric adverse events compared with ritonavir-boosted atazanavir (RR, 2.4 [95% CI, 1.5 to 3.8]), dolutegravir (RR, 16.7 [95% CI, 2.0 to 137.8]) and maraviroc (RR, 5.3 [95% CI, 1.6 to 18.1]); there were no data on severe neuropsychiatric adverse events with the integrase inhibitor raltegravir. The rate of depression was 3.3 percent (95% CI, 2.2 to 4.3) and the rate of suicidal ideation was 0.60 percent (95% CI, 0.20 to 1.10). However, an analysis of the D:A:D cohorts found no association between use of efavirenz and death from suicide,^107^ and an analysis on a large (n=19,983) U.S. administrative cohort found no association between inititation of efavirenz and increased risk of suicidal ideation.^106^ Another cohort study (n=694) also found no increased risk of suicidal ideation with efavirenz versus nevirapine (adjusted HR, 0.47 [95% CI, 0.21 to 1.07]).^108^ Rather, efavirenz was associated with lower risk of depression than nevirapine (adjusted HR, 0.56 [95% CI, 0.35 to 0.89]).

#### Cancer

An analysis of the D:A:D cohort found longer exposure to ART associated with lower risk of AIDS-defining cancer (rate ratio, 0.88/year [95% CI, 0.85 to 0.92]).^109^ However, protease inhibitor use was associated with higher risk of non–AIDS-defining cancer (rate ratio, 1.03/year [95% CI, 1.01 to 1.05]), largely due to an increased risk of anal cancer (rate ratio, 1.08/year [95% CI, 1.04 to 1.13]). There was no association between non-NRTI use and risk of non–AIDS-defining cancer. The overall incidence of non–AIDS-defining cancer in the D:A:D cohort was 0.46 per 100 person-years.

#### Hepatic and Renal Adverse Events

Two D:A:D analyses and three other studies reported increased risk of hepatic or renal adverse events with ART (Appendix B Tables 10 and 11). An analysis of the D:A:D cohorts found TDF (relative rate, 1.46 [95% CI, 1.11 to 1.93]) associated with increased risk of end-stage liver disease or hepatocellular carcinoma, independent of viral hepatitis status, and emtricitabine associated with decreased risk (relative rate, 0.51 [95% CI, 0.32 to 0.83]).^110^ However, the risk of ART-related liver deaths in the D:A:D cohorts was low (0.04/1,000 person-years).^117^ Another D:A:D analysis found an association between use of TDF (rate ratio, 1.14 per year of exposure [95% CI, 1.10 to 1.19]) or ritonavir-boosted atazanavir (rate ratio, 1.20 per year of exposure [95% CI, 1.13 to 1.26]) and increased risk of chronic kidney disease.^111^ After discontinuation, the incidence of renal impairment decreased, suggesting that effects depend on ongoing exposure.^123^ A cohort study of VHA data (n=10,841; 5.5 years followup) also found TDF associated with increased risk of chronic kidney disease (adjusted HR for any exposure, 1.88 [95% CI, 1.50 to 2.36] and for cumulative exposure, 1.36 [95% CI, 1.22 to 1.51]).^119^ Both TDF (adjusted HR, 1.63 [95% CI, 1.26 to 2.10]) and protease inhibitors (adjusted HR, 1.46 [95% CI, 1.07 to 2.01]) were associated with increased likelihood of decreased kidney function (estimated glomerular filtration rate <90 mL/min/1.73m^2^) in another (n=1,043) observational study with up to 10 years of followup (HR, 1.63 [95% CI, 1.26 to 2.10]).^118^ Finally, another cohort study (n=9,876) with 2.5 years followup found efavirenz associated with lower risk of renal adverse events (based on International Classification of Diseases, Ninth Revision, Clinical Modification codes for renal disease) compared with elvitegravir/cobicistat, when each was combined with emtricitabine and TDF (adjusted incidence rate difference, -1.78 [95% CI, -2.19 to -1.50]).^120^

#### Fracture

An analysis of the EuroSIDA cohort (n=11,820) found ever use of TDF associated with increased risk of fracture compared with nonuse (adjusted IRR, 1.40 [95% CI, 1.15 to 1.70]) after more than 86,000 person-years followup.^112^ However, there was no difference in risk of fracture based on cumulative duration of TDF use (adjusted IRR per 5 years of exposure, 1.08 [95% CI, 0.94 to 1.25]). Another large study (n=10,383) found efavirenz associated with lower risk of fracture compared with elvitegravir/cobicistat, when each was combined with emtricitabine and TDF (adjusted incidence rate difference, -3.85 [95% CI, -5.02 to -2.78]).^120^

#### Non-AIDS Mortality

An analysis of a European cohort (EuroSIDA; n=12,069) found no association between longer-term (>2 years) exposure to ART and risk of non–AIDS-related death after a median of 5.4 years.^121^