# Chapter 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^80^ the USPSTF and the Agency for Healthcare Research and Quality determined the scope and Key Questions for this review. Investigators created an analytic framework with the Key Questions and the patient populations, interventions, and outcomes reviewed (Figure 1). Key informants with expertise in HIV screening were surveyed for input, and the draft Research Plan was posted for public comment prior to finalization.

Figure 1 Analytic Framework and Key Questions

* Harms of screening include false-positive results, anxiety and effects of labeling, and partner discord, abuse, or violence.

† Harms of treatment include adverse effects associated with antiretroviral therapy, including cardiometabolic outcomes.

Abbreviations: CD4=cluster of differentiation 4; STI=sexually transmitted infection.

Key Questions

1. What are the benefits of screening for HIV infection in asymptomatic, nonpregnant adolescents and adults on mortality, AIDS and opportunistic infections, quality of life, function, and reduced transmission of HIV and other sexually transmitted infections?
2. What is the yield (number of new diagnoses per tests performed) of screening for HIV infection at different intervals in asymptomatic, nonpregnant adolescents and adults, and how does the screening yield vary in different risk groups?
3. What are the harms of screening for HIV infection in asymptomatic, nonpregnant adolescents and adults?
4. What are the effects of initiating antiretroviral therapy in adolescents and adults with chronic HIV infection at a higher versus lower CD4 count on mortality, AIDS and opportunistic infections, quality of life, function, and reduced transmission of HIV and other sexually transmitted infections, and harms?
5. What are the longer-term harms (≥2 years) associated with currently recommended antiretroviral therapy regimens?

The analytic framework depicts the relationship between the population, intervention, outcomes, and harms of screening for HIV. The far left of the framework describes the target population for screening as asymptomatic, nonpregnant adolescents and adults age 15 years and older. To the right of the population is an arrow corresponding to key question 2, which represents screening. This arrow leads to both HIV-positive and HIV-negative populations, and an arrow assessing potential harms of screening corresponds to key question 3. From the HIV-positive population, an arrow leads to disease staging with viral load and CD4 count testing followed by intervention with antiretroviral therapy (key question 4), which assesses clinical outcomes of mortality, AIDs and opportunistic infections, quality of life, functional status, and reduced transmission of HIV and other sexually transmitted infections. An arrow assessing potential harms of treatment stems from the interventions, which corresponds to key question 5. An overarching arrow for key question 1 goes directly from screening to clinical outcomes.

### Key Questions

1. What are the benefits of screening for HIV infection in asymptomatic, nonpregnant adolescents and adults on mortality, AIDS and opportunistic infections, quality of life, function, and reduced transmission of HIV and other STIs?
2. What is the yield (number of new diagnoses per tests performed) of screening for HIV infection at different intervals in asymptomatic, nonpregnant adolescents and adults, and how does the screening yield vary in different risk groups?
3. What are the harms of screening for HIV infection in asymptomatic, nonpregnant adolescents and adults?
4. What are the effects of initiating ART in adolescents and adults with chronic HIV infection at a higher versus lower CD4 count on mortality, AIDS and opportunistic infections, quality of life, function, and reduced transmission of HIV and other STIs?
5. What are the longer-term harms (≥2 years) associated with currently recommended ART regimens?

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, and Ovid MEDLINE (2012 through June 2018) for relevant studies and systematic reviews. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles.

After June 2018, we conducted surveillance through article alerts and targeted searches of high-impact journals to identify major studies that may affect conclusions. The last surveillance was conducted on January 25, 2019, and identified no primary research that would meet inclusion criteria for this review.

## Study Selection

All titles and abstracts identified through searches were independently reviewed by two members of the research team for eligibility using predefined inclusion/exclusion criteria, as specified using the PICOTS (population, intervention, comparator, outcome, timing, study design) framework (Appendix A2). Studies marked for possible inclusion by either reviewer underwent full-text review. All results were tracked in an EndNote^®^ database (Thomson Reuters, New York, NY).

Each full-text article was independently reviewed by two trained members of the research team for inclusion or exclusion on the basis of the eligibility criteria. If the reviewers disagreed, conflicts were resolved by discussion and consensus or by consulting another member of the review team. Results of the full-text review were also tracked in the EndNote^®^ database, including the reason for exclusion. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists the included studies, and Appendix A5 lists the excluded studies with reasons for exclusion.

## Scope of Review

This update is a focused review to inform an update of the prior USPSTF recommendation for screening for HIV infection in the general population (“A” recommendation). It targets gaps identified in the prior review, including direct evidence on benefits and harms of screening, the yield of screening at different intervals, and longer-term harms of ART, concentrating on regimens currently recommended by the U.S. Department of Health and Human Services Panel on Antiretroviral Guidelines for Adults and Adolescents (Appendix A6).^61^ This update also includes a Key Question on effects of earlier versus later initiation of ART, given evolution in clinical practice from reserving ART for patients with more advanced HIV infection to offering it to all patients.^61^ We focused on studies on initiation of ART in patients with baseline CD4 counts greater than 350 cells/mm^3^, as the effectiveness of ART in patients with more advanced immune deficiency is well established.

The USPSTF previously determined that ART and prophylaxis for immunologically advanced HIV infection are effective and that screening (with rapid or standard HIV tests) is highly accurate.^1,52^ Given recommendations for universal HIV screening from the USPSTF and other groups, the update does not address universal versus targeted screening, which the USPSTF determined was not relevant for current clinical practice.

The target population for Key Questions related to screening was nonpregnant adolescents (defined as persons ages 13 to <18 years) and adults without signs or symptoms of HIV infection, regardless of risk of HIV infection. Patient subgroups of interest included those defined by age and race/ethnicity. The screening intervention is combination antigen/antibody testing, according to the 2014 CDC testing algorithm, or point-of-care rapid testing (usually antibody-based). Outcomes were mortality, risk of AIDS and opportunistic infections, quality of life, function, risk of HIV transmission and STIs, harms of screening (e.g., harms due to false-positive results, anxiety, effects of labeling, and partner discord, abuse, or violence), and long-term harms of currently recommended ART (defined as harms occurring at least 2 years after initiation of therapy), with a focus on cardiovascular, renal, hepatic, and bone (fracture) harms. For screening at different intervals, we assessed the yield of screening, defined as the number of new diagnoses per number of tests performed. For all Key Questions, we included RCTs, cohort studies, and case-control studies. This update focuses on studies conducted in the United States and other high-income countries with low prevalence of HIV infection and in which HIV management is similar to that in the United States, unless studies are not available in those settings.

## Data Abstraction and Quality Rating

For studies meeting inclusion criteria, we created data abstraction forms to summarize characteristics of study populations, interventions, comparators, outcomes, study designs, settings, and methods. One investigator conducted data abstraction, which was reviewed for completeness and accuracy by another team member. Randomized trials of early versus delayed ART primarily reported outcomes using hazards ratios (HRs). To estimate absolute risk differences, we calculated relative risks (RRs) based on the event rates reported in the trials. Because the RRs and HRs were very similar, we reported results based on RRs. Both HRs and calculated RRs are presented in the evidence table.

Predefined criteria were used to assess the quality of individual controlled trials, systematic reviews, and observational studies by using criteria developed by the USPSTF; studies were rated as “good,” “fair,” or “poor” per USPSTF criteria, depending on the seriousness of the methodological shortcomings (Appendix A7).^80^ For each study, quality assessment was performed by two team members. Disagreements were resolved by consensus.

## Data Synthesis

For all Key Questions, the overall quality of evidence was determined using the approach described in the USPSTF Procedure Manual.^80^ Evidence was rated “good,” “fair,” or “poor,” based on study quality, consistency of results between studies, precision of estimates, study limitations, risk of reporting bias, and applicability.^80^

## External Review

The draft report was reviewed by content experts (Appendix A8), USPSTF members, Agency for Healthcare Research and Quality Project Officers, and collaborative partners and was posted for public comment; it has been revised accordingly.

## Response to Public Comments

The draft report was posted for public comment from November 20, 2018 to December 26, 2018, and few comments were received. In response to the comments, we updated the report with recently published 2017 HIV surveillance data,^11^ revised the section on “Risk Factors” to focus on sexual risk behaviors (specifically, men who have sex with men) rather than sexual orientation, and added having a partner with an STI as a risk factor.