# Chapter 1 Introduction and Background

## Purpose

The purpose of this report is to update a previous review^1,2^ commissioned by the U.S. Preventive Services Task Force (USPSTF) on benefits and harms of screening for HIV infection. This report will be used by the USPSTF to update its 2013 recommendation^3^ on screening for HIV in adolescents and adults, which was based on the prior review. Prenatal HIV screening is addressed in a separate report.^4^

In 2013, the USPSTF recommended that clinicians screen all adolescents and adults ages 15 to 65 years for HIV infection, as well as younger adolescents and older adults at increased risk (“A” recommendation). This recommendation reaffirmed and expanded on the prior (2005) USPSTF recommendation,^5^ in which the USPSTF recommended that clinicians screen all adolescents and adults at higher risk of HIV infection (“A” recommendation). In 2005, the USPSTF did not recommend for or against screening for HIV in adolescents and adults not at increased risk of HIV infection.

The expanded 2013 USPSTF recommendation was based on evidence supporting greater benefits of screening. Studies found that earlier treatment of HIV infection (i.e., at CD4+ T helper [CD4] cell counts of 350 to 500 cells/mm^3^) was associated with improved clinical outcomes compared with delayed treatment, that antiretroviral therapy (ART) was associated with decreased risk of transmission,^1,2^ and that undiagnosed HIV infection was present in a significant proportion of patients. The USPSTF previously found strong evidence that standard screening tests accurately detect HIV infection, and that interventions, particularly ART, are associated with improved health outcomes in patients with more advanced HIV infection. The USPSTF determined that the harms associated with HIV screening and treatment are small or manageable and are substantially outweighed by the benefits. The USPSTF also reviewed modeling studies that estimated cost-effectiveness ratios of less than $50,000 (2004 U.S. dollars) or less than $60,000 (2007 U.S. dollars) per quality-adjusted life-year for screening versus no screening in settings with an HIV prevalence as low as 0.10 to 0.20 percent.^6,7^

## Condition Background

### Condition Definition

HIV is a retrovirus that infects human immune cells, in particular CD4 cells. Left untreated, HIV infection results in progressive immunodeficiency, AIDS, and death.^8^ AIDS is a life-threatening condition characterized by presence of HIV infection and severe immune dysfunction (CD4 count ≤200 cells/mm^3^) or one or more AIDS-defining neoplastic conditions or opportunistic infections.^8^ HIV-1 infection is the most common variant in the United States. HIV-2 infection is rare in the United States, less clinically severe, and endemic in parts of West Africa.^9^

### Prevalence and Burden of Disease/Illness

Since the first cases of AIDS were reported in 1981, more than 700,000 persons diagnosed with AIDS in the United States have died.^10^ The Centers for Disease Control and Prevention (CDC) estimates that 1 million persons in the United States were living with HIV infection in 2016.^11^ In 2015, an estimated 15 percent of infected persons were unaware of their infection.^12^ This represents a decrease since 2008, when approximately 20 percent of infected persons were estimated to be unaware of their positive status,^13–15^ and from 2010, when 17.1 percent were estimated to be unaware of their status.^16^ The number of new HIV infections annually in the United States has decreased slightly in recent years, from about 42,000 in 2011 to 40,000 each year from 2013 to 2016 to 38,281 in 2017.^10,11^ Approximately 530,000 persons were living with AIDS in 2016. The estimated delay in diagnosis of HIV infection declined from a median of 3.6 years in 2011 to 3.0 years in 2015.^12^

Groups disproportionately affected by HIV infection in the United States include men who have sex with men and black and Hispanic/Latino persons. Between 2006 and 2009, there was a 21 percent increase in HIV incidence among persons ages 13 to 29 years, driven largely by a 34 percent increase among men who have sex with men, the only risk group to experience a statistically significant increase in incidence during this period.^17^ In 2017, 31,239 (81%) HIV diagnoses were among adult and adolescent males (age ≥13 years), 7,401 (19%) among adult and adolescent females, and 99 among children younger than age 13 years.^11^ Persons ages 20 to 34 years accounted for half of the new diagnoses and had the highest incidence of HIV infection (25.6 to 32.8 per 100,000 persons). Among adolescents, the annual incidence of HIV infection rises sharply from age 13 to 14 years (0.3 per 100,000 persons) to age 15 to 19 years (8.1 per 100,000 persons). When stratified by race/ethnicity, 43 percent of new diagnoses occurred in black, 26 percent in white, and 25 percent in Hispanic/Latino populations.^11^ Among males, men who have sex with men are the most common transmission method (82%), followed by heterosexual contact (7.3%), injection drug use (4.4%), and both men who have sex with men and injection drug use (4.0%). Among females, heterosexual contact is the most common transmission method (86%), followed by injection drug use (14%).

### Etiology and Natural History

HIV infection is acquired through mucosal or intravenous exposure to infected bodily fluids such as blood, semen, and genital tract secretions. Factors facilitating sexual transmission include the presence of sexually transmitted infections (STIs), certain sexual practices (e.g., penile-anal or penile-vaginal intercourse without a condom, sex with multiple partners, sex with persons with or at high risk of HIV infection), and high viral load in the infected partner.^18,19^ In persons who inject drugs, factors associated with HIV infection include increased frequency of injection drug use, sharing needles, and certain injection practices (e.g., backloading, or injecting drugs from one syringe into the back of another opened syringe).^20^

The primary HIV infection syndrome usually develops 2 to 4 weeks following initial exposure to HIV.^21^ Acute infection is associated with nonspecific symptoms such as fever and fatigue that may resemble infectious mononucleosis, but is often unrecognized.^22,23^ Very early after acute infection, there is rapid virus production that declines to a variable set point as the host immune system responds, although continuous rapid virus production and clearance occurs at all stages of infection.^24–29^

Although a small proportion of untreated persons infected with HIV remain asymptomatic and show little evidence of progressive immune suppression after 10 or more years of infection, nearly all eventually develop AIDS.^8^ Before the era of highly active antiretroviral therapy (HAART), the median time from seroconversion to the development of AIDS was 7.7 to 11.0 years and median survival ranged from 7.5 to 12 years.^30,31^

The primary mechanism by which chronic HIV infection causes immune deficiency is through a decrease in the level and functioning of CD4 cells. In untreated HIV infection, the CD4 count declines an average of 50 to 75 cells/mm^3^ per year.^32^ Most patients with CD4 counts greater than 200 cells/mm^3^ are either asymptomatic or have mild disease,^33^ although research indicates an increased risk of AIDS or even death in patients with CD4 counts greater than 500 cells/mm^3^.^34^ Patients with CD4 counts less than 200 cells/mm^3^ have advanced immune deficiency and are at markedly increased risk of AIDS-related opportunistic infections, other AIDS-related complications, and AIDS-associated mortality.^35–37^

A higher HIV viral load is a strong independent predictor of more rapid progression to AIDS.^35–40^ Other predictors of more rapid progression include older age at the time of infection,^30,31,35,36,39,41,42^ more severe symptoms at the time of primary HIV infection,^43^ and other clinical and genetic factors. One factor associated with slow progression is the C-C chemokine receptor type 5 delta32 genotype.^44–48^

### Risk Factors

Persons at increased risk of HIV infection include men who have sex with men; men and women who have unprotected vaginal or anal intercourse with more than one partner; men and women who exchange sex for drugs or money; persons with a history of or current injection drug use; persons seeking treatment for other STIs or who have a sexual partner with STIs; persons with a history of blood transfusion from 1978 to 1985; persons whose past or present sex partners are infected with HIV, men who have sex with men, or persons who inject drugs; persons who are transgender; and persons who do not report one of these risk factors but who request HIV testing.^49–51^ Settings in which the prevalence of HIV infection is often greater than 1 percent include STI clinics, correctional facilities, homeless shelters, tuberculosis clinics, clinics specialized in the care of sexual and gender minorities, and clinics caring for an adolescent community with a high prevalence of STIs.^52^

### Rationale for Screening/Screening Strategies

Identification and treatment of asymptomatic persons who are infected with HIV may help identify patients at higher CD4 counts before they develop severe immune deficiency or present with an AIDS-defining event. It may also lead to earlier initiation of interventions (including ART and prophylaxis for opportunistic infections)^52^ that reduce the risk of progression to AIDS, AIDS-defining clinical events, and mortality.^1,2^ Identification of asymptomatic persons who are infected with HIV may also help reduce the risk of transmission by reducing behaviors^53^ associated with transmission or through effects of ART on transmission risk.^54–57^ Identification through screening could also lead to additional benefits through partner notification and testing. Persons at high risk of HIV infection who test negative on screening could benefit from pre-exposure prophylaxis with ART to reduce risk of HIV acquisition;^58^ the USPSTF commissioned a separate report to address pre-exposure prophylaxis.^59^

### Interventions/Treatment

There remains no effective vaccine to prevent HIV infection. Interventions for patients with HIV infection include ART, prophylaxis for opportunistic infections, immunizations, Papanicolaou and human papillomavirus testing,^60^ counseling to reduce high-risk behaviors, and routine monitoring and followup. HAART, defined as three or more antiretroviral agents used in combination (usually from at least two drug classes), is the standard of care for ART.^61^ As all currently recommended antiretroviral regimens meet criteria for HAART, this report will simply use the term “ART,” in accordance with current treatment guidelines. Current guidelines recommend initial ART regimens containing an integrase strand transfer inhibitor plus two nucleoside reverse transcriptase inhibitors (NRTIs) in most persons with HIV infection; other regimens are recommended in certain clinical situations.^61^ Of the interventions used to treat chronic HIV infection, ART has the greatest effect on clinical outcomes, including survival.^62^ Clinical practice has evolved from initiation of ART in persons with more advanced HIV infection toward use in all infected persons.^61^ Detailed and regularly updated guidelines for the U.S. population regarding specifically recommended antiretroviral regimens and chemoprophylaxis for opportunistic infections are available.^61,63^

### Current Clinical Practice/Recommendations of Other Groups

The CDC introduced a new HIV testing algorithm in 2014 that begins with a combined assay that detects HIV-1 and HIV-2 antibodies and HIV-1 p24 antigens, with supplemental testing following a reactive assay to differentiate HIV-1 and HIV-2 antibodies. If supplemental testing is nonreactive or indeterminate,^64^ HIV-1 ribonucleic acid testing is performed to differentiate acute HIV infection from a false-positive test result. Advantages of the new algorithm are earlier diagnosis of acute HIV infection (median, 18 days from time of infection until detection with combined antigen-antibody assays),^65^ fewer indeterminate results, faster turnaround time, and more accurate diagnosis of HIV-2 infection.^66,67^ The use of repeatedly reactive enzyme immunoassay on an office-based venipuncture specimen followed by confirmatory Western blot or immunofluorescent assay for positive tests, the prior standard method for testing for HIV infection, was previously reviewed by the USPSTF and found to be associated with a sensitivity and specificity greater than 99 percent.^68,69^ Point-of-care rapid HIV tests (primarily antibody- based) that can be used in nonclinical settings are also highly accurate and have turnaround times that range from 15 to 20 minutes.^70^

As of 2010, about 45 percent of U.S. adults had ever been tested for HIV infection.^71^ HIV screening rates vary by state, age, sex, race/ethnicity, and other factors. Among persons age 18 years or older, the proportion ever tested for HIV infection ranges from 35 percent among those ages 18 to 24 years to 57 percent among those ages 25 to 44 years, and from 41 percent in white persons to 65 percent in black persons. Testing rates are lower in men (40%) than in women (50%). Among high school students who have had sexual intercourse, 22 percent reported ever have been tested.^72^ In 2015, 71 percent of men who have sex with men (76% in black and 70% in white men), 58 percent of persons who inject drugs, and 41 percent of persons at risk of HIV infection due to heterosexual contact reported testing in the past 12 months.^12^ The median interval from infection to diagnosis (known as diagnosis delay) was estimated at 3.0 years. Diagnosis delay varies by race/ethnicity, from about 2.2 years in white persons to 3.3 to 4.2 years in nonwhite races/ethnicities, and by transmission category, with the longest delay in males at risk due to heterosexual contact (4.9 years).

In 2006 the CDC recommended routine voluntary HIV screening of all adults ages 13 to 64 years regardless of other recognized risk factors, unless the prevalence of HIV was documented to be less than 0.1 percent within the community.^73^ The CDC also recommended “opt-out” HIV testing, meaning that all patients should be informed about testing and tested unless they specifically decline, without a requirement for prevention counseling prior to screening, to reduce barriers to testing. The CDC recommended that persons get tested at least once in their lifetimes and those with risk factors get tested more frequently (e.g., annually), and recently recommended that clinicians consider testing sexually active men who have sex with men more frequently (e.g., every 3 or 6 months), based on risk behaviors, HIV prevalence in the community, and other considerations.^74^

In 2009, the American College of Physicians issued a guidance statement on HIV screening consistent with the CDC approach,^75^ and the Infectious Diseases Society of America recommended routine HIV screening for all sexually active adults.^76^ The American College of Obstetricians and Gynecologists recommends that all females ages 13 to 64 years be tested at least once in their lifetime and then annually thereafter if they have risk factors.^77^ The American Academy of Pediatrics recommends offering routine HIV testing to all adolescents at least once by age 16 to 18 years when prevalence of HIV is greater than 0.1 percent in the community, and testing of all sexually active adolescents and those with risk factors in low-prevalence settings.^78^ The American Academy of Family Physicians follows the 2013 USPSTF recommendation, except it recommends that routine screening not begin until age 18 years.^79^