# Appendix B Evidence Tables and Quality Tables

Appendix B Table 1 Key Question 4: Evidence Table of Trials of Initiating Antiretroviral Therapy at Different CD4 Counts on Clinical Outcomes—Study Characteristics

Appendix B Table 2 Key Question 4: Evidence Table of Trials of Initiating Antiretroviral Therapy at Different CD4 Counts on Clinical Outcomes—Results

Appendix B Table 3 Key Question 4: Quality Assessment of Randomized, Controlled Trials

Appendix B Table 4 Key Question 4: Evidence Table of Cohort Studies of Initiating Antiretroviral Therapy at Different CD4 Counts on Clinical Outcomes—Study Characteristics

Appendix B Table 5 Key Question 4: Evidence Table of Cohort Studies of Initiating Antiretroviral Therapy at Different CD4 Counts on Clinical Outcomes—Results

Appendix B Table 6 Key Question 4: Quality Assessment of Cohort Studies

Appendix B Table 7 Key Question 5: Evidence Table of Systematic Reviews of Harms While Using Antiretroviral Therapy—Study Characteristics

Appendix B Table 8 Key Question 5: Evidence Table of Systematic Reviews of Harms While Using Antiretroviral Therapy—Results

Appendix B Table 9 Key Question 5: Quality Assessment of Systematic Reviews

Appendix B Table 10 Key Question 5: Evidence Table of Studies of Harms While Using Antiretroviral Therapy—Study Characteristics

Appendix B Table 11 Key Question 5: Evidence Table of Studies of Harms While Using Antiretroviral Therapy—Results

Appendix B Table 12 Key Question 5: Quality Assessment of Randomized, Controlled Trials

Appendix B Table 13 Key Question 5: Quality Assessment of Single-Arm Cohort Studies

Appendix B Table 14 Key Question 5: Quality Assessment of Comparative Cohort Studies