# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Screening

#### Database: Ovid MEDLINE(R) without Revisions

1. exp HIV/
2. HIV Antibodies/
3. HIV Antigens/
4. HIV Seroprevalence/
5. HIV Seropositivity/
6. HIV Seronegativity/
7. AIDS Serodiagnosis/
8. human immunodeficiency virus.ti.
9. hiv.ti.
10. Mass Screening/
11. screen$.ti.
12. or/1-9
13. 10 or 11
14. 12 and 13
15. limit 14 to (english language and humans)
16. limit 15 to yr="2012 - 2018"
17. limit 16 to (clinical trial, all or comparative study or controlled clinical trial or meta analysis or randomized controlled trial or systematic reviews)
18. (random* or control* or cohort).ti,ab.
19. 16 and 18
20. 17 or 19
21. 20 not pregnan*.ti.

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp HIV/
2. HIV Antibodies/
3. HIV Antigens/
4. HIV Seroprevalence/
5. HIV Seropositivity/
6. HIV Seronegativity/
7. AIDS Serodiagnosis/
8. human immunodeficiency virus.ti.
9. hiv.ti.
10. Mass Screening/
11. screen$.ti.
12. or/1-9
13. 10 or 11
14. 12 and 13
15. limit 14 to yr="2012 - 2018"
16. 15 not pregnan*.ti.

### Treatment

#### Database: Ovid MEDLINE(R) without Revisions

1. exp HIV Infections/dt, pc, th
2. exp Anti-Retroviral Agents/ad, tu
3. Antiretroviral Therapy, Highly Active/
4. or/1-3
5. Viral Load/
6. exp CD4 Lymphocyte Count/
7. CD4.ti,ab.
8. or/5-7
9. 4 and 8
10. (timing or initiat*).mp.
11. 9 and 10
12. limit 11 to (english language and humans)
13. limit 12 to (clinical trial, all or comparative study or controlled clinical trial or meta analysis or randomized controlled trial or systematic reviews)
14. 12 and (random* or control* or cohort).ti,ab.
15. 13 or 14
16. limit 15 to yr="2012 - 2018"
17. 16 not pregnan*.ti.

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 exp HIV Infections/dt, pc, th
2 exp Anti-Retroviral Agents/ad, tu
4 or/1-3
5 Viral Load/
6 exp CD4 Lymphocyte Count/
7 CD4.ti,ab.
8 or/5-7
9 4 and 8
10 (timing or initiat*).mp.
11 9 and 10
12 limit 11 to yr="2012 - 2018"
13 12 not pregnan*.ti.

### Treatment Harms

#### Database: Ovid MEDLINE(R) without Revisions

1. exp HIV Infections/dt, pc, th
2. exp Anti-Retroviral Agents/ad, tu
3. Antiretroviral Therapy, Highly Active/
4. or/1-3
5. 4 and (harm* or safety or adverse).ti,ab.
6. limit 5 to yr="2012 - 2018"
7. 6 not (pregnan* or mother*).ti.

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp HIV Infections/dt, pc, th
2. exp Anti-Retroviral Agents/ad, tu
3. Antiretroviral Therapy, Highly Active/
4. or/1-3
5. 4 and (harm* or safety or adverse).ti,ab.
6. limit 5 to yr="2012 - 2018"
7. 6 not (pregnan* or mother*).ti.

### Screening and Treatment

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. (hiv or “human immunodeficiency virus”).ti.
2. 1 and screen*.ti.
3. 1 and (treatment or antiretroviral or therapy).ti.
4. 2 or 3

## Appendix A2 Inclusion and Exclusion Criteria

Category | Include | Exclude
Settings | - Primary care or other settings generalizable to primary care (e.g., family planning clinics, school-based health clinics), other health care settings in which screening is commonly performed (e.g., sexually transmitted infection clinics, emergency room or urgent care); - Will focus on studies conducted in the United States and other high-income countries with low prevalence of HIV infection and in which HIV management is similar to that in the United States, unless studies are not available in those settings | Studies conducted in low- and middle-income countries, unless fair- or good-quality studies from the United States are not available
Populations^*^ | KQs 1–3: Asymptomatic adolescents and adults age 15 years and older; KQs 4, 5: Adolescents and adults living with HIV | KQs 1–3: Persons who have known HIV infection, are on dialysis, are posttransplant, have occupational exposure (due to risk of needle stick or other parenteral exposure), or have known infection with hepatitis C virus, hepatitis B virus, or tuberculosis; KQ 4: Persons who have acute HIV infection, are on dialysis, or are posttransplant; studies limiting enrollment to persons with hepatitis C virus, hepatitis B virus, or tuberculosis coinfection; KQ 5: Same as for KQ 4, plus persons who are already or were previously taking antiretroviral therapy
Interventions | KQs 1–3: Rapid or standard HIV testing; KQs 4, 5: Currently recommended antiretroviral therapy regimens
Outcomes | KQs 1, 4: Mortality; AIDS and opportunistic infections; quality of life; function; reduced transmission of HIV and other sexually transmitted infections; KQ 2: Number of new diagnoses per number of tests performed; KQ 3: False-positive results, anxiety and effects of labeling, and partner discord, abuse, or violence; KQ 5: Adverse outcomes associated with antiretroviral therapy, including cardiometabolic outcomes
Comparisons | KQs 1, 3: HIV screening vs. no screening; KQ 2: Repeat HIV screening vs. one-time screening; screening at one interval vs. another; KQ 4: Initiation of antiretroviral therapy at higher vs. lower CD4 counts
Study designs | KQs 1–3: Randomized, controlled trials and controlled observational studies; KQ 4: Randomized, controlled trials and large (n ≥1,000) controlled observational studies; KQ 5: Randomized, controlled trials and controlled observational studies; will consider treatment series if these study designs are not available | KQ 1: Uncontrolled observational studies
Timing | KQ 5: Long-term followup, defined as ≥2 years

* For all KQs, subgroups of interest include those defined by sex, age (including adolescents), race/ethnicity, and risk group.

Abbreviation: KQ=key question.

## Appendix A3 Literature Flow Diagram

*Other sources include reference lists of relevant articles, studies, systematic reviews, and suggestions from reviewers; includes background articles.

^†^In addition, 11 studies were carried forward from the prior U.S. Preventive Services Task Force reports.

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows that 4,905 citations were identified through literature database searches, 835 were identified from other sources, and 11 were identified from the previous reviews; 4,886 unique citations were screened after duplicates were removed. 361 articles were reviewed at the full-text level after excluding 4,525 abstracts and background articles. From the 361 full-text articles reviewed, 321 were excluded for the following reasons: wrong population (16), wrong intervention (32), wrong outcome (73), wrong comparator (32), wrong study design for key question (45), not a study (27), not English language but possibly relevant (3), inadequate duration (23), sample size too small (10), systematic review or meta-analysis used as a source document to identify individual studies (4), wrong country (52), systematic review of old data (3), or included within an included systematic review (1). After excluding these studies, 18 studies in 29 new articles were included that provide evidence for the key questions as follows: 3 trials in 5 articles and 3 cohort studies in 4 publications for Key Question 4, and 2 systematic reviews, 2 trials, and 8 cohort studies in 16 articles for Key Question 5. No evidence met inclusion criteria for Key Questions 1, 2 or 3. A footnote indicates that 11 studies were also carried forward from the prior evidence reports.

## Appendix A4 Included Studies List

Arribas JR, Thompson M, Sax PE, . Brief report: Randomized, double-blind comparison of tenofovir alafenamide (TAF) vs tenofovir disoproxil fumarate (TDF), each coformulated eith elvitegravir, cobicistat, and emtricitabine (E/C/F) for initial HIV-1 treatment: Week 144 results. J Acquir Immune Defic Syndr. 2017;75(2):211–8. doi: 10.1097/QAI.0000000000001350. PMID: 28282300.28282300
Borges AH, Hoy J, Florence E, . Antiretrovirals, fractures, and osteonecrosis in a large international HIV cohort. Clin Infect Dis. 2017;64(10):1413–21. doi: 10.1093/cid/cix167. PMID: 28329090.28329090
Bruyand M, Ryom L, Shepherd L, . Cancer risk and use of protease inhibitor or nonnucleoside reverse transcriptase inhibitor-based combination antiretroviral therapy: the D: A: D study. J Acquir Immune Defic Syndr. 2015;68(5):568–77. doi: 10.1097/qai.0000000000000523. PMID: 25763785.25763785
Chang JL, Tsai AC, Musinguzi N, . Depression and suicidal ideation among HIV-infected adults receiving efavirenz versus nevirapine in Uganda: A prospective cohort study. Ann Intern Med. 2018 doi: 10.7326/m17-2252. PMID: 29946683.29946683
Cohen MS, Chen YQ, McCauley M, . Antiretroviral therapy for the prevention of HIV-1 transmission. N Engl J Med. 2016;375(9):830–9. doi: 10.1056/NEJMoa1600693. PMID: 27424812.27424812
Desai M, Joyce V, Bendavid E, . Risk of cardiovascular events associated with current exposure to HIV antiretroviral therapies in a US veteran population. Clin Infect Dis. 2015;61(3):445–52. doi: 10.1093/cid/civ316. PMID: 25908684.25908684
Ding X, Andraca-Carrera E, Cooper C, . No association of abacavir use with myocardial infarction: findings of an FDA meta-analysis. J Acquir Immune Defic Syndr. 2012;61(4):441–7. doi: 10.1097/QAI.0b013e31826f993c. PMID: 22932321.22932321
Edwards JK, Cole SR, Westreich D, . Age at entry into care, timing of antiretroviral therapy initiation, and 10-year mortality among HIV-seropositive adults in the United States. Clin Infect Dis. 2015;61(7):1189–95. doi: 10.1093/cid/civ463. PMID: 26082505.26082505
Ford N, Shubber Z, Pozniak A, . Comparative safety and neuropsychiatric adverse events associated with efavirenz use in first-line antiretroviral therapy: A systematic review and meta-analysis of randomized trials. J Acquir Immune Defic Syndr. 2015;69(4):422–9. doi: 10.1097/QAI.0000000000000606. PMID: 25850607.25850607
Grinsztejn B, Hosseinipour MC, Ribaudo HJ, . Effects of early versus delayed initiation of antiretroviral treatment on clinical outcomes of HIV-1 infection: results from the phase 3 HPTN 052 randomised controlled trial. Lancet Infect Dis. 2014;14(4):281–90. doi: 10.1016/s1473-3099(13)70692-3. PMID: 24602844.24602844
Kovari H, Sabin CA, Ledergerber B, . Antiretroviral drug-related liver mortality among HIV-positive persons in the absence of hepatitis B or C virus coinfection: the data collection on adverse events of anti-HIV drugs study. Clin Infect Dis. 2013;56(6):870–9. doi: 10.1093/cid/cis919. PMID: 23090925.23090925
Kowalska JD, Reekie J, Mocroft A, . Long-term exposure to combination antiretroviral therapy and risk of death from specific causes: no evidence for any previously unidentified increased risk due to antiretroviral therapy. AIDS. 2012;26(3):315–23. doi: 10.1097/QAD.0b013e32834e8805. PMID: 22112597.22112597
Laprise C, Baril J-G, Dufresne S, . Association between tenofovir exposure and reduced kidney function in a cohort of HIV-positive patients: results from 10 years of follow-up. Clin Infect Dis. 2013;56(4):567–75. doi: 10.1093/cid/cis937. PMID: 23143096.23143096
Lima VD, Reuter A, Harrigan PR, . Initiation of antiretroviral therapy at high CD4+ cell counts is associated with positive treatment outcomes.[Erratum appears in AIDS. 2016 Feb 20;30(4):677]. AIDS. 2015;29(14):1871–82. doi: 10.1097/QAD.0000000000000790. PMID: 26165354.26165354
Lodi S, Costagliola D, Sabin C, . Effect of immediate initiation of antiretroviral treatment in HIV-positive individuals aged 50 years or older. J Acquir Immune Defic Syndr. 2017;76(3):311–8. doi: 10.1097/qai.0000000000001498. PMID: 28746165.28746165
Lodi S, Phillips A, Logan R, . Comparative effectiveness of immediate antiretroviral therapy versus CD4-based initiation in HIV-positive individuals in high-income countries: observational cohort study. Lancet HIV. 2015;2(8):e335–43. doi: 10.1016/S2352-3018(15)00108-3. PMID: 26423376.26423376
Lundgren JD, Babiker AG, Gordin F, . Initiation of antiretroviral therapy in early asymptomatic HIV infection. N Engl J Med. 2015;373(9):795–807. doi: 10.1056/NEJMoa1506816. PMID: 26192873.26192873
Mocroft A, Lundgren JD, Ross M, . Cumulative and current exposure to potentially nephrotoxic antiretrovirals and development of chronic kidney disease in HIV-positive individuals with a normal baseline estimated glomerular filtration rate: a prospective international cohort study. Lancet HIV. 2016;3(1):e23–32. doi: 10.1016/s2352-3018(15)00211-8. PMID: 26762990.26762990
Monforte A, Reiss P, Ryom L, . Atazanavir is not associated with an increased risk of cardio- or cerebrovascular disease events. AIDS. 2013;27(3):407–15. doi: 10.1097/QAD.0b013e32835b2ef1. PMID: 23291539.23291539
Nkhoma ET, Coumbis J, Farr AM, . No evidence of an association between efavirenz exposure and suicidality among HIV patients initiating antiretroviral therapy in a retrospective cohort study of real world data. Medicine (Baltimore). 2016;95(3):e2480. doi: 10.1097/MD.0000000000002480. PMID: 26817882.26817882
Nkhoma ET, Rosenblatt L, Myers J, . Real-world assessment of renal and bone safety among patients with HIV infection exposed to tenofovir disoproxil fumarate-containing single-tablet regimens. PLoS One. 2016;11(12):e0166982. doi: 10.1371/journal.pone.0166982. PMID: 27941989.27941989
O’Connor J, Vjecha MJ, Phillips AN, . Effect of immediate initiation of antiretroviral therapy on risk of severe bacterial infections in HIV-positive people with CD4 cell counts of more than 500 cells per muL: secondary outcome results from a randomised controlled trial. Lancet HIV. 2017;4(3):e105–e12. doi: 10.1016/s2352-3018(16)30216-8. PMID: 28063815.28063815
Rockstroh JK, DeJesus E, Lennox JL, . Durable efficacy and safety of raltegravir versus efavirenz when combined with tenofovir/emtricitabine in treatment-naive HIV-1-infected patients: final 5-year results from STARTMRK. J Acquir Immune Defic Syndr. 2013;63(1):77–85. doi: 10.1097/QAI.0b013e31828ace69. PMID: 23412015.23412015
Ryom L, Lundgren JD, De Wit S, . Use of antiretroviral therapy and risk of end-stage liver disease and hepatocellular carcinoma in HIV-positive persons. AIDS. 2016;30(11):1731–43. doi: 10.1097/qad.0000000000001018. PMID: 26752282.26752282
Ryom L, Mocroft A, Kirk O, . Association between antiretroviral exposure and renal impairment among HIV-positive persons with normal baseline renal function: the D:A:D study. J Infect Dis. 2013;207(9):1359–69. doi: 10.1093/infdis/jit043. PMID: 23382571.23382571
Sabin CA, Reiss P, Ryom L, . Is there continued evidence for an association between abacavir usage and myocardial infarction risk in individuals with HIV? A cohort collaboration. BMC Med. 2016;14:61. doi: 10.1186/s12916-016-0588-4. PMID: 27036962.27036962
Scherzer R, Estrella M, Li Y, . Association of tenofovir exposure with kidney disease risk in HIV infection. AIDS. 2012;26(7):867–75. doi: 10.1097/QAD.0b013e328351f68f. PMID: 22313955.22313955
Smith C, Ryom L, d’Arminio Monforte A, . Lack of association between use of efavirenz and death from suicide: evidence from the D:A:D study. J Int AIDS Soc. 2014;17(4 Suppl 3):19512. doi: 10.7448/IAS.17.4.19512. PMID: 25394021.25394021
TEMPRANO ANRS 12136 Study Group, Danel C, Moh R, . A trial of early antiretrovirals and isoniazid preventive therapy in Africa. N Engl J Med. 2015;373(9):808–22. doi: 10.1056/NEJMoa1507198. PMID: 26193126.26193126

## Appendix A5 Excluded Studies List

Achhra AC, Mocroft A, Ross MJ, . Kidney disease in antiretroviral-naive HIV-positive adults with high CD4 counts: prevalence and predictors of kidney disease at enrolment in the INSIGHT Strategic Timing of AntiRetroviral Treatment (START) trial. HIV Med. 2015 Apr;16 Suppl 1:55–63. doi: 10.1111/hiv.12234. PMID: 25711324. Excluded: Wrong study design for Key Question.25711324
Adebayo AM, Ilesanmi OS, Omotoso BA, . Disclosure to sexual partner and condom use among HIV positive clients attending ART clinic at a tertiary health facility in South West Nigeria. Pan Afr Med J. 2014;18:245. doi: 10.11604/pamj.2014.18.245.4371. PMID: 25426203. Excluded: Wrong country.25426203
Adetokunboh OO, Schoonees A, Balogun TA, . Efficacy and safety of abacavir-containing combination antiretroviral therapy as first-line treatment of HIV infected children and adolescents: a systematic review and meta-analysis. BMC Infect Dis. 2015;15:469. doi: 10.1186/s12879-015-1183-6. PMID: 26502899. Excluded: Wrong country.26502899
Adewumi OM, Odaibo GN, Olaleye OD. Baseline CD4 T cell level predicts recovery rate after initiation of ART in HIV infected Nigerians. J Immunoassay Immunochem. 2016;37(2):109–18. doi: 10.1080/15321819.2015.1057738. PMID: 26065646. Excluded: Wrong country.26065646
Ahmadi M, Khalili H, Abbasian L, . Effect of valerian in preventing neuropsychiatric adverse effects of efavirenz in HIV-positive patients: A pilot randomized, placebo-controlled clinical trial. Ann Pharmacother. 2017 Jun;51(6):457–64. doi: 10.1177/1060028017696105. PMID: 28478716. Excluded: Wrong intervention.28478716
Aho I, Kivela P, Haukka J, . Declining prevalence of cytological squamous intraepithelial lesions of the cervix among women living with well-controlled HIV - Most women living with HIV do not need annual PAP smear screening. Acta Obstet Gynecol Scand. 2017 Nov;96(11):1330–7. doi: 10.1111/aogs.13207. PMID: 28832899. Excluded: Wrong study design for Key Question.28832899
Amin J, Boyd MA, Kumarasamy N, . Raltegravir non-inferior to nucleoside based regimens in second-line therapy with lopinavir/ritonavir over 96 weeks: a randomised open label study for the treatment of HIV-1 infection.[Erratum appears in PLoS One. 2015;10(10):e0140623; PMID: 26451848]. PLoS One. 2015;10(2):e0118228. doi: 10.1371/journal.pone.0118228. PMID: 25723472. Excluded: Wrong population.25723472
Anderson D, DeMasi R, DeLaitsch L, . Week 96 outcomes of patients with less treatment experience versus more treatment experience receiving etravirine in the DUET trials. Curr HIV Res. 2012 Apr;10(3):256–61. PMID: 22497697. Excluded: Wrong comparator.22497697
Anglemyer A, Rutherford GW, Easterbrook PJ, . Early initiation of antiretroviral therapy in HIV-infected adults and adolescents: a systematic review. AIDS. 2014 Mar;28 Suppl 2:S105–18. doi: 10.1097/QAD.0000000000000232. PMID: 24849469. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies.24849469
Baeten JM, Palanee-Phillips T, Brown ER, . Use of a vaginal ring containing dapivirine for HIV-1 prevention in women. N Engl J Med. 2016 Dec 01;375(22):2121–32. doi: 10.1056/NEJMoa1506110. PMID: 26900902. Excluded: Wrong intervention.26900902
Baker JV, Engen NW, Huppler Hullsiek K, . Assessment of arterial elasticity among HIV-positive participants with high CD4 cell counts: a substudy of the INSIGHT Strategic Timing of AntiRetroviral Treatment (START) trial. HIV Med. 2015 Apr;16 Suppl 1:109–18. doi: 10.1111/hiv.12239. PMID: 25711329. Excluded: Wrong outcome.25711329
Banhegyi D, Katlama C, da Cunha CA, . Week 96 efficacy, virology and safety of darunavir/r versus lopinavir/r in treatment-experienced patients in TITAN. Curr HIV Res. 2012 Mar;10(2):171–81. PMID: 22339125. Excluded: Wrong population.22339125
Bavinger C, Bendavid E, Niehaus K, . Risk of cardiovascular disease from antiretroviral therapy for HIV: a systematic review. PLoS One. 2013;8(3):e59551. doi: 10.1371/journal.pone.0059551. PMID: 23555704. Excluded: Systematic review of old data.23555704
Bavinton B, Grinsztejn B, Phanuphak N, . HIV treatment prevents HIV transmission in male serodiscordant couples in Australia, Thailand and Brazil. J Int AIDS Soc. 2017. Int AIDS Society Avenue de France 23, Geneva, 1202, Switzerland; 20. Excluded: Wrong study design for Key Question.
Bavinton BR, Jin F, Prestage G, . The Opposites Attract Study of viral load, HIV treatment and HIV transmission in serodiscordant homosexual male couples: design and methods. BMC Public Health. 2014 Sep 4;14:917. doi: 10.1186/1471-2458-14-917. PMID: 25190360. Excluded: Wrong study design for Key Question.25190360
Bedimo R, Maalouf NM, Zhang S, . Osteoporotic fracture risk associated with cumulative exposure to tenofovir and other antiretroviral agents. AIDS. 2012 Apr 24;26(7):825–31. doi: 10.1097/QAD.0b013e32835192ae. PMID: 22301411. Excluded: Wrong study design for Key Question.22301411
Behrens G, Rijnders B, Nelson M, . Rilpivirine versus efavirenz with emtricitabine/tenofovir disoproxil fumarate in treatment-naive HIV-1-infected patients with HIV-1 RNA <100,000 copies/mL: week 96 pooled ECHO/THRIVE subanalysis. AIDS Patient Care STDS. 2014 Apr;28(4):168–75. doi: 10.1089/apc.2013.0310. PMID: 24660840. Excluded: Sample size too small.24660840
Benoit AC, Younger J, Beaver K, . Increased mortality among Indigenous persons in a multisite cohort of people living with HIV in Canada. Can J Public Health. 2017 Jun 16;108(2):e169–e75. doi: 10.17269/cjph.108.5708. PMID: 28621653. Excluded: Wrong comparator.28621653
Bermudez-Aza EH, Shetty S, Ousley J, . Long-term clinical, immunological and virological outcomes of patients on antiretroviral therapy in southern Myanmar. PLoS ONE. 2018;13(2):e0191695. doi: 10.1371/journal.pone.0191695. PMID: 29420652. Excluded: Wrong country.29420652
Bernardino JI, Mocroft A, Mallon PW, . Bone mineral density and inflammatory and bone biomarkers after darunavir-ritonavir combined with either raltegravir or tenofovir-emtricitabine in antiretroviral-naive adults with HIV-1: a substudy of the NEAT001/ANRS143 randomised trial. Lancet HIV. 2015 Nov;2(11):e464–73. doi: 10.1016/S2352-3018(15)00181-2. PMID: 26520926. Excluded: Sample size too small.26520926
Blick G, Greiger-Zanlungo P, Gretz S, . Long-term efficacy and safety of once-daily fosamprenavir 1400 mg boosted by ritonavir 100 mg: the BOLD100 study. Int J STD AIDS. 2012 Mar;23(3):e18–22. doi: 10.1258/ijsa.2009.009161. PMID: 22581890. Excluded: Wrong outcome.22581890
Boettiger DC, Sabin CA, Grulich A, . Is nelfinavir exposure associated with cancer incidence in HIV-positive individuals? AIDS. 2016 Jun 19;30(10):1629–37. doi: 10.1097/qad.0000000000001053. PMID: 26854812. Excluded: Wrong intervention.26854812
Bor J, Ahmed S, Fox MP, . Effect of eliminating CD4-count thresholds on HIV treatment initiation in South Africa: An empirical modeling study. PLoS One. 2017;12(6):e0178249. doi: 10.1371/journal.pone.0178249. PMID: 28617805. Excluded: Wrong study design for Key Question.28617805
Bottero J, Boyd A, Gozlan J, . Simultaneous hiv-hbv-hcv point-of-care tests improve the screening outcomes. J Hepatol. 2015;62(22). Excluded: Wrong outcome.
Brouwer ES, Napravnik S, Eron JJ, Jr., . Effects of combination antiretroviral therapies on the risk of myocardial infarction among HIV patients. Epidemiology. 2014 May;25(3):406–17. doi: 10.1097/EDE.0000000000000041. PMID: 24713880. Excluded: Sample size too small.24713880
Brown TT, Moser C, Currier JS, . Changes in bone mineral density after initiation of antiretroviral treatment with tenofovir disoproxil fumarate/emtricitabine plus atazanavir/ritonavir, darunavir/ritonavir, or raltegravir. J Infect Dis. 2015 Oct 15;212(8):1241–9. doi: 10.1093/infdis/jiv194. PMID: 25948863. Excluded: Sample size too small.25948863
Bunupuradah T, Phupitakphol T, Sophonphan J, . Prevalence of persistent renal dysfunction in perinatally HIV-infected Thai adolescents. Pediatr Infect Dis J. 2018 Jan;37(1):66–70. doi: 10.1097/INF.0000000000001684. PMID: 28719505. Excluded: Wrong country.28719505
Burt RD, Tinsley J, Glick SN. A decline in HIV testing among persons who inject drugs in the Seattle area, 2004-2015. J Acquir Immune Defic Syndr. 2017 Jul 01;75 Suppl 3:S346–S51. doi: 10.1097/QAI.0000000000001409. PMID: 28604437. Excluded: Wrong outcome.28604437
Campbell TB, Smeaton LM, Kumarasamy N, . Efficacy and safety of three antiretroviral regimens for initial treatment of HIV-1: a randomized clinical trial in diverse multinational settings. PLoS Med. 2012;9(8):e1001290. PMID: 22936892. Excluded: Wrong country.22936892
Capetti A, Landonio S, Meraviglia P, . 96 Week follow-up of HIV-infected patients in rescue with raltegravir plus optimized backbone regimens: a multicentre Italian experience. PLoS One. 2012;7(7):e39222. doi: 10.1371/journal.pone.0039222. PMID: 22808029. Excluded: Wrong population.22808029
Capetti A, Meraviglia P, Landonio S, . Four years data of raltegravir-based salvage therapy in HIV-1-infected, treatment-experienced patients: the SALIR-E Study. Int J Antimicrob Agents. 2014 Feb;43(2):189–94. doi: 10.1016/j.ijantimicag.2013.10.013. PMID: 24315315. Excluded: Wrong population.24315315
Capetti AF, Cossu MV, Paladini L, . Dolutegravir plus rilpivirine dual therapy in treating HIV-1 infection. Expert Opin Pharmacother. 2018 Jan;19(1):65–77. doi: 10.1080/14656566.2017.1417984. PMID: 29246084. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).29246084
Caro-Vega Y, del Rio C, Lima VD, . Estimating the impact of earlier ART initiation and increased testing coverage on HIV transmission among men who have sex with men in Mexico using a mathematical model. PLoS One. 2015;10(8):e0136534. doi: 10.1371/journal.pone.0136534. PMID: 26302044. Excluded: Wrong study design for Key Question.26302044
Carr A, Grund B, Neuhaus J, . Prevalence of and risk factors for low bone mineral density in untreated HIV infection: a substudy of the INSIGHT Strategic Timing of AntiRetroviral Treatment (START) trial. HIV Med. 2015 Apr;16 Suppl 1:137–46. doi: 10.1111/hiv.12242. PMID: 25711332. Excluded: Wrong study design for Key Question.25711332
Caseiro MM, Nelson M, Diaz RS, . Vicriviroc plus optimized background therapy for treatment-experienced subjects with CCR5 HIV-1 infection: final results of two randomized phase III trials. J Infect. 2012 Oct;65(4):326–35. doi: 10.1016/j.jinf.2012.05.008. PMID: 22634184. Excluded: Wrong population.22634184
Castagna A, Maggiolo F, Penco G, . Dolutegravir in antiretroviral-experienced patients with raltegravir- and/or elvitegravir-resistant HIV-1: 24-week results of the phase III VIKING-3 study. J Infect Dis. 2014 Aug 1;210(3):354–62. doi: 10.1093/infdis/jiu051. PMID: 24446523. Excluded: Wrong study design for Key Question.24446523
Castelnuovo B, Kiragga A, Musaazi J, . Outcomes in a cohort of patients started on antiretroviral treatment and followed up for a decade in an urban clinic in Uganda. PLoS One. 2015;10(12):e0142722. doi: 10.1371/journal.pone.0142722. PMID: 26642214. Excluded: Wrong country.26642214
Castilho JL, Melekhin VV, Sterling TR. Sex differences in HIV outcomes in the highly active antiretroviral therapy era: a systematic review. AIDS Res Hum Retroviruses. 2014 May;30(5):446–56. doi: 10.1089/AID.2013.0208. PMID: 24401107. Excluded: Wrong comparator.24401107
Centers for Disease Control and Prevention. Diagnoses of HIV infection among adults aged 50 years and older in the United States and dependent areas 2011-2016. 2018. https://www.cdc.gov/hiv/pdf/library/reports/surveillance/cdc-hiv-surveillance-supplemental-report-vol-23-5.pdf. Accessed January 11, 2019. Excluded: Not a study.
Cettomai D, Kwasa JK, Birbeck GL, . Screening for HIV-associated peripheral neuropathy in resource-limited settings. Muscle Nerve. 2013 Oct;48(4):516–24. doi: 10.1002/mus.23795. PMID: 24037693. Excluded: Wrong country.24037693
Chadwick DR, Sarfo FS, Kirk ES, . Tenofovir is associated with increased tubular proteinuria and asymptomatic renal tubular dysfunction in Ghana. BMC Nephrol. 2015;16:195. doi: 10.1186/s12882-015-0192-4. PMID: 26627687. Excluded: Wrong country.26627687
Chen J, Han X, An M, . Immunological and virological benefits resulted from short-course treatment during primary HIV infection: a meta-analysis. PLoS One. 2013;8(12):e82461. doi: 10.1371/journal.pone.0082461. PMID: 24324793. Excluded: Wrong outcome.24324793
Chen M, Dou Z, Wang L, . Gender eifferences in outcomes of antiretroviral treatment among HIV-infected patients in China: A retrospective cohort study, 2010-2015. J Acquir Immune Defic Syndr. 2017 Nov 01;76(3):281–8. doi: 10.1097/QAI.0000000000001500. PMID: 28708809. Excluded: Wrong country.28708809
Chen R, Scherzer R, Hsue PY, . Association of tenofovir use with risk of incident heart failure in HIV-infected patients. J Am Heart Assoc. 2017 Apr 24;6(4)doi: 10.1161/jaha.116.005387. PMID: 28438737. Excluded: Wrong outcome.28438737
Chen YQ, Masse B, Wang L, . Statistical considerations for the HPTN 052 Study to evaluate the effectiveness of early versus delayed antiretroviral strategies to prevent the sexual transmission of HIV-1 in serodiscordant couples. Contemp Clin Trials. 2012 Nov;33(6):1280–6. doi: 10.1016/j.cct.2012.07.007. PMID: 22813645. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).22813645
Cheret A, Nembot G, Melard A, . Intensive five-drug antiretroviral therapy regimen versus standard triple-drug therapy during primary HIV-1 infection (OPTIPRIM-ANRS 147): a randomised, open-label, phase 3 trial. Lancet Infect Dis. 2015 Apr;15(4):387–96. doi: 10.1016/S1473-3099(15)70021-6. PMID: 25701561. Excluded: Wrong comparator.25701561
Clotet B, Feinberg J, van LJ, . Once-daily dolutegravir versus darunavir plus ritonavir in antiretroviral-naive adults with HIV-1 infection (FLAMINGO): 48 week results from the randomised open-label phase 3b study. Lancet. 2014;383(9936):2222–31. PMID: 24698485. Excluded: Inadequate duration.24698485
Cohen CJ, Molina JM, Cassetti I, . Week 96 efficacy and safety of rilpivirine in treatment-naive, HIV-1 patients in two Phase III randomized trials. AIDS. 2013 Mar 27;27(6):939–50. doi: 10.1097/QAD.0b013e32835cee6e. PMID: 23211772. Excluded: Wrong outcome.23211772
Conway DP, Holt M, McNulty A, . Multi-centre evaluation of the Determine HIV Combo assay when used for point of care testing in a high risk clinic-based population.[Erratum appears in PLoS One. 2014;9(7):e103399]. PLoS One. 2014;9(4):e94062. doi: 10.1371/journal.pone.0094062. PMID: 24714441. Excluded: Wrong outcome.24714441
Cooper DA, Heera J, Ive P, . Efficacy and safety of maraviroc vs. efavirenz in treatment-naive patients with HIV-1: 5-year findings. AIDS. 2014 Mar 13;28(5):717–25. doi: 10.1097/QAD.0000000000000131. PMID: 24983542. Excluded: Wrong comparator.24983542
Copeland B, Shah B, Wheatley M, . Diagnosing HIV in men who have sex with men: an emergency department’s experience. AIDS Patient Care STDS. 2012 Apr;26(4):202–7. doi: 10.1089/apc.2011.0303. PMID: 22356726. Excluded: Wrong study design for Key Question.22356726
Cornell M, Schomaker M, Garone DB, . Gender differences in survival among adult patients starting antiretroviral therapy in South Africa: a multicentre cohort study. PLoS Med. 2012;9(9):e1001304. PMID: 22973181. Excluded: Wrong country.22973181
Corrao S, Prestileo T, Di Lorenzo F. Antiretroviral therapy in early HIV infection [Comment on “Initiation of antiretroviral therapy in early asymptomatic HIV infection”]. N Engl J Med. 2016 Jan 28;374(4):393–4. doi: 10.1056/NEJMc1513311#SA2. PMID: 26816021. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).26816021
Costello JF, Sliney A, MacLeod C, . Implementation of routine HIV testing in an acute care hospital in Rhode Island: a nurse-initiated opt-out pilot project. J Assoc Nurses AIDS Care. 2013 Sep-Oct;24(5):460–8. doi: 10.1016/j.jana.2012.09.007. PMID: 23270811. Excluded: Wrong study design for Key Question.23270811
Cruciani M, Mengoli C, Malena M, . Virological efficacy of abacavir: systematic review and meta-analysis. J Antimicrob Chemother. 2014 Dec;69(12):3169–80. doi: 10.1093/jac/dku279. PMID: 25074854. Excluded: Systematic review of old data.25074854
da Motta LR, Vanni AC, Kato SK, . Evaluation of five simple rapid HIV assays for potential use in the Brazilian national HIV testing algorithm. J Virol Methods. 2013 Dec;194(1-2):132–7. doi: 10.1016/j.jviromet.2013.08.016. PMID: 23994148. Excluded: Wrong intervention.23994148
Da Silva B, Tschampa J, Beron J, . Evaluation of myocardial infarction and coronary artery disease in subjects taking lopinavir/ritonavir: a study using clinical trial and pharmacovigilance databases. Int J Clin Pharmacol Ther. 2012 Jun;50(6):391–402. doi: 10.5414/CP201606. PMID: 22541744. Excluded: Wrong intervention.22541744
daCosta DiBonaventura M, Gupta S, Cho M, . The association of HIV/AIDS treatment side effects with health status, work productivity, and resource use. AIDS Care. 2012;24(6):744–55. doi: 10.1080/09540121.2011.630363. PMID: 22292729. Excluded: Wrong outcome.22292729
d’Almeida KW, Kierzek G, de Truchis P, . Modest public health impact of nontargeted human immunodeficiency virus screening in 29 emergency departments. Arch Intern Med. 2012 Jan 9;172(1):12–20. doi: 10.1001/archinternmed.2011.535. PMID: 22025095. Excluded: Wrong study design for Key Question.22025095
Damtew B, Mengistie B, Alemayehu T. Survival and determinants of mortality in adult HIV/Aids patients initiating antiretroviral therapy in Somali Region, Eastern Ethiopia. Pan Afr Med J. 2015;22:138. doi: 10.11604/pamj.2015.22.138.4352. PMID: 26889319. Excluded: Wrong country.26889319
Danjuma MI, Mohamad-Fadzillah NH, Khoo S. An investigation of the pattern of kidney injury in HIV-positive persons exposed to tenofovir disoproxil fumarate: an examination of a large population database (MHRA database). Int J STD AIDS. 2014 Mar;25(4):273–9. doi: 10.1177/0956462413504747. PMID: 24067251. Excluded: Wrong study design for Key Question.24067251
D’Ascenzo F, Cerrato E, Biondi-Zoccai G, . Acute coronary syndromes in human immunodeficiency virus patients: a meta-analysis investigating adverse event rates and the role of antiretroviral therapy. Eur Heart J. 2012 Apr;33(7):875–80. doi: 10.1093/eurheartj/ehr456. PMID: 22187508. Excluded: Wrong outcome.22187508
D’Ascenzo F, Quadri G, Cerrato E, . A meta-analysis investigating incidence and features of stroke in HIV-infected patients in the highly active antiretroviral therapy era. J Cardiovasc Med. 2015 Dec;16(12):839–43. doi: 10.2459/JCM.0b013e328365ca31. PMID: 24979113. Excluded: Wrong comparator.24979113
Davies NE, Karstaedt AS. Antiretroviral outcomes in South African prisoners: a retrospective cohort analysis. PLoS One. 2012;7(3):e33309. doi: 10.1371/journal.pone.0033309. PMID: 22470448. Excluded: Wrong country.22470448
Davis DH, Smith R, Brown A, . Early diagnosis and treatment of HIV infection: magnitude of benefit on short-term mortality is greatest in older adults. Age Ageing. 2013 Jul;42(4):520–6. doi: 10.1093/ageing/aft052. PMID: 23672932. Excluded: Wrong population.23672932
de Bruyn G, Magaret A, Baeten JM, . Mortality in members of HIV-1 serodiscordant couples in Africa and implications for antiretroviral therapy initiation: results of analyses from a multicenter randomized trial. BMC Infect Dis. 2012;12:277. doi: 10.1186/1471-2334-12-277. PMID: 23130818. Excluded: Wrong country.23130818
de Miguel R, Montejano R, Stella-Ascariz N, . A safety evaluation of raltegravir for the treatment of HIV. Expert Opin Drug Saf. 2018 Feb;17(2):217–23. doi: 10.1080/14740338.2018.1411903. PMID: 29199485. Excluded: Systematic review or meta- analysis used as a source document only to identify individual studies.29199485
de Waal R, Cohen K, Maartens G. Systematic review of antiretroviral-associated lipodystrophy: lipoatrophy, but not central fat gain, is an antiretroviral adverse drug reaction. PLoS One. 2013;8(5):e63623. doi: 10.1371/journal.pone.0063623. PMID: 23723990. Excluded: Wrong outcome.23723990
Deconinck L, Yazdanpanah Y, Gilson RJ, . Time to initiation of antiretroviral therapy in HIV-infected patients diagnosed with an opportunistic disease: a cohort study. HIV Med. 2015 Apr;16(4):219–29. doi: 10.1111/hiv.12201. PMID: 25522796. Excluded: Sample size too small.25522796
Deeks ED. Emtricitabine/rilpivirine/tenofovir disoproxil fumarate single-tablet regimen: a review of its use in HIV infection. Drugs. 2014 Nov;74(17):2079–95. doi: 10.1007/s40265-014-0318-1. PMID: 25352394. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).25352394
Dikman AE, Schonfeld E, Srisarajivakul NC, . Human immunodeficiency virus-associated diarrhea: Still an issue in the era of antiretroviral therapy. Dig Dis Sci. 2015 Aug;60(8):2236–45. doi: 10.1007/s10620-015-3615-y. PMID: 25772777. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).25772777
Diop SA, Fortes-Deguenonvo L, Seydi M, . [Efficacy and tolerance of tenofovir-lamivudine-efavirenz combination in HIV-1 patients in Fann Teaching Hospital in Dakar]. Bull Soc Pathol Exot. 2013 Feb;106(1):22–6. doi: 10.1007/s13149-012-0272-7. PMID: 23247755. Excluded: Not English language but possibly relevant.23247755
Dolling DI, Goodall RL, Chirara M, . The virological durability of first-line ART among HIV-positive adult patients in resource limited settings without virological monitoring: a retrospective analysis of DART trial data. BMC Infect Dis. 2017 Feb 21;17(1):160. doi: 10.1186/s12879-017-2266-3. PMID: 28222702. Excluded: Wrong outcome.28222702
Donnell-Fink LA, Arbelaez C, Collins JE, . Acceptability of fingerstick versus oral fluid rapid HIV testing: results from the universal screening for HIV infection in the emergency room (USHER Phase II) randomized controlled trial. J Acquir Immune Defic Syndr. 2012 Dec 15;61(5):588–92. doi: 10.1097/QAI.0b013e31826a6d67. PMID: 23183149. Excluded: Wrong outcome.23183149
Doshi RK, Milberg J, Isenberg D, . High rates of retention and viral suppression in the US HIV safety net system: HIV care continuum in the Ryan White HIV/AIDS Program, 2011. Clin Infect Dis. 2015 Jan 1;60(1):117–25. doi: 10.1093/cid/ciu722. PMID: 25225233. Excluded: Wrong outcome.25225233
Druyts E, Dybul M, Kanters S, . Male sex and the risk of mortality among individuals enrolled in antiretroviral therapy programs in Africa: a systematic review and meta-analysis. AIDS. 2013 Jan 28;27(3):417–25. doi: 10.1097/QAD.0b013e328359b89b. PMID: 22948271. Excluded: Wrong country.22948271
Ekouevi DK, Tchounga BK, Coffie PA, . Antiretroviral therapy response among HIV-2 infected patients: a systematic review. BMC Infect Dis. 2014;14:461. doi: 10.1186/1471-2334-14-461. PMID: 25154616. Excluded: Wrong country.25154616
Eluwa GI, Badru T, Agu KA, . Adverse drug reactions to antiretroviral therapy (ARVs): incidence, type and risk factors in Nigeria.[Erratum appears in BMC Clin Pharmacol. 2012;12:14 Note: Agu, Kenneth A [added]; Chabikuli, Otto [added]; Hamelmann, Christoph [added]]. BMC Clin Pharml. 2012;12:7. doi: 10.1186/1472-6904-12-7. PMID: 22369677. Excluded: Wrong country.22369677
Elvstam O, Medstrand P, Yilmaz A, . Virological failure and all-cause mortality in HIV-positive adults with low-level viremia during antiretroviral treatment. PLoS One. 2017;12(7):e0180761. doi: 10.1371/journal.pone.0180761. PMID: 28683128. Excluded: Wrong comparator.28683128
Elzi L, Battegay M. [When to start antiretroviral therapy]. Ther Umsch. 2014 Jan;71(1):23–9. doi: 10.1024/0040-5930/a000478. PMID: 24394206. Excluded: Not English language but possibly relevant.24394206
Emerson B, Plough K. Detection of acute HIV-1 infections utilizing NAAT technology in Dallas, Texas. J Clin Virol. 2013 Dec;58 Suppl 1:e48–53. doi: 10.1016/j.jcv.2013.08.005. PMID: 23999031. Excluded: Wrong study design for Key Question.23999031
ENCORE1 Study Group, R P, J A, . Efficacy of 400 mg efavirenz versus standard 600 mg dose in HIV-infected, antiretroviral-naive adults (ENCORE1): a randomised, double-blind, placebo-controlled, non-inferiority trial. Lancet. 2014;383(9927):1474–82. PMID: 24522178. Excluded: Inadequate duration.24522178
Encore Study Group, Carey D, Puls R, . Efficacy and safety of efavirenz 400 mg daily versus 600 mg daily: 96-week data from the randomised, double-blind, placebo-controlled, non-inferiority ENCORE1 study.[Erratum appears in Lancet Infect Dis. 2015 Jul;15(7):761; PMID: 26122437]. Lancet Infect Dis. 2015 Jul;15(7):793–802. doi: 10.1016/S1473-3099(15)70060-5. PMID: 25877963. Excluded: Inadequate duration.25877963
Escarcega RO, Franco JJ, Mani BC, . Cardiovascular disease in patients with chronic human immunodeficiency virus infection. Int J Cardiol. 2014 Jul 15;175(1):1–7. doi: 10.1016/j.ijcard.2014.04.155. PMID: 24798779. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).24798779
Ewald H, Santini-Oliveira M, Buhler JE, . Comparative effectiveness of tenofovir in HIV-infected treatment-experienced patients: systematic review and meta-analysis. HIV Clin Trials. 2017 Jan;18(1):17–27. doi: 10.1080/15284336.2016.1261073. PMID: 27951755. Excluded: Systematic review or meta- analysis used as a source document only to identify individual studies.27951755
Ewings FM, Ford D, Walker AS, . Optimal CD4 count for initiating HIV treatment: impact of CD4 observation frequency and grace periods, and performance of dynamic marginal structural models. Epidemiology. 2014 Mar;25(2):194–202. doi: 10.1097/EDE.0000000000000043. PMID: 24487204. Excluded: Wrong study design for Key Question.24487204
Fafin C, Pugliese P, Durant J, . Increased time exposure to tenofovir is associated with a greater decrease in estimated glomerular filtration rate in HIV patients with kidney function of less than 60 ml/min/1.73 m2. Nephron Clin Pract. 2012;120(4):c205–14. doi: 10.1159/000342377. PMID: 23037894. Excluded: Wrong outcome.23037894
Feyissa GT, Lockwood C, Munn Z. The effectiveness of home-based HIV counseling and testing on reducing stigma and risky sexual behavior among adults and adolescents: A systematic review and meta-analyses. JBI Database System Rev Implement Rep. 2015;13(6):318–72. doi: 10.11124/jbisrir-2015-2235. PMID: 26455755. Excluded: Wrong outcome.26455755
Fidler S, Porter K, Ewings F, . Short-course antiretroviral therapy in primary HIV infection. N Engl J Med. 2013;368(3):207–17. PMID: 23323897. Excluded: Wrong comparator.23323897
Fontela C, Castilla J, Juanbeltz R, . Comorbidities and cardiovascular risk factors in an aged cohort of HIV-infected patients on antiretroviral treatment in a Spanish hospital in 2016. Postgrad Med. 2018 Apr;130(3):317–24. doi: 10.1080/00325481.2018.1446653. PMID: 29486621. Excluded: Wrong outcome.29486621
Frampton JE. Crofelemer: a review of its use in the management of non-infectious diarrhoea in adult patients with HIV/AIDS on antiretroviral therapy. Drugs. 2013 Jul;73(10):1121–9. doi: 10.1007/s40265-013-0083-6. PMID: 23807722. Excluded: Wrong intervention.23807722
Friis-Moller N, Ryom L, Smith C, . An updated prediction model of the global risk of cardiovascular disease in HIV-positive persons: The Data-collection on Adverse Effects of Anti-HIV Drugs (D:A:D) study. Eur J Prev Cardiolog. 2016 Jan;23(2):214–23. doi: 10.1177/2047487315579291. PMID: 25882821. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).25882821
Fu TC, Westergaard RP, Lau B, . Changes in sexual and drug-related risk behavior following antiretroviral therapy initiation among HIV-infected injection drug users. AIDS. 2012 Nov 28;26(18):2383–91. doi: 10.1097/QAD.0b013e32835ad438. PMID: 23079804. Excluded: Wrong outcome.23079804
Furtado J, Madruga JV, Bicudo EL, . Safety and immunovirologic outcomes with maraviroc combination regimens in patients with a history of past treatment failures and virologic resistance in Brazil: an open-label, multicenter phase 3b study. AIDS Res Hum Retroviruses. 2013 Sep;29(9):1203–10. doi: 10.1089/AID.2012.0330. PMID: 23731330. Excluded: Wrong population.23731330
Gabillard D, Lewden C, Ndoye I, . Mortality, AIDS-morbidity, and loss to follow-up by current CD4 cell count among HIV-1-infected adults receiving antiretroviral therapy in Africa and Asia: data from the ANRS 12222 collaboration. J Acquir Immune Defic Syndr. 2013 Apr 15;62(5):555–61. doi: 10.1097/QAI.0b013e3182821821. PMID: 23274931. Excluded: Wrong country.23274931
Gagliardo C, Brozovich A, Birnbaum J, . A multicenter study of initiation of antiretroviral therapy and transmitted drug resistance in antiretroviral-naive adolescents and young adults with HIV in New York City. Clin Infect Dis. 2014 Mar;58(6):865–72. doi: 10.1093/cid/ciu003. PMID: 24429431. Excluded: Wrong outcome.24429431
Galizzi N, Galli L, Poli A, . Long-term efficacy and safety of rilpivirine plus abacavir and lamivudine in HIV-1 infected patients with undetectable viral load. PLoS ONE. 2018;13(2):e0191300. doi: 10.1371/journal.pone.0191300. PMID: 29451870. Excluded: Wrong outcome.29451870
Gallien S, Flandre P, Nguyen N, . Safety and efficacy of coformulated efavirenz/emtricitabine/tenofovir single-tablet regimen in treatment-naive patients infected with HIV-1. J Med Virol. 2015 Feb;87(2):187–91. doi: 10.1002/jmv.24023. PMID: 25070158. Excluded: Inadequate duration.25070158
Geng EH, Odeny TA, Lyamuya RE, . Estimation of mortality among HIV-infected people on antiretroviral treatment in East Africa: a sampling based approach in an observational, multisite, cohort study. Lancet HIV. 2015 Mar;2(3):e107–16. doi: 10.1016/S2352-3018(15)00002-8. PMID: 26424542. Excluded: Wrong country.26424542
Ghislain M, Bastard JP, Meyer L, . Late antiretroviral therapy (ART) initiation is associated with long-term persistence of systemic inflammation and metabolic abnormalities. PLoS One. 2015;10(12):e0144317. doi: 10.1371/journal.pone.0144317. PMID: 26636578. Excluded: Wrong outcome.26636578
Giaquinto C, Anabwani G, Feiterna-Sperling C, . Steady-state pharmacokinetics of nevirapine extended-release tablets in HIV-1-infected children and adolescents: an open-label, multiple-dose, cross-over study. Pediatr Infect Dis J. 2014 Jul;33(7):e173–9. doi: 10.1097/INF.0000000000000241. PMID: 24378938. Excluded: Wrong outcome.24378938
Gordon MS, Kinlock TW, McKenzie M, . Rapid HIV testing for individuals on probation/parole: outcomes of an intervention trial. AIDS Behav. 2013 Jul;17(6):2022–30. doi: 10.1007/s10461-013-0456-6. PMID: 23536140. Excluded: Wrong comparator.23536140
Gotti D, Danesi M, Calabresi A, . Clinical characteristics, incidence, and risk factors of HIV-related Hodgkin lymphoma in the era of combination antiretroviral therapy. AIDS Patient Care STDS. 2013 May;27(5):259–65. doi: 10.1089/apc.2012.0424. PMID: 23600703. Excluded: Wrong study design for Key Question.23600703
Gotuzzo E, Markowitz M, Ratanasuwan W, . Sustained efficacy and safety of raltegravir after 5 years of combination antiretroviral therapy as initial treatment of HIV-1 infection: final results of a randomized, controlled, phase II study (Protocol 004). J Acquir Immune Defic Syndr. 2012 Sep 1;61(1):73–7. PMID: 22743596. Excluded: Sample size too small.22743596
Goujard C, Emilie D, Roussillon C, . Continuous versus intermittent treatment strategies during primary HIV-1 infection: the randomized ANRS INTERPRIM Trial. AIDS. 2012 Sep 24;26(15):1895–905. PMID: 22842994. Excluded: Wrong comparator.22842994
Gous N, Scott L, Potgieter J, . Feasibility of performing multiple point of care testing for HIV anti-retroviral treatment initiation and monitoring from multiple or single fingersticks. PLoS One. 2013;8(12):e85265. doi: 10.1371/journal.pone.0085265. PMID: 24376873. Excluded: Wrong country.24376873
Grabarczyk P, van Drimmelen H, Kopacz A, . Head-to-head comparison of two transcription-mediated amplification assay versions for detection of hepatitis B virus, hepatitis C virus, and human immunodeficiency virus Type 1 in blood donors. Transfusion. 2013 Oct;53(10 Pt 2):2512–24. doi: 10.1111/trf.12190. PMID: 23590145. Excluded: Wrong outcome.23590145
Grant PM, Zolopa AR. When to start ART in the setting of acute AIDS-related opportunistic infections: the time is now! Curr HIV/AIDS Rep. 2012 Sep;9(3):251–8. doi: 10.1007/s11904-012-0126-8. PMID: 22733609. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).22733609
Gray RT, Prestage GP, Down I, . Increased HIV testing will modestly reduce HIV incidence among gay men in NSW and would be acceptable if HIV testing becomes convenient. PLoS One. 2013;8(2):e55449. doi: 10.1371/journal.pone.0055449. PMID: 23457470. Excluded: Wrong outcome.23457470
Green N, Hoenigl M, Morris S, . Risk behavior and sexually transmitted infections among transgender women and men undergoing community-based screening for acute and early HIV infection in San Diego. Medicine (Baltimore). 2015 Oct;94(41):e1830. doi: 10.1097/MD.0000000000001830. PMID: 26469928. Excluded: Wrong outcome.26469928
Greenwald JL, Bursetin GR, Pincus J, . A rapid review of rapid HIV antibody tests. Curr Infect Dis Rep. 2006;8:125–31. PMID: 16524549. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).16524549
Greig JR, Batchelor D, Wallis M. Positive predictive value is poor in low risk populations seen in universal screening for HIV infection [Comment on Sugarman “Implications of universal screening for HIV infection”]. BMJ. 2013;346:f3575. PMID: 23737279. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).23737279
Greig SL, Deeks ED. Abacavir/dolutegravir/lamivudine single-tablet regimen: a review of its use in HIV-1 infection. Drugs. 2015 Apr;75(5):503–14. doi: 10.1007/s40265-015-0361-6. PMID: 25698454. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).25698454
Guehi C, Badje A, Gabillard D, . High prevalence of being overweight and obese HIV-infected persons, before and after 24 months on early ART in the ANRS 12136 Temprano Trial. AIDS Res Ther. 2016;13:12. doi: 10.1186/s12981-016-0094-y. PMID: 26925155. Excluded: Wrong country.26925155
Guest JL, Weintrob AC, Rimland D, . A comparison of HAART outcomes between the US military HIV Natural History Study (NHS) and HIV Atlanta Veterans Affairs Cohort Study (HAVACS). PLoS One. 2013;8(5):e62273. doi: 10.1371/journal.pone.0062273. PMID: 23658717. Excluded: Wrong comparator.23658717
Gupta SK, McComsey GA, Lombaard J, . Efficacy, safety, bone and metabolic effects of HIV nucleoside reverse transcriptase inhibitor BMS-986001 (AI467003): a phase 2b randomised, controlled, partly blinded trial. Lancet HIV. 2016 Jan;3(1):e13–22. doi: 10.1016/S2352-3018(15)00231-3. PMID: 26762988. Excluded: Wrong intervention.26762988
Gupta SK, Shen C, Moe SM, . Worsening endothelial function with efavirenz compared to protease inhibitors: a 12-month prospective study. PLoS One. 2012;7(9):e45716. doi: 10.1371/journal.pone.0045716. PMID: 23029197. Excluded: Wrong outcome.23029197
Gwadz M, Cleland CM, Applegate E, . Behavioral intervention improves treatment outcomes among HIV-infected individuals who have delayed, declined, or discontinued antiretroviral therapy: a randomized controlled trial of a novel intervention. AIDS Behav. 2015 Oct;19(10):1801–17. doi: 10.1007/s10461-015-1054-6. PMID: 25835462. Excluded: Wrong intervention.25835462
Hack CM, Scarfi CA, Sivitz AB, . Implementing routine HIV screening in an urban pediatric emergency department. Pediatr Emerg Care. 2013 Mar;29(3):319–23. doi: 10.1097/PEC.0b013e3182850910. PMID: 23426243. Excluded: Wrong study design for Key Question.23426243
Han N, Wright ST, O’Connor CC, . HIV and aging: insights from the Asia Pacific HIV Observational Database (APHOD). HIV Med. 2015 Mar;16(3):152–60. doi: 10.1111/hiv.12188. PMID: 25407085. Excluded: Wrong study design for Key Question.25407085
Handford CD, Rackal JM, Tynan AM, . The association of hospital, clinic and provider volume with HIV/AIDS care and mortality: systematic review and meta-analysis. AIDS Care. 2012;24(3):267–82. doi: 10.1080/09540121.2011.608419. PMID: 22007914. Excluded: Wrong comparator.22007914
Hankin A, Freiman H, Copeland B, . A comparison of parallel and integrated models for implementation of routine HIV screening in a large, urban emergency department. Public Health Rep. 2016 Jan-Feb;131 Suppl 1:90–5. PMID: 26862234. Excluded: Wrong comparator.26862234
Hemkens LG, Bucher HC. HIV infection and cardiovascular disease. Eur Heart J. 2014 Jun 1;35(21):1373–81. doi: 10.1093/eurheartj/eht528. PMID: 24408888. Excluded: Wrong study design for Key Question.24408888
Hemkens LG, Ewald H, Santini-Oliveira M, . Comparative effectiveness of tenofovir in treatment-naive HIV-infected patients: systematic review and meta-analysis. HIV Clin Trials. 2015 Oct;16(5):178–89. doi: 10.1179/1945577115Y.0000000004. PMID: 26395328. Excluded: Wrong outcome.26395328
Hermans SM, van Leth F, Manabe YC, . Earlier initiation of antiretroviral therapy, increased tuberculosis case finding and reduced mortality in a setting of improved HIV care: a retrospective cohort study. HIV Med. 2012 Jul;13(6):337–44. doi: 10.1111/j.1468-1293.2011.00980.x. PMID: 22296211. Excluded: Wrong country.22296211
Hirsch AA, Compan A, Lawrence RH, . Pilot study to assess subjective and objective reporting of potential adverse drug reactions in older versus younger HIV-infected patients using antiretroviral therapy. J Assoc Nurses AIDS Care. 2012 Sep-Oct;23(5):397–408. doi: 10.1016/j.jana.2011.09.005. PMID: 22137548. Excluded: Wrong comparator.22137548
Hirschhorn LR, Kaaya SF, Garrity PS, . Cancer and the ‘other’ noncommunicable chronic diseases in older people living with HIV/AIDS in resource-limited settings: a challenge to success. AIDS. 2012 Jul 31;26 Suppl 1:S65–75. PMID: 22781178. Excluded: Wrong country.22781178
Ho JE, Scherzer R, Hecht FM, . The association of CD4+ T-cell counts and cardiovascular risk in treated HIV disease. AIDS. 2012 Jun 1;26(9):1115–20. doi: 10.1097/QAD.0b013e328352ce54. PMID: 22382147. Excluded: Wrong outcome.22382147
Hocqueloux L, Avettand-Fenoel V, Jacquot S, . Long-term antiretroviral therapy initiated during primary HIV-1 infection is key to achieving both low HIV reservoirs and normal T cell counts. J Antimicrob Chemother. 2013 May;68(5):1169–78. doi: 10.1093/jac/dks533. PMID: 23335199. Excluded: Wrong study design for Key Question.23335199
Hoffmann C, Welz T, Sabranski M, . Higher rates of neuropsychiatric adverse events leading to dolutegravir discontinuation in women and older patients. HIV Med. 2017 Jan;18(1):56–63. doi: 10.1111/hiv.12468. PMID: 27860104. Excluded: Sample size too small.27860104
Hogan CM, Degruttola V, Sun X, . The setpoint study (ACTG A5217): effect of immediate versus deferred antiretroviral therapy on virologic set point in recently HIV-1-infected individuals. J Infect Dis. 2012 Jan 1;205(1):87–96. doi: 10.1093/infdis/jir699. PMID: 22180621. Excluded: Sample size too small.22180621
Hoover JB, Tao G, Heffelfinger JD. Monitoring HIV testing at visits to emergency departments in the United States: very-low rate of HIV testing. J Acquir Immune Defic Syndr. 2013 Jan 1;62(1):90–4. doi: 10.1097/QAI.0b013e3182742933. PMID: 23018376. Excluded: Wrong study design for Key Question.23018376
IeDea and A. R. T. Cohort Collaborations, Avila D, Althoff KN, . Immunodeficiency at the start of combination antiretroviral therapy in low-, middle-, and high-income countries. J Acquir Immune Defic Syndr. 2014 Jan 1;65(1):e8–16. doi: 10.1097/QAI.0b013e3182a39979. PMID: 24419071. Excluded: Wrong country.24419071
Islam FM, Wu J, Jansson J, . Relative risk of cardiovascular disease among people living with HIV: a systematic review and meta-analysis. HIV Med. 2012 Sep;13(8):453–68. doi: 10.1111/j.1468-1293.2012.00996.x. PMID: 22413967. Excluded: Systematic review of old data.22413967
Jain V, Hartogensis W, Bacchetti P, . Antiretroviral therapy initiated within 6 months of HIV infection is associated with lower T-cell activation and smaller HIV reservoir size. J Infect Dis. 2013 Oct 15;208(8):1202–11. doi: 10.1093/infdis/jit311. PMID: 23852127. Excluded: Wrong outcome.23852127
Jamil MS, Prestage G, Fairley CK, . Rationale and design of FORTH: a randomised controlled trial assessing the effectiveness of HIV self-testing in increasing HIV testing frequency among gay and bisexual men. BMC Infect Dis. 2015;15:561. doi: 10.1186/s12879-015-1300-6. PMID: 26653203. Excluded: Wrong study design for Key Question.26653203
Jose S, Quinn K, Hill T, . Laboratory adverse events and discontinuation of therapy according to CD4(+) cell count at the start of antiretroviral therapy. AIDS. 2014 Jun 1;28(9):1333–9. doi: 10.1097/QAD.0000000000000242. PMID: 24583670. Excluded: Wrong outcome.24583670
Joyce VR, Barnett PG, Chow A, . Effect of treatment interruption and intensification of antiretroviral therapy on health-related quality of life in patients with advanced HIV: a randomized, controlled trial. Med Decis Making. 2012 Jan-Feb;32(1):70–82. doi: 10.1177/0272989X10397615. PMID: 21383086. Excluded: Wrong comparator.21383086
Kahouadji Y, Dumurgier J, Sellier P, . Cognitive function after several years of antiretroviral therapy with stable central nervous system penetration score. HIV Med. 2013 May;14(5):311–5. doi: 10.1111/j.1468-1293.2012.01052.x. PMID: 23035982. Excluded: Wrong outcome.23035982
Kakaire O, Byamugisha JK, Tumwesigye NM, . Clinical versus laboratory screening for sexually transmitted infections prior to insertion of intrauterine contraception among women living with HIV/AIDS: a randomized controlled trial. Hum Reprod. 2015 Jul;30(7):1573–9. doi: 10.1093/humrep/dev109. PMID: 25979373. Excluded: Wrong intervention.25979373
Kalayjian RC, Lau B, Mechekano RN, . Risk factors for chronic kidney disease in a large cohort of HIV-1 infected individuals initiating antiretroviral therapy in routine care. AIDS. 2012 Sep 24;26(15):1907–15. PMID: 22824630. Excluded: Sample size too small.22824630
Kanters S, Mills EJ, Thorlund K, . Antiretroviral therapy for initial human immunodeficiency virus/AIDS treatment: critical appraisal of the evidence from over 100 randomized trials and 400 systematic reviews and meta-analyses. Clin Microbiol Infect. 2014 Feb;20(2):114–22. doi: 10.1111/1469-0691.12475. PMID: 24274661. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).24274661
Karim R, Mack WJ, Kono N, . T-cell activation, both pre- and post-HAART levels, correlates with carotid artery stiffness over 6.5 years among HIV-infected women in the WIHS. J Acquir Immune Defic Syndr. 2014 Nov 1;67(3):349–56. doi: 10.1097/QAI.0000000000000311. PMID: 25314253. Excluded: Wrong outcome.25314253
Karris MY, Kao YT, Patel D, . Predictors of virologic response in persons who start antiretroviral therapy during recent HIV infection. AIDS. 2014 Mar 27;28(6):841–9. doi: 10.1097/QAD.0000000000000149. PMID: 24401640. Excluded: Wrong outcome.24401640
Kiertiburanakul S, Boettiger D, Lee MP, . Trends of CD4 cell count levels at the initiation of antiretroviral therapy over time and factors associated with late initiation of antiretroviral therapy among Asian HIV-positive patients. J Int AIDS Soc. 2014;17:18804. doi: 10.7448/IAS.17.1.18804. PMID: 24598459. Excluded: Wrong population.24598459
Kiertiburanakul S, Luengroongroj P, Sungkanuparph S. Clinical characteristics of HIV-infected patients who survive after the diagnosis of HIV infection for more than 10 years in a resource-limited setting. J Int Assoc Physicians AIDS Care. 2012 Nov-Dec;11(6):361–5. doi: 10.1177/1545109712449191. PMID: 22745182. Excluded: Wrong country.22745182
Kim EK, Thorpe L, Myers JE, . Healthcare-related correlates of recent HIV testing in New York City. Prev Med. 2012 Jun;54(6):440–3. doi: 10.1016/j.ypmed.2012.03.006. PMID: 22449481. Excluded: Wrong study design for Key Question.22449481
Kityo C, Gibb DM, Gilks CF, . High level of viral suppression and low switch rate to second-line antiretroviral therapy among HIV-infected adult patients followed over five years: retrospective analysis of the DART trial. PLoS One. 2014;9(3):e90772. doi: 10.1371/journal.pone.0090772. PMID: 24625508. Excluded: Wrong country.24625508
Koethe JR, Grome H, Jenkins CA, . The metabolic and cardiovascular consequences of obesity in persons with HIV on long-term antiretroviral therapy. AIDS. 2016 Jan 2;30(1):83–91. doi: 10.1097/QAD.0000000000000893. PMID: 26418084. Excluded: Wrong comparator.26418084
Koethe JR, Jenkins CA, Lau B, . Body mass index and early CD4 T-cell recovery among adults initiating antiretroviral therapy in North America, 1998-2010. HIV Med. 2015 Oct;16(9):572–7. doi: 10.1111/hiv.12259. PMID: 25960080. Excluded: Wrong study design for Key Question.25960080
Koethe JR, Jenkins CA, Turner M, . Body mass index and the risk of incident noncommunicable diseases after starting antiretroviral therapy. HIV Med. 2015 Jan;16(1):67–72. doi: 10.1111/hiv.12178. PMID: 25230709. Excluded: Wrong study design for Key Question.25230709
Krastinova E, Seng R, Lechenadec J, . Does transient cART started during primary HIV infection undermine the long-term immunologic and virologic response on cART resumption? BMC Infect Dis. 2015;15:178. doi: 10.1186/s12879-015-0892-1. PMID: 25888386. Excluded: Wrong outcome.25888386
Krishnan S, Schouten JT, Atkinson B, . Metabolic syndrome before and after initiation of antiretroviral therapy in treatment-naive HIV-infected individuals. J Acquir Immune Defic Syndr. 2012 Nov 1;61(3):381–9. doi: 10.1097/QAI.0b013e3182690e3c. PMID: 22828718. Excluded: Wrong outcome.22828718
Kryst J, Kawalec P, Pilc A. Efavirenz-based regimens in antiretroviral-naive HIV-infected patients: A systematic review and meta-analysis of randomized controlled trials. PLoS One. 2015;10(5):e0124279. doi: 10.1371/journal.pone.0124279. PMID: 25933004. Excluded: Wrong outcome.25933004
Kunisaki KM, Niewoehner DE, Collins G, . Pulmonary function in an international sample of HIV-positive, treatment-naive adults with CD4 counts > 500 cells/muL: a substudy of the INSIGHT Strategic Timing of AntiRetroviral Treatment (START) trial. HIV Med. 2015 Apr;16 Suppl 1:119–28. doi: 10.1111/hiv.12240. PMID: 25711330. Excluded: Wrong study design for Key Question.25711330
Kurth AE, Severynen A, Spielberg F. Addressing unmet need for HIV testing in emergency care settings: a role for computer-facilitated rapid HIV testing? AIDS Educ Prev. 2013 Aug;25(4):287–301. doi: 10.1521/aeap.2013.25.4.287. PMID: 23837807. Excluded: Wrong intervention.23837807
Kyle TL, Horigian VE, Tross S, . Uptake of HIV testing in substance use disorder treatment programs that offer on-site testing. AIDS Behav. 2015 Mar;19(3):536–42. doi: 10.1007/s10461-014-0864-2. PMID: 25074737. Excluded: Wrong outcome.25074737
Laanani M, Ghosn J, Essat A, . Impact of the timing of initiation of antiretroviral therapy during primary HIV-1 infection on the decay of cell-associated HIV-DNA. Clin Infect Dis. 2015 Jun 1;60(11):1715–21. doi: 10.1093/cid/civ171. PMID: 25737374. Excluded: Wrong outcome.25737374
Lacombe JM, Boue F, Grabar S, . Risk of Kaposi sarcoma during the first months on combination antiretroviral therapy. AIDS. 2013 Feb 20;27(4):635–43. doi: 10.1097/QAD.0b013e32835cba6c. PMID: 23196937. Excluded: Wrong outcome.23196937
Lakey W, Yang LY, Yancy W, . Short communication: from wasting to obesity: initial antiretroviral therapy and weight gain in HIV-infected persons. AIDS Res Hum Retroviruses. 2013 Mar;29(3):435–40. doi: 10.1089/AID.2012.0234. PMID: 23072344. Excluded: Wrong outcome.23072344
Langebeek N, Sprenger HG, Gisolf EH, . A simplified combination antiretroviral therapy regimen enhances adherence, treatment satisfaction and quality of life: results of a randomized clinical trial. HIV Med. 2014 May;15(5):286–90. doi: 10.1111/hiv.12112. PMID: 24215485. Excluded: Wrong intervention.24215485
Laprise C, Baril JG, Dufresne S, . Atazanavir and other determinants of hyperbilirubinemia in a cohort of 1150 HIV-positive patients: results from 9 years of follow-up. AIDS Patient Care STDS. 2013 Jul;27(7):378–86. doi: 10.1089/apc.2013.0009. PMID: 23829329. Excluded: Wrong outcome.23829329
Laureillard D, Marcy O, Madec Y, . Paradoxical tuberculosis-associated immune reconstitution inflammatory syndrome after early initiation of antiretroviral therapy in a randomized clinical trial. AIDS. 2013 Oct 23;27(16):2577–86. doi: 10.1097/01.aids.0000432456.14099.c7. PMID: 24096631. Excluded: Wrong country.24096631
Le T, Wright EJ, Smith DM, . Enhanced CD4+ T-cell recovery with earlier HIV-1 antiretroviral therapy. N Engl J Med. 2013 Jan 17;368(3):218–30. doi: 10.1056/NEJMoa1110187. PMID: 23323898. Excluded: Wrong outcome.23323898
Legoupil C, Peltier A, Henry Kagan V, . Out-of-Hospital screening for HIV, HBV, HCV and Syphilis in a vulnerable population, a public health challenge. AIDS Care. 2017 Jun;29(6):686–8. doi: 10.1080/09540121.2016.1231886. PMID: 27626811. Excluded: Wrong outcome.27626811
Lennox JL, Landovitz RJ, Ribaudo HJ, . Efficacy and tolerability of 3 nonnucleoside reverse transcriptase inhibitor-sparing antiretroviral regimens for treatment-naive volunteers infected with HIV-1: A randomized, controlled equivalence trial. Ann Intern Med. 2014;161(7):461–71. PMID: 25285539. Excluded: Wrong outcome.25285539
Lenzi L, Wiens A, Pontarolo R. Evaluation of adverse events associated with antiretroviral therapy and the relationship to treatment adherence. Int J Clin Pharmacol Ther. 2013 Feb;51(2):141–6. doi: 10.5414/CP201818. PMID: 23253950. Excluded: Wrong outcome.23253950
Leon N, Mathews C, Lewin S, . A comparison of linkage to HIV care after provider-initiated HIV testing and counselling (PITC) versus voluntary HIV counselling and testing (VCT) for patients with sexually transmitted infections in Cape Town, South Africa. BMC Health Serv Res. 2014;14:350. doi: 10.1186/1472-6963-14-350. PMID: 25134822. Excluded: Wrong country.25134822
Leonard NR, Rajan S, Gwadz MV, . HIV testing patterns among urban YMSM of color. Health Educ Behav. 2014 Dec;41(6):673–81. doi: 10.1177/1090198114537064. PMID: 24973260. Excluded: Wrong study design for Key Question.24973260
Leung V, Gillis J, Raboud J, . Predictors of CD4:CD8 ratio normalization and its effect on health outcomes in the era of combination antiretroviral therapy. PLoS One. 2013;8(10):e77665. doi: 10.1371/journal.pone.0077665. PMID: 24204912. Excluded: Wrong outcome.24204912
Leutscher PD, Stecher C, Storgaard M, . Discontinuation of efavirenz therapy in HIV patients due to neuropsychiatric adverse effects. Scand J Infect Dis. 2013 Aug;45(8):645–51. doi: 10.3109/00365548.2013.773067. PMID: 23427878. Excluded: Wrong outcome.23427878
Li L, Tian JH, Yang K, . Humanized PA14 (a monoclonal CCR5 antibody) for treatment of people with HIV infection. Cochrane Database Syst Rev. 2014;7:CD008439. doi: 10.1002/14651858.CD008439.pub3. PMID: 25063928. Excluded: Wrong intervention.25063928
Li SL, Xu P, Zhang L, . Effectiveness and safety of rilpivirine, a non-nucleoside reverse transcriptase inhibitor, in treatment-naive adults infected with HIV-1: a meta-analysis. HIV Clin Trials. 2014 Nov-Dec;15(6):261–8. doi: 10.1310/hct1506-261. PMID: 25433665. Excluded: Inadequate duration.25433665
Libois A, Feoli F, Nkuize M, . Prolonged antiretroviral therapy is associated with fewer anal high-grade squamous intraepithelial lesions in HIV-positive MSM in a cross-sectional study. Sex Transm Infect. 2017 Feb;93(1):15–7. doi: 10.1136/sextrans-2015-052444. PMID: 27030607. Excluded: Wrong comparator.27030607
Lifson AR, Grandits GA, Gardner EM, . Quality of life assessment among HIV-positive persons entering the INSIGHT Strategic Timing of AntiRetroviral Treatment (START) trial. HIV Med. 2015 Apr;16 Suppl 1:88–96. doi: 10.1111/hiv.12237. PMID: 25711327. Excluded: Wrong study design for Key Question.25711327
Lin D, Li W, Rieder MJ. Cotrimoxazole for prophylaxis or treatment of opportunistic infections of HIV/AIDS in patients with previous history of hypersensitivity to cotrimoxazole. Cochrane Database Syst Rev. 2009(1)doi: 10.1002/14651858.CD005646.pub2. PMID: 17443608. Excluded: Wrong intervention.17443608
Lin D, Rieder MJ. Interventions for the treatment of decreased bone mineral density associated with HIV infection. Cochrane Database Syst Rev. 2009(1)doi: 10.1002/14651858.CD005645.pub2. PMID: 17443607. Excluded: Wrong intervention.17443607
Lipshultz SE, Mas CM, Henkel JM, . HAART to heart: highly active antiretroviral therapy and the risk of cardiovascular disease in HIV-infected or exposed children and adults. Expert Rev Anti Infect Ther. 2012 Jun;10(6):661–74. doi: 10.1586/eri.12.53. PMID: 22734956. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).22734956
Lodi S, Fisher M, Phillips A, . Symptomatic illness and low CD4 cell count at HIV seroconversion as markers of severe primary HIV infection. PLoS One. 2013;8(11):e78642. doi: 10.1371/journal.pone.0078642. PMID: 24244330. Excluded: Wrong study design for Key Question.24244330
Lodi S, Phillips A, Fidler S, . Role of HIV infection duration and CD4 cell level at initiation of combination anti-retroviral therapy on risk of failure. PLoS One. 2013;8(9):e75608. doi: 10.1371/journal.pone.0075608. PMID: 24086588. Excluded: Wrong outcome.24086588
Longenecker CT, Triant VA. Initiation of antiretroviral therapy at high CD4 cell counts: does it reduce the risk of cardiovascular disease? Curr Opin HIV AIDS. 2014 Jan;9(1):54–62. doi: 10.1097/COH.0000000000000015. PMID: 24275676. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).24275676
Lopez-Cortes LF, Gutierrez-Valencia A, Ben-Marzouk-Hidalgo OJ. Antiretroviral therapy in early HIV infection [Comment on “Initiation of antiretroviral therapy in early asymptomatic HIV infection”]. N Engl J Med. 2016 Jan 28;374(4):393. doi: 10.1056/NEJMc1513311#SA1. PMID: 26816020. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).26816020
Lopez-Cortes LF, Viciana P, Giron-Gonzalez JA, . Clinical and virological efficacy of etravirine plus two active Nucleos(t)ide analogs in an heterogeneous HIV-infected population. PLoS One. 2014;9(5):e97262. doi: 10.1371/journal.pone.0097262. PMID: 24836963. Excluded: Wrong intervention.24836963
Loutfy MR, Sherr L, Sonnenberg-Schwan U, . Caring for women living with HIV: gaps in the evidence. J Int AIDS Soc. 2013;16:18509. doi: 10.7448/IAS.16.1.18509. PMID: 24088395. Excluded: Wrong outcome.24088395
Loutfy MR, Wu W, Letchumanan M, . Systematic review of HIV transmission between heterosexual serodiscordant couples where the HIV-positive partner is fully suppressed on antiretroviral therapy. PLoS One. 2013;8(2):e55747. doi: 10.1371/journal.pone.0055747. PMID: 23418455. Excluded: Wrong outcome.23418455
Lu CL, Chang SY, Sun HY, . Impact of vaccination with seven-valent pneumococcal conjugate vaccine on virologic and immunologic outcomes among HIV-infected adult patients in the era of highly active antiretroviral therapy. J Formos Med Assoc. 2012 Aug;111(8):445–51. doi: 10.1016/j.jfma.2011.06.027. PMID: 22939663. Excluded: Wrong intervention.22939663
Lucas KD, Eckert V, Behrends CN, . Evaluation of routine HIV opt-out screening and continuum of care services following entry into eight prison reception centers-California, 2012. MMWR Morb Mortal Wkly Rep. 2016 Feb 26;65(7):178–81. doi: 10.15585/mmwr.mm6507a3. PMID: 26914322. Excluded: Wrong study design for Key Question.26914322
Lundgren J, Babiker AG, Neaton JD. Antiretroviral therapy in early HIV infection [Authors’ reply]. N Engl J Med. 2016 Jan 28;374(4):394. doi: 10.1056/NEJMc1513311. PMID: 26816019. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).26816019
Lundgren JD, Babiker AG, Gordin FM, . When to start antiretroviral therapy: the need for an evidence base during early HIV infection. BMC Med. 2013;11:148. doi: 10.1186/1741-7015-11-148. PMID: 23767777. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).23767777
Luz PM, Grinsztejn B, Velasque L, . Long-term CD4+ cell count in response to combination antiretroviral therapy. PLoS One. 2014;9(4):e93039. doi: 10.1371/journal.pone.0093039. PMID: 24695533. Excluded: Wrong outcome.24695533
Lyons MS, Lindsell CJ, Ruffner AH, . Randomized comparison of universal and targeted HIV screening in the emergency department. J Acquir Immune Defic Syndr. 2013 Nov 1;64(3):315–23. doi: 10.1097/QAI.0b013e3182a21611. PMID: 23846569. Excluded: Wrong comparator.23846569
MacArthur RD, DuPont HL. Etiology and pharmacologic management of noninfectious diarrhea in HIV-infected individuals in the highly active antiretroviral therapy era. Clin Infect Dis. 2012 Sep;55(6):860–7. doi: 10.1093/cid/cis544. PMID: 22700829. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).22700829
Madeddu G, Mameli G, Capobianco G, . HPV infection in HIV-positive females: the need for cervical cancer screening including HPV-DNA detection despite successful HAART. Eur Rev Med Pharmacol Sci. 2014;18(8):1277–85. PMID: 24817305. Excluded: Wrong intervention.24817305
Maggi P, Bartolozzi D, Bonfanti P, . Renal complications in HIV disease: between present and future. AIDS Rev. 2012 Jan-Mar;14(1):37–53. PMID: 22297503. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).22297503
Maggi P, Di Biagio A, Rusconi S, . Cardiovascular risk and dyslipidemia among persons living with HIV: a review. BMC Infect Dis. 2017 Aug 09;17(1):551. doi: 10.1186/s12879-017-2626-z. PMID: 28793863. Excluded: Systematic review or meta- analysis used as a source document only to identify individual studies.28793863
Mahajan AP, Kinsler JJ, Cunningham WE, . Does the Centers for Disease Control and Prevention’s recommendation of opt-out HIV screening impact the effect of stigma on HIV test acceptance? AIDS Behav. 2016 Jan;20(1):107–14. PMID: 26462670. Excluded: Wrong outcome.26462670
Maina EK, Bonney EY, Bukusi EA, . CD4+ T cell counts in initiation of antiretroviral therapy in HIV infected asymptomatic individuals; controversies and inconsistencies. Immunol Lett. 2015 Dec;168(2):279–84. doi: 10.1016/j.imlet.2015.10.005. PMID: 26475399. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).26475399
Maman D, Pujades-Rodriguez M, Nicholas S, . Response to antiretroviral therapy: improved survival associated with CD4 above 500 cells/mul. AIDS. 2012 Jul 17;26(11):1393–8. doi: 10.1097/QAD.0b013e328352d054. PMID: 22441247. Excluded: Wrong country.22441247
Manzardo C, Esteve A, Ortega N, . Optimal timing for initiation of highly active antiretroviral therapy in treatment-naive human immunodeficiency virus-1-infected individuals presenting with AIDS-defining diseases: the experience of the PISCIS Cohort. Clin Microbiol Infect. 2013 Jul;19(7):646–53. doi: 10.1111/j.1469-0691.2012.03991.x. PMID: 22967234. Excluded: Sample size too small.22967234
Marco Mourino A, Gallego Castellvi C, Garcia de Olalla P, . Late diagnosis of HIV infection among prisoners. AIDS Rev. 2013 Jul-Sep;15(3):146–51. PMID: 24002198. Excluded: Wrong study design for Key Question.24002198
Margolick JB, Apuzzo L, Singer J, . A randomized trial of time-limited antiretroviral therapy in acute/early HIV infection. PLoS One. 2015;10(11):e0143259. doi: 10.1371/journal.pone.0143259. PMID: 26600459. Excluded: Inadequate duration.26600459
Margolis DA, Brinson CC, Smith GH, . Cabotegravir plus rilpivirine, once a day, after induction with cabotegravir plus nucleoside reverse transcriptase inhibitors in antiretroviral-naive adults with HIV-1 infection (LATTE): a randomised, phase 2b, dose-ranging trial. Lancet Infect Dis. 2015 Oct;15(10):1145–55. doi: 10.1016/S1473-3099(15)00152-8. PMID: 26201299. Excluded: Wrong intervention.26201299
Margolis DA, Eron JJ, DeJesus E, . Unexpected finding of delayed-onset seizures in HIV-positive, treatment-experienced subjects in the Phase IIb evaluation of fosdevirine (GSK2248761). Antiviral Ther. 2014;19(1):69–78. doi: 10.3851/IMP2689. PMID: 24158593. Excluded: Wrong intervention.24158593
Markowitz M, Zolopa A, Squires K, . Phase I/II study of the pharmacokinetics, safety and antiretroviral activity of tenofovir alafenamide, a new prodrug of the HIV reverse transcriptase inhibitor tenofovir, in HIV-infected adults. J Antimicrob Chemother. 2014 May;69(5):1362–9. doi: 10.1093/jac/dkt532. PMID: 24508897. Excluded: Wrong intervention.24508897
Markowitz N, Lopardo G, Wentworth D, . Long-term effects of intermittent IL-2 in HIV infection: extended follow-up of the INSIGHT STALWART Study. PLoS One. 2012;7(10):e47506. doi: 10.1371/journal.pone.0047506. PMID: 23082173. Excluded: Wrong intervention.23082173
Martin-Echevarria E, Serrano-Villar S, Sainz T, . Development of tuberculosis in human immunodeficiency virus infected patients receiving antiretroviral therapy. Int J Tuberc Lung Dis. 2014 Sep;18(9):1080–4. doi: 10.5588/ijtld.13.0757. PMID: 25189556. Excluded: Inadequate duration.25189556
Maskew M, Fox MP, van Cutsem G, . Treatment response and mortality among patients starting antiretroviral therapy with and without Kaposi sarcoma: a cohort study. PLoS One. 2013;8(6):e64392. doi: 10.1371/journal.pone.0064392. PMID: 23755122. Excluded: Wrong country.23755122
Matthews GV, Neuhaus J, Bhagani S, . Baseline prevalence and predictors of liver fibrosis among HIV-positive individuals: a substudy of the INSIGHT Strategic Timing of AntiRetroviral Treatment (START) trial. HIV Med. 2015 Apr;16 Suppl 1:129–36. doi: 10.1111/hiv.12241. PMID: 25711331. Excluded: Wrong study design for Key Question.25711331
May MT, Hogg RS, Justice AC, . Heterogeneity in outcomes of treated HIV-positive patients in Europe and North America: relation with patient and cohort characteristics. Int J Epidemiol. 2012 Dec;41(6):1807–20. doi: 10.1093/ije/dys164. PMID: 23148105. Excluded: Wrong outcome.23148105
Mayer KH, Safren SA, Elsesser SA, . Optimizing pre-exposure antiretroviral prophylaxis adherence in men who have sex with men: Results of a pilot randomized controlled trial of “Life-Steps for PrEP”. AIDS Behav. 2016 Nov 15 doi: 10.1007/s10461-016-1606-4. PMID: 27848089. Excluded: Wrong intervention.27848089
McNicholl IR. Does once-daily etravirine have a role in the management of HIV-1 infection? Drugs. 2013 Mar;73(3):207–12. doi: 10.1007/s40265-013-0022-6. PMID: 23420097. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).23420097
Merchant RC, Baird JR, Liu T, . Does a brief intervention increase HIV/HCV screening among drug-using emergency department patients? Acad Emerg Med. 2014 START: 2014 May 13 CONFERENCE END: 2014 May 17, 2014 Annual Meeting of the Society for Academic Emergency Medicine, SAEM 2014 Dallas, TX United States;21(5 SUPPL. 1):S305-S6. Excluded: Wrong outcome.
Metsch LR, Feaster DJ, Gooden L. Effect of risk-reduction counseling with rapid HIV testing on risk of acquiring sexually transmitted infections: The AWARE randomized clinical trial. JAMA. 2013;310(16):1701–10. PMID: 24150466. Excluded: Wrong comparator.24150466
Mfinanga SG, Kirenga BJ, Chanda DM, . Early versus delayed initiation of highly active antiretroviral therapy for HIV-positive adults with newly diagnosed pulmonary tuberculosis (TB-HAART): a prospective, international, randomised, placebo-controlled trial.[Erratum appears in Lancet Infect Dis. 2014 Jul;14(7):548]. Lancet Infect Dis. 2014 Jul;14(7):563–71. doi: 10.1016/S1473-3099(14)70733-9. PMID: 24810491. Excluded: Wrong population.24810491
Miller CJ, Baker JV, Bormann AM, . Adjudicated morbidity and mortality outcomes by age among individuals with HIV infection on suppressive antiretroviral therapy. PLoS One. 2014;9(4):e95061. doi: 10.1371/journal.pone.0095061. PMID: 24728071. Excluded: Wrong comparator.24728071
Ming Z, Prybylski D, Cheng F, . Two-year prospective cohort study on quality of life outcomes among people living with HIV after initiation of antiretroviral therapy in Guangxi, China. J Assoc Nurses AIDS Care. 2014 Nov-Dec;25(6):603–13. doi: 10.1016/j.jana.2014.04.003. PMID: 24950656. Excluded: Wrong outcome.24950656
Mitchell SG, Schwartz RP, Kirk AS, . SBIRT implementation for adolescents in urban federally qualified health centers. J Subst Abuse Treat. 2016 Jan;60:81–90. doi: 10.1016/j.jsat.2015.06.011. PMID: 26297321. Excluded: Wrong outcome.26297321
Molina JM, Clotet B, van Lunzen J, . Once-daily dolutegravir versus darunavir plus ritonavir for treatment-naive adults with HIV-1 infection (FLAMINGO): 96 week results from a randomised, open-label, phase 3b study.[Erratum appears in Lancet HIV. 2015 Apr;2(4):e126]. Lancet HIV. 2015 Apr;2(4):e127–36. doi: 10.1016/S2352-3018(15)00027-2. PMID: 26424673. Excluded: Inadequate duration.26424673
Molina JM, Clumeck N, Orkin C, . Week 96 analysis of rilpivirine or efavirenz in HIV-1-infected patients with baseline viral load < 100 000 copies/mL in the pooled ECHO and THRIVE phase 3, randomized, double-blind trials. HIV Med. 2014 Jan;15(1):57–62. doi: 10.1111/hiv.12071. PMID: 23980523. Excluded: Inadequate duration.23980523
Molina JM, Clumeck N, Redant K, . Rilpivirine vs. efavirenz in HIV-1 patients with baseline viral load 100,000 copies/ml or less: week 48 phase III analysis. AIDS. 2013 Mar 27;27(6):889–97. doi: 10.1097/QAD.0b013e32835e1554. PMID: 23276806. Excluded: Inadequate duration.23276806
Molina JM, Lamarca A, Andrade-Villanueva J, . Efficacy and safety of once daily elvitegravir versus twice daily raltegravir in treatment-experienced patients with HIV-1 receiving a ritonavir-boosted protease inhibitor: randomised, double-blind, phase 3, non-inferiority study. Lancet Infect Dis. 2012 Jan;12(1):27–35. doi: 10.1016/S1473-3099(11)70249-3. PMID: 22015077. Excluded: Wrong population.22015077
Mollan KR, Smurzynski M, Eron JJ, . Association between efavirenz as initial therapy for HIV-1 infection and increased risk for suicidal ideation or attempted or completed suicide: An analysis of trial data. Ann Intern Med. 2014;161(1):1–10. PMID: 24979445. Excluded: included within an included systematic review.24979445
Montoy JC, Chan GK, Mahadevan SV. Opt-in versus opt-out HIV screening in emergency departments: A randomized trial. Ann Emerg Med. 2012 START: 2012 Oct 8 CONFERENCE END: 2012 Oct 9, American College of Emergency Physicians, ACEP Research Forum 2012 Denver, CO United States;60(4 SUPPL. 1):S103. Excluded: Wrong intervention.
Montoy JC, Dow WH, Kaplan BC. Patient choice in opt-in, active choice, and opt-out HIV screening: randomized clinical trial. BMJ. 2016;532:h6895. doi: 10.1136/bmj.h6895. PMID: 26786744. Excluded: Wrong intervention.26786744
Mudiope PK, Kim S, Wabwire D, . Long-term clinical and immunologic outcomes of HIV-infected women with and without previous exposure to nevirapine. Trop Med Int Health. 2013 Mar;18(3):344–51. doi: 10.1111/tmi.12054. PMID: 23289497. Excluded: Wrong country.23289497
Mudzviti T, Sibanda M, Gavi S, . Implementing a pharmacovigilance program to evaluate cutaneous adverse drug reactions in an antiretroviral access program. J Infect Dev Ctries. 2012;6(11):806–8. doi: 10.3855/jidc.1908. PMID: 23277506. Excluded: Wrong country.23277506
Mugo NR, Hong T, Celum C, . Pregnancy incidence and outcomes among women receiving preexposure prophylaxis for HIV prevention: a randomized clinical trial. Jama. 2014 Jul 23-30;312(4):362–71. doi: 10.1001/jama.2014.8735. PMID: 25038355. Excluded: Wrong intervention.25038355
Mugusi SF, Ngaimisi E, Janabi MY, . Risk factors for mortality among HIV-positive patients with and without active tuberculosis in Dar es Salaam, Tanzania. Antiviral Ther. 2012;17(2):265–74. doi: 10.3851/IMP1956. PMID: 22293579. Excluded: Wrong country.22293579
Munene E, Ekman B. Does duration on antiretroviral therapy determine health-related quality of life in people living with HIV? A cross-sectional study in a regional referral hospital in Kenya. Glob Health Action. 2014;7:23554. doi: 10.3402/gha.v7.23554. PMID: 24713353. Excluded: Wrong country.24713353
Murphy K, Hoover DR, Shi Q, . Association of self-reported race with AIDS death in continuous HAART users in a cohort of HIV-infected women in the United States. AIDS. 2013 Sep 24;27(15):2413–23. doi: 10.1097/01.aids.0000432537.92958.73. PMID: 24037210. Excluded: Wrong study design for Key Question.24037210
Murray M, Hogg RS, Lima VD, . The effect of injecting drug use history on disease progression and death among HIV-positive individuals initiating combination antiretroviral therapy: collaborative cohort analysis. HIV Med. 2012 Feb;13(2):89–97. doi: 10.1111/j.1468-1293.2011.00940.x. PMID: 21819529. Excluded: Wrong comparator.21819529
Mussini C, Galli L, Lepri AC, . Incidence, timing, and determinants of bacterial pneumonia among HIV-infected patients: data from the ICONA Foundation Cohort. J Acquir Immune Defic Syndr. 2013 Jul 1;63(3):339–45. doi: 10.1097/QAI.0b013e318295ab85. PMID: 23591636. Excluded: Wrong outcome.23591636
Mwesigire DM, Martin F, Seeley J, . Relationship between CD4 count and quality of life over time among HIV patients in Uganda: a cohort study. Health Qual Life Outcomes. 2015;13:144. doi: 10.1186/s12955-015-0332-3. PMID: 26370702. Excluded: Wrong country.26370702
Nabatanzi R, Bayigga L, Ssinabulya I, . Low antigen-specific CD4 T-cell immune responses despite normal absolute CD4 counts after long-term antiretroviral therapy an African cohort. Immunol Lett. 2014 Dec;162(2 Pt B):264–72. doi: 10.1016/j.imlet.2014.09.016. PMID: 25263953. Excluded: Wrong country.25263953
Naidoo K, Hassan-Moosa R, Yende-Zuma N, . High mortality rates in men initiated on anti-retroviral treatment in KwaZulu-Natal, South Africa. PLoS One. 2017;12(9):e0184124. doi: 10.1371/journal.pone.0184124. PMID: 28902869. Excluded: Wrong comparator.28902869
Nan C, Shaefer M, Urbaityte R, . Abacavir use and risk for myocardial infarction and cardiovascular events: Pooled analysis of data from clinical trials. Open Forum Infect Dis. 2018 May;5(5):ofy086. doi: 10.1093/ofid/ofy086. PMID: 29766019. Excluded: Inadequate duration.29766019
Ndagije H, Nambasa V, Namagala E, . Targeted spontaneous reporting of suspected renal toxicity in patients undergoing highly active anti-retroviral therapy in two public health facilities in Uganda. Drug Saf. 2015 Apr;38(4):395–408. doi: 10.1007/s40264-015-0277-9. PMID: 25749663. Excluded: Wrong country.25749663
Nduka C, Sarki A, Uthman O, . Impact of antiretroviral therapy on serum lipoprotein levels and dyslipidemias: a systematic review and meta-analysis. Int J Cardiol. 2015 Nov 15;199:307–18. doi: 10.1016/j.ijcard.2015.07.052. PMID: 26241636. Excluded: Wrong outcome.26241636
Nguyen KA, Peer N, Mills EJ, . A meta-analysis of the metabolic syndrome prevalence in the global HIV-infected population. PLoS One. 2016;11(3):e0150970. doi: 10.1371/journal.pone.0150970. PMID: 27008536. Excluded: Wrong outcome.27008536
Nishijima T, Komatsu H, Teruya K, . Once-daily darunavir/ritonavir and abacavir/lamivudine versus tenofovir/emtricitabine for treatment-naive patients with a baseline viral load of more than 100 000 copies/ml. AIDS. 2013 Mar 13;27(5):839–42. doi: 10.1097/QAD.0b013e32835cadb7. PMID: 23719354. Excluded: Wrong comparator.23719354
Nishijima T, Takano M, Ishisaka M, . Abacavir/lamivudine versus tenofovir/emtricitabine with atazanavir/ritonavir for treatment-naive Japanese patients with HIV-1 infection: a randomized multicenter trial. Intern Med. 2013;52(7):735–44. PMID: 23545667. Excluded: Wrong outcome.23545667
Nsanzimana S, Remera E, Kanters S, . Effect of baseline CD4 cell count at linkage to HIV care and at initiation of antiretroviral therapy on mortality in HIV-positive adult patients in Rwanda: a nationwide cohort study.[Erratum appears in Lancet HIV. 2015 Sep;2(9):e364]. Lancet HIV. 2015 Sep;2(9):e376–84. doi: 10.1016/S2352-3018(15)00112-5. PMID: 26423551. Excluded: Wrong country.26423551
Nunn A, Towey C, Chan PA, . Routine HIV screening in an urban community health center: Results from a geographically focused implementation science program. Public Health Rep. 2016 Jan-Feb;131 Suppl 1:30–40. PMID: 26862228. Excluded: Wrong study design for Key Question.26862228
Nyaku AN, Williams LM, Galvin SR. Comparison of HIV testing uptake in an urban academic emergency department using different testing assays and support systems. AIDS Patient Care STDS. 2016 Apr;30(4):166–9. doi: 10.1089/apc.2015.0297. PMID: 26982908. Excluded: Wrong study design for Key Question.26982908
Obiabo YO, Ogunrin OA, Ogun AS. Effects of highly active antiretroviral therapy on cognitive functions in severely immune-compromised HIV-seropositive patients. J Neurol Sci. 2012 Feb 15;313(1-2):115–22. doi: 10.1016/j.jns.2011.09.011. PMID: 21996271. Excluded: Wrong country.21996271
O’Brien D, Spelman T, Greig J, . Risk factors for mortality during antiretroviral therapy in older populations in resource-limited settings. J Int AIDS Soc. 2016;19(1):20665. doi: 10.7448/IAS.19.1.20665. PMID: 26782169. Excluded: Wrong country.26782169
Odafe S, Idoko O, Badru T, . Patients’ demographic and clinical characteristics and level of care associated with lost to follow-up and mortality in adult patients on first-line ART in Nigerian hospitals. J Int AIDS Soc. 2012;15(2):17424. doi: 10.7448/IAS.15.2.17424. PMID: 23010378. Excluded: Wrong country.23010378
Olsen CM, Knight LL, Green AC. Risk of melanoma in people with HIV/AIDS in the pre- and post-HAART eras: a systematic review and meta-analysis of cohort studies. PLoS One. 2014;9(4):e95096. doi: 10.1371/journal.pone.0095096. PMID: 24740329. Excluded: Wrong outcome.24740329
O’Neill TJ, Nguemo JD, Tynan AM, . Risk of colorectal cancer and associated mortality in HIV: A systematic review and meta-analysis. J Acquir Immune Defic Syndr. 2017 Aug 01;75(4):439–47. doi: 10.1097/QAI.0000000000001433. PMID: 28471838. Excluded: Wrong comparator.28471838
Orkin C, DeJesus E, Khanlou H, . Final 192-week efficacy and safety of once-daily darunavir/ritonavir compared with lopinavir/ritonavir in HIV-1-infected treatment-naive patients in the ARTEMIS trial. HIV Med. 2013 Jan;14(1):49–59. doi: 10.1111/j.1468-1293.2012.01060.x. PMID: 23088336. Excluded: Wrong comparator.23088336
Otwombe KN, Laher F, Tutu-Gxashe T, . The effect of a maturing antiretroviral program on early mortality for patients with advanced immune-suppression in Soweto, South Africa. PLoS One. 2013;8(11):e81538. doi: 10.1371/journal.pone.0081538. PMID: 24312317. Excluded: Wrong country.24312317
Pacheco YM, Jarrin I, Rosado I, . Increased risk of non-AIDS-related events in HIV subjects with persistent low CD4 counts despite cART in the CoRIS cohort. Antiviral Res. 2015 May;117:69–74. doi: 10.1016/j.antiviral.2015.03.002. PMID: 25766861. Excluded: Wrong outcome.25766861
Pammi M, Arumainayagam J, Kumari B, . Safety and efficacy of tenofovir/emtricitabine or abacavir/lamivudine in combination with efavirenz in treatment naive HIV patients: a 5 year retrospective observational cohort study. (the TOKEN Study). Int J Clin Pract. 2013 Sep;67(9):922–3. doi: 10.1111/ijcp.12233. PMID: 23952469. Excluded: Wrong country.23952469
Pantazis N, Psichogiou M, Paparizos V, . Treatment modifications and treatment-limiting toxicities or side effects: Risk factors and temporal trends. AIDS Res Hum Retroviruses. 2015 Jul;31(7):707–17. doi: 10.1089/AID.2015.0018. PMID: 25950848. Excluded: Wrong study design for Key Question.25950848
Patel P, Bennett B, Sullivan T, . Rapid HIV screening: missed opportunities for HIV diagnosis and prevention. J Clin Virol. 2012 May;54(1):42–7. doi: 10.1016/j.jcv.2012.01.022. PMID: 22381919. Excluded: Wrong comparator.22381919
Patterson S, Cescon A, Samji H, . Cohort profile: HAART Observational Medical Evaluation and Research (HOMER) cohort. Int J Epidemiol. 2015 Feb;44(1):58–67. doi: 10.1093/ije/dyu046. PMID: 24639444. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).24639444
Pedrol E, Llibre JM, Tasias M, . Outcome of neuropsychiatric symptoms related to an antiretroviral drug following its substitution by nevirapine: the RELAX study. HIV Med. 2015 Nov;16(10):628–34. doi: 10.1111/hiv.12298. PMID: 26238151. Excluded: Wrong intervention.26238151
Perez-Molina JA, Diaz-Menendez M, Plana MN, . Very late initiation of HAART impairs treatment response at 48 and 96 weeks: results from a meta-analysis of randomized clinical trials. J Antimicrob Chemother. 2012 Feb;67(2):312–21. doi: 10.1093/jac/dkr478. PMID: 22127587. Excluded: Wrong population.22127587
Perez-Molina JA, Mora Rillo M, Suarez-Lozano I, . Response to combined antiretroviral therapy according to gender and origin in a cohort of naive HIV-infected patients: GESIDA-5808 study. HIV Clin Trials. 2012 May-Jun;13(3):131–41. doi: 10.1310/hct1303-131. PMID: 22592093. Excluded: Wrong comparator.22592093
Peters PJ, Westheimer E, Cohen S, . Screening yield of HIV antigen/antibody combination and pooled HIV RNA testing for acute HIV infection in a high-prevalence population. JAMA. 2016 Feb 16;315(7):682–90. doi: 10.1001/jama.2016.0286. PMID: 26881371. Excluded: Wrong comparator.26881371
Petersen ML, Tran L, Geng EH, . Delayed switch of antiretroviral therapy after virologic failure associated with elevated mortality among HIV-infected adults in Africa. AIDS. 2014 Sep 10;28(14):2097–107. PMID: 24977440. Excluded: Wrong country.24977440
Petoumenos K, Reiss P, Ryom L, . Increased risk of cardiovascular disease (CVD) with age in HIV-positive men: a comparison of the D:A:D CVD risk equation and general population CVD risk equations. HIV Med. 2014 Nov;15(10):595–603. doi: 10.1111/hiv.12162. PMID: 24840675. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).24840675
Phanuphak N, Ananworanich J, Teeratakulpisarn N, . A 72-week randomized study of the safety and efficacy of a stavudine to zidovudine switch at 24 weeks compared to zidovudine or tenofovir disoproxil fumarate when given with lamivudine and nevirapine. Antiviral Ther. 2012;17(8):1521–31. doi: 10.3851/IMP2497. PMID: 23220732. Excluded: Inadequate duration.23220732
Phusanti S, Manosudprasit K, Sungkanuparph S. Long-term liver diseases after initiation of antiretroviral therapy in HIV-infected patients with and without HBV or HCV coinfection. J Int Assoc Provid AIDS Care. 2017 Mar/Apr;16(2):194–200. doi: 10.1177/2325957416686838. PMID: 28071205. Excluded: Wrong intervention.28071205
Piwowar-Manning E, Fogel JM, Laeyendecker O, . Failure to identify HIV-infected individuals in a clinical trial using a single HIV rapid test for screening. HIV Clin Trials. 2014 Mar-Apr;15(2):62–8. doi: 10.1310/hct1502-62. PMID: 24710920. Excluded: Wrong study design for Key Question.24710920
Podzamczer D, Imaz A, Perez I, . Abacavir/lamivudine plus darunavir/ritonavir in routine clinical practice: a multicentre experience in antiretroviral therapy-naive and -experienced patients. J Antimicrob Chemother. 2014 Sep;69(9):2536–40. doi: 10.1093/jac/dku157. PMID: 24833755. Excluded: Inadequate duration.24833755
Pottie K, Medu O, Welch V, . Effect of rapid HIV testing on HIV incidence and services in populations at high risk for HIV exposure: an equity-focused systematic review. BMJ Open. 2014;4(12):e006859. doi: 10.1136/bmjopen-2014-006859. PMID: 25510889. Excluded: Wrong comparator.25510889
Prekker ME, Gary BM, Patel R, . A comparison of routine, opt-out HIV screening with the expected yield from physician-directed HIV testing in the ED. Am J Emerg Med. 2015 Apr;33(4):506–11. doi: 10.1016/j.ajem.2014.12.057. PMID: 25727169. Excluded: Wrong study design for Key Question.25727169
Prosperi MC, Fabbiani M, Fanti I, . Predictors of first-line antiretroviral therapy discontinuation due to drug-related adverse events in HIV-infected patients: a retrospective cohort study. BMC Infect Dis. 2012;12:296. doi: 10.1186/1471-2334-12-296. PMID: 23145925. Excluded: Wrong outcome.23145925
Protopopescu C, Raffi F, Spire B, . Twelve-year mortality in HIV-infected patients receiving antiretroviral therapy: the role of social vulnerability. The ANRS CO8 APROCO-COPILOTE cohort. Antiviral Ther. 2015;20(7):763–72. doi: 10.3851/IMP2960. PMID: 25859625. Excluded: Wrong outcome.25859625
Pujari SN, Smith C, Makane A, . Higher risk of renal impairment associated with tenofovir use amongst people living with HIV in India: a comparative cohort analysis between Western India and United Kingdom. BMC Infect Dis. 2014;14:173. doi: 10.1186/1471-2334-14-173. PMID: 24679159. Excluded: Wrong comparator.24679159
Raffi F, Babiker AG, Richert L, . Ritonavir-boosted darunavir combined with raltegravir or tenofovir-emtricitabine in antiretroviral-naive adults infected with HIV-1: 96 week results from the NEAT001/ANRS143 randomised non-inferiority trial. Lancet. 2014;384(9958):1942–51. PMID: 25103176. Excluded: Wrong intervention.25103176
Raffi F, Jaeger H, Quiros-Roldan E, . Once-daily dolutegravir versus twice-daily raltegravir in antiretroviral-naive adults with HIV-1 infection (SPRING-2 study): 96 week results from a randomised, double-blind, non-inferiority trial. Lancet Infect Dis. 2013 Nov;13(11):927–35. doi: 10.1016/S1473-3099(13)70257-3. PMID: 24074642. Excluded: Inadequate duration.24074642
Rajesh R, Vidyasagar S, Varma DM, . A prospective study of highly active antiretroviral therapy in Indian human immunodeficiency virus positive patients. Int J Risk Saf Med. 2013 Jan 1;25(1):53–65. doi: 10.3233/JRS-130580. PMID: 23442298. Excluded: Wrong country.23442298
Rasmussen LD, Kronborg G, Larsen CS, . Statin therapy and mortality in HIV-infected individuals; a Danish nationwide population-based cohort study. PLoS One. 2013;8(3):e52828. doi: 10.1371/journal.pone.0052828. PMID: 23469159. Excluded: Wrong intervention.23469159
Read TR, Hocking JS, Bradshaw CS, . Provision of rapid HIV tests within a health service and frequency of HIV testing among men who have sex with men: randomised controlled trial. BMJ. 2013;347:f5086. doi: 10.1136/bmj.f5086. PMID: 24004988. Excluded: Wrong outcome.24004988
Reniers G, Slaymaker E, Nakiyingi-Miiro J, . Mortality trends in the era of antiretroviral therapy: evidence from the Network for Analysing Longitudinal Population based HIV/AIDS data on Africa (ALPHA). Aids. 2014 Nov;28 Suppl 4:S533–42. doi: 10.1097/qad.0000000000000496. PMID: 25406756. Excluded: Wrong country.25406756
Reynes J, Trinh R, Pulido F, . Lopinavir/ritonavir combined with raltegravir or tenofovir/emtricitabine in antiretroviral-naive subjects: 96-week results of the PROGRESS study. AIDS Res Hum Retroviruses. 2013 Feb;29(2):256–65. doi: 10.1089/AID.2011.0275. PMID: 22730929. Excluded: Wrong comparator.22730929
Riveiro-Barciela M, Falco V, Burgos J, . Neurological opportunistic infections and neurological immune reconstitution syndrome: impact of one decade of highly active antiretroviral treatment in a tertiary hospital. HIV Med. 2013 Jan;14(1):21–30. doi: 10.1111/j.1468-1293.2012.01033.x. PMID: 22726389. Excluded: Wrong population.22726389
Rockstroh JK, DeJesus E, Henry K, . A randomized, double-blind comparison of coformulated elvitegravir/cobicistat/emtricitabine/tenofovir DF vs ritonavir-boosted atazanavir plus coformulated emtricitabine and tenofovir DF for initial treatment of HIV-1 infection: analysis of week 96 results. J Acquir Immune Defic Syndr. 2013 Apr 15;62(5):483–6. doi: 10.1097/QAI.0b013e318286415c. PMID: 23337366. Excluded: Wrong outcome.23337366
Rokx C, Fibriani A, van de Vijver DA, . Increased virological failure in naive HIV-1-infected patients taking lamivudine compared with emtricitabine in combination with tenofovir and efavirenz or nevirapine in the Dutch nationwide ATHENA cohort. Clin Infect Dis. 2015 Jan 1;60(1):143–53. doi: 10.1093/cid/ciu763. PMID: 25273080. Excluded: Inadequate duration.25273080
Roy A, Anaraki S, Hardelid P, . Universal HIV testing in London tuberculosis clinics: a cluster randomised controlled trial. Eur Respir J. 2013 Mar;41(3):627–34. doi: 10.1183/09031936.00034912. PMID: 22700845. Excluded: Wrong population.22700845
Rutstein RM, Samson P, Fenton T, . Long-term safety and efficacy of atazanavir-based therapy in HIV-infected infants, children and adolescents: the Pediatric AIDS Clinical Trials Group Protocol 1020A. Pediatr Infect Dis J. 2015 Feb;34(2):162–7. doi: 10.1097/INF.0000000000000538. PMID: 25232777. Excluded: Inadequate duration.25232777
Ryan R, Dayaram YK, Schaible D, . Outcomes in older versus younger patients over 96 weeks in HIV-1- infected patients treated with rilpivirine or efavirenz in ECHO and THRIVE. Curr HIV Res. 2013 Oct;11(7):570–5. PMID: 24467642. Excluded: Wrong comparator.24467642
Ryom L, Mocroft A, Lundgren JD. Antiretroviral therapy, immune suppression and renal impairment in HIV-positive persons. Curr Opin HIV AIDS. 2014 Jan;9(1):41–7. doi: 10.1097/COH.0000000000000023. PMID: 24225381. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).24225381
Sarfo FS, Sarfo MA, Kasim A, . Long-term effectiveness of first-line non-nucleoside reverse transcriptase inhibitor (NNRTI)-based antiretroviral therapy in Ghana. J Antimicrob Chemother. 2014 Jan;69(1):254–61. doi: 10.1093/jac/dkt336. PMID: 24003181. Excluded: Wrong country.24003181
Schnall R, Liu N, Sperling J, . An electronic alert for HIV screening in the emergency department increases screening but not the diagnosis of HIV. Appl Clin Inform. 2014;5(1):299–312. doi: 10.4338/ACI-2013-09-RA-0075. PMID: 24734140. Excluded: Wrong intervention.24734140
Second-Line Study Group, Boyd MA, Kumarasamy N, . Ritonavir-boosted lopinavir plus nucleoside or nucleotide reverse transcriptase inhibitors versus ritonavir-boosted lopinavir plus raltegravir for treatment of HIV-1 infection in adults with virological failure of a standard first-line ART regimen (SECOND-LINE): a randomised, open-label, non-inferiority study. Lancet. 2013 Jun 15;381(9883):2091–9. doi: 10.1016/S0140-6736(13)61164-2. PMID: 23769235. Excluded: Wrong population.23769235
Sendagire I, Cobelens F, Kambugu A, . Frequency and predictors for late start of antiretroviral therapy in primary care clinics, Kampala, Uganda. J Acquir Immune Defic Syndr. 2012 Nov 1;61(3):e33–9. doi: 10.1097/QAI.0b013e318265aad7. PMID: 22820807. Excluded: Wrong country.22820807
Seng R, Goujard C, Krastinova E, . Influence of lifelong cumulative HIV viremia on long-term recovery of CD4+ cell count and CD4+/CD8+ ratio among patients on combination antiretroviral therapy. AIDS. 2015 Mar 13;29(5):595–607. doi: 10.1097/QAD.0000000000000571. PMID: 25715104. Excluded: Wrong outcome.25715104
Sengayi M, Babb C, Egger M, . HIV testing and burden of HIV infection in black cancer patients in Johannesburg, South Africa: a cross-sectional study. BMC Cancer. 2015;15:144. doi: 10.1186/s12885-015-1171-7. PMID: 25884599. Excluded: Wrong country.25884599
Sepako E, Glennie SJ, Jambo KC, . Incomplete recovery of pneumococcal CD4 T cell immunity after initiation of antiretroviral therapy in HIV-infected malawian adults. PLoS One. 2014;9(6):e100640. doi: 10.1371/journal.pone.0100640. PMID: 24959834. Excluded: Wrong country.24959834
Serrano Vicente MC, Navarro Aznarez H, Carrera Lasfuentes P, . [Safety and effectiveness of salvage therapy in HIV patients]. Farm Hosp. 2012 Jul-Aug;36(4):187–93. PMID: 22099741. Excluded: Not English language but possibly relevant.22099741
Serrano-Villar S, Perez-Elias MJ, Dronda F, . Increased risk of serious non-AIDS-related events in HIV-infected subjects on antiretroviral therapy associated with a low CD4/CD8 ratio. PLoS One. 2014;9(1):e85798. doi: 10.1371/journal.pone.0085798. PMID: 24497929. Excluded: Wrong outcome.24497929
Serrano-Villar S, Sainz T, Lee SA, . HIV-infected individuals with low CD4/CD8 ratio despite effective antiretroviral therapy exhibit altered T cell subsets, heightened CD8+ T cell activation, and increased risk of non-AIDS morbidity and mortality. PLoS Pathog. 2014 May;10(5):e1004078. doi: 10.1371/journal.ppat.1004078. PMID: 24831517. Excluded: Wrong outcome.24831517
Serrano-Villar S, Sainz T, Ma ZM, . Effects of combined CCR5/integrase inhibitors-based regimen on mucosal immunity in HIV-infected patients naive to antiretroviral therapy: A pilot randomized trial.[Erratum appears in PLoS Pathog. 2016 Mar;12(3):e1005540; PMID: 27015639]. PLoS Pathog. 2016 Jan;12(1):e1005381. doi: 10.1371/journal.ppat.1005381. PMID: 26795282. Excluded: Wrong outcome.26795282
Seth P, Figueroa A, Wang G, . HIV testing, HIV positivity, and linkage and referral services in correctional facilities in the United States, 2009-2013. Sex Transm Dis. 2015 Nov;42(11):643–9. doi: 10.1097/OLQ.0000000000000353. PMID: 26462190. Excluded: Wrong study design for Key Question.26462190
Seth P, Wang G, Sizemore E, . HIV testing and HIV service delivery to populations at high risk attending sexually transmitted disease clinics in the United States, 2011-2013. Am J Public Health. 2015 Nov;105(11):2374–81. doi: 10.2105/AJPH.2015.302778. PMID: 26378854. Excluded: Wrong study design for Key Question.26378854
Setkina S, Dotsenko M, Bondar S, . Safety and effectiveness of highly active antiretroviral therapy in treatment-naive HIV patients: Preliminary findings of a cohort event monitoring study in Belarus. Drug Saf. 2015 Apr;38(4):365–72. doi: 10.1007/s40264-015-0279-7. PMID: 25808626. Excluded: Inadequate duration.25808626
Shaffer D, Hughes MD, Sawe F, . Cardiovascular disease risk factors in HIV-infected women after initiation of lopinavir/ritonavir- and nevirapine-based antiretroviral therapy in Sub-Saharan Africa: A5208 (OCTANE). J Acquir Immune Defic Syndr. 2014 Jun 1;66(2):155–63. doi: 10.1097/QAI.0000000000000131. PMID: 24562349. Excluded: Wrong country.24562349
Sharma A, Hoover DR, Shi Q, . Relationship between body mass index and mortality in HIV-infected HAART users in the Women’s Interagency HIV Study. PLoS One. 2015;10(12):e0143740. doi: 10.1371/journal.pone.0143740. PMID: 26699870. Excluded: Wrong study design for Key Question.26699870
Shih HI, Ko NY, Hsu HC, . Rapid human immunodeficiency virus screening in an emergency department in a region with low HIV seroprevalence. Jpn J Infect Dis. 2015;68(4):305–11. doi: 10.7883/yoken.JJID.2014.088. PMID: 25720638. Excluded: Wrong study design for Key Question.25720638
Shubber Z, Calmy A, Andrieux-Meyer I, . Adverse events associated with nevirapine and efavirenz-based first-line antiretroviral therapy: a systematic review and meta-analysis. AIDS. 2013 Jun 1;27(9):1403–12. doi: 10.1097/QAD.0b013e32835f1db0. PMID: 23343913. Excluded: Wrong intervention.23343913
Singano V, Amberbir A, Garone D, . The burden of gynecomastia among men on antiretroviral therapy in Zomba, Malawi. PLoS One. 2017;12(11):e0188379. doi: 10.1371/journal.pone.0188379. PMID: 29155891. Excluded: Wrong outcome.29155891
Sloan DJ, van Oosterhout JJ, Malisita K, . Evidence of improving antiretroviral therapy treatment delays: an analysis of eight years of programmatic outcomes in Blantyre, Malawi. BMC Public Health. 2013;13:490. doi: 10.1186/1471-2458-13-490. PMID: 23687946. Excluded: Wrong country.23687946
Soliman EZ, Sharma S, Arasteh K, . Baseline cardiovascular risk in the INSIGHT Strategic Timing of AntiRetroviral Treatment (START) trial. HIV Med. 2015 Apr;16 Suppl 1:46–54. doi: 10.1111/hiv.12233. PMID: 25711323. Excluded: Wrong study design for Key Question.25711323
Surgers L, Valin N, Viala C, . Evaluation of the efficacy and safety of switching to tenofovir, emtricitabine, and rilpivirine in treatment-experienced patients. J Acquir Immune Defic Syndr. 2015 Jan 1;68(1):e10–2. doi: 10.1097/QAI.0000000000000401. PMID: 25321178. Excluded: Inadequate duration.25321178
Suthar AB, Ford N, Bachanas PJ, . Towards universal voluntary HIV testing and counselling: a systematic review and meta-analysis of community-based approaches. PLoS Med. 2013 Aug;10(8):e1001496. doi: 10.1371/journal.pmed.1001496. PMID: 23966838. Excluded: Wrong study design for Key Question.23966838
Swartz JE, Vandekerckhove L, Ammerlaan H, . Efficacy of tenofovir and efavirenz in combination with lamivudine or emtricitabine in antiretroviral-naive patients in Europe. J Antimicrob Chemother. 2015;70(6):1850–7. doi: 10.1093/jac/dkv033. PMID: 25740950. Excluded: Inadequate duration.25740950
Tanaka H, Arai M, Tomoda Y, . Evaluation of renal adverse effects of combination anti-retroviral therapy including tenofovir in HIV-infected patients. J Pharm Pharm Sci. 2013;16(3):405–13. PMID: 24021289. Excluded: Inadequate duration.24021289
Tanuma J, Lee KH, Haneuse S, . Incidence of AIDS-defining opportunistic infections and mortality during antiretroviral therapy in a cohort of adult HIV-infected individuals in Hanoi, 2007-2014. PLoS One. 2016;11(3):e0150781. doi: 10.1371/journal.pone.0150781. PMID: 26939050. Excluded: Inadequate duration.26939050
Teofilo E, Rocha-Pereira N, Kuhlmann B, . Long-term efficacy, tolerability, and renal safety of atazanavir/ritonavir-based antiretroviral therapy in a cohort of treatment-naive patients with HIV-1 infection: the REMAIN study. HIV Clin Trials. 2016 Feb;17(1):17–28. doi: 10.1080/15284336.2015.1112494. PMID: 26899539. Excluded: Wrong outcome.26899539
Todd JV, Cole SR, Pence BW, . Effects of antiretroviral therapy and depressive symptoms on all-cause mortality among HIV-infected women. Am J Epidemiol. 2017 May 15;185(10):869–78. doi: 10.1093/aje/kww192. PMID: 28430844. Excluded: Wrong outcome.28430844
U.S. Department of Health and Human Services. Guidelines for the use of antiretroviral agents in adults and adolescents living with HIV. Accessed January 11, 2019. Excluded: Not a study.
Uthman OA, Okwundu C, Gbenga K, . Optimal timing of antiretroviral therapy initiation for HIV-infected adults with newly diagnosed pulmonary tuberculosis: A systematic review and meta-analysis. Ann Intern Med. 2015 Jul 7;163(1):32–9. doi: 10.7326/M14-2979. PMID: 26148280. Excluded: Wrong population.26148280
Vendruscolo O, Majdalani M, Mota R, . Frequency of adverse events associated to antiretroviral drugs in patients starting therapy in Salvador, Brazil. Braz J Infect Dis. 2015 Jan-Feb;19(1):108–9. doi: 10.1016/j.bjid.2014.09.008. PMID: 25527110. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).25527110
Wada N, Jacobson LP, Cohen M, . Cause-specific mortality among HIV-infected individuals, by CD4(+) cell count at HAART initiation, compared with HIV-uninfected individuals. AIDS. 2014 Jan 14;28(2):257–65. doi: 10.1097/QAD.0000000000000078. PMID: 24105030. Excluded: Wrong study design for Key Question.24105030
Wolff MJ, Giganti MJ, Cortes CP, . A decade of HAART in Latin America: Long term outcomes among the first wave of HIV patients to receive combination therapy. PLoS One. 2017;12(6):e0179769. doi: 10.1371/journal.pone.0179769. PMID: 28651014. Excluded: Wrong intervention.28651014
Wu PY, Cheng CY, Liu CE, . Multicenter study of skin rashes and hepatotoxicity in antiretroviral-naive HIV-positive patients receiving non-nucleoside reverse-transcriptase inhibitor plus nucleoside reverse-transcriptase inhibitors in Taiwan. PLoS One. 2017;12(2):e0171596. doi: 10.1371/journal.pone.0171596. PMID: 28222098. Excluded: Inadequate duration.28222098
Zhyvytsia D. Mortality and its predictors among highly active antiretroviral therapy naive hiv-infected individuals: data from prospective cohort study in Ukraine. Georgian Med. 2014 Jul-Aug(232-233):69–74. PMID: 25214276. Excluded: Wrong population.25214276
Zolopa A, Sax PE, DeJesus E, . A randomized double-blind comparison of coformulated elvitegravir/cobicistat/emtricitabine/tenofovir disoproxil fumarate versus efavirenz/emtricitabine/tenofovir disoproxil fumarate for initial treatment of HIV-1 infection: analysis of week 96 results. J Acquir Immune Defic Syndr. 2013 May 1;63(1):96–100. doi: 10.1097/QAI.0b013e318289545c. PMID: 23392460. Excluded: Inadequate duration.23392460

## Appendix A6 Currently Recommended Antiretroviral Therapy Regimens

### Preferred Regimens

Integrase strand transfer inhibitor + two nucleoside reverse transcriptase inhibitors:

- Bictegravir/tenofovir alafenamide/emtricitabine
- Dolutegravir/abacavir/lamivudine^*^
- Dolutegravir + tenofovir^†^/emtricitabine^*^
- Raltegravir + tenofovir^†^/emtricitabine^*^

### Secondary Regimens (Based on Clinical Considerations)

Integrase strand transfer inhibitor + two nucleoside reverse transcriptase inhibitors:

- Elvitegravir/tenofovir^†^/emtricitabine
- Raltegravir + abacavir/lamivudine^*^

Boosted protease inhibitor + two nucleoside reverse transcriptase inhibitors:

- Darunavir/cobicistat or darunavir/ritonavir + tenofovir^†^/emtricitabine^*^
- Atazanavir/cobicistat or atazanavir/ritonavir + tenofovir^†^/emtricitabine^*^
- Darunavir/cobicistat or darunavir/ritonavir + abacavir/lamivudine^*^

Nonnucleoside reverse transcriptase inhibitor + two nucleoside reverse transcriptase inhibitors:

- Doravirine/tenofovir disoproxil fumarate^†^/lamivudine or doravirine + tenofovir alafenamide^†^/emtricitabine
- Efavirenz + tenofovir disoproxil fumarate^†^/emtricitabine^*^
- Rilpivirine/tenofovir^†^/emtricitabine^*^

Regimens to consider when abacavir, tenofovir alafenamide, and tenofovir disoproxil fumarate cannot be used or are not optimal:

- Dolutegravir + lamivudine
- Darunavir/ritonavir + raltegravir twice daily
- Darunavir/ritonavir once daily + lamivudine^*^

Source: Panel on Antiretroviral Guidelines for Adults and Adolescents. Guidelines for the Use of Antiretroviral Agents in Adults and Adolescents Living with HIV. Department of Health and Human Services. October 25, 2018. Available at https://aidsinfo.nih.gov/contentfiles/lvguidelines/adultandadolescentgl.pdf.

* Lamivudine may be substituted for emtricitabine, or vice versa.

† Tenofovir alafenamide and tenofovir disoproxil fumarate are two forms of tenofovir approved by the U.S. Food and Drug Administration.

## Appendix A7 Criteria for Assessing Internal Validity of Individual Studies

### Systematic Reviews

Criteria:

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

Definition of ratings based on above criteria:

Good:: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions
Fair:: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies
Poor:: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

### Case-Control Studies

Criteria:

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls, with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

Definition of ratings based on above criteria:

Good:: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; accurate diagnostic procedures and measurements applied equally to cases and controls; and appropriate attention to confounding variables
Fair:: Recent, relevant, and without major apparent selection or diagnostic workup bias, but response rate less than
  80 percent or attention to some but not all important confounding variables
Poor:: Major selection or diagnostic workup bias, response rate less than 50 percent, or inattention to confounding variables

### RCTs and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  - For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  - For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Definition of ratings based on above criteria:

Good:: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair:: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
Poor:: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of ratings based on above criteria:

Good:: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease
Fair:: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients
Poor:: Has a fatal flaw, such as: Uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

Source: U.S. Preventive Services Task Force Procedure Manual. Accessed at https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes.

## Appendix A8 Expert Reviewers of the Draft Report

❖ Maggie Czarnogorski, MD, MPH, Deputy Director, Comprehensive Women’s Health, U.S. Department of Veterans Affairs
❖ Lisa Metsch, PhD, Chair of Social Medicine, Columbia University
❖ Zelalem Temesgen, MD, Professor of Medicine, Mayo Clinic Director, Mayo Clinic Global HIV Education Initiative, Mayo Center for Tuberculosis
❖ Brandy Peaker, MD, MPH, Centers for Disease Control and Prevention
❖ Philip Peters, MD, DTM&H, Division of HIV/AIDS Prevention, Centers for Disease Control and Prevention

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the report findings.