# References

1 Rischitelli G, Nygren P, Bougatsos C, . Screening for elevated lead levels in childhood and pregnancy: an updated summary of evidence for the US Preventive Services Task Force. Pediatrics. 2006;118(6):e1867–95. doi: 10.1542/peds.2006-2284. PMID: 17142507.17142507
2 Centers for Disease Control and Prevention. Standard surveillance definitions and classifications. 2013. http://www.cdc.gov/nceh/lead/data/definitions.htm. Accessed January 29, 2019.
3 Centers for Disease Control and Prevention. Guidelines for the identification and management of lead exposure in pregnant and lactating women. U.S. Department of Health and Human Services. Atlanta, GA; 2010. www.cdc.gov/nceh/lead/publications/leadandpregnancy2010.pdf. Accessed November 15, 2017.
4 Flora G, Gupta D, Tiwari A. Toxicity of lead: a review with recent updates. Interdiscip Toxicol. 2012;5(2):47–58. doi: 10.2478/v10102-012-0009-2. PMID: 23118587.23118587
5 Guidotti TL, Ragain L. Protecting children from toxic exposure: three strategies. Pediatr Clin North Am. 2007;54(2):227–35, vii. doi: 10.1016/j.pcl.2007.02.002. PMID: 17448358.17448358
6 Schober SE, Mirel LB, Graubard BI, . Blood lead levels and death from all causes, cardiovascular disease, and cancer: results from the NHANES III mortality study. Environ Health Perspect. 2006;114(10):1538–41. PMID: 17035139.17035139
7 Centers for Disease Control and Prevention, Roper WL, Houk VN, . Preventing lead poisoning in young children: A statement by the Centers for Disease Control, October 1991 Centers for Disease Control and Prevention. Atlanta, GA (United States): 1991.
8 International Agency for Research on Cancer (IARC). Agents classified by the IARC monographs, Volumes 1–112. 2015. monographs.iarc.fr/ENG/Classification/ClassificationsGroupOrder.pdf. Accessed November 15, 2017.
9 Department of Health and Human Services National Toxicology Program. Lead and Lead Compounds. 2016. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/lead.pdf Accessed February 9, 2018.
10 Miranda ML, Edwards SE, Swamy GK, . Blood lead levels among pregnant women: historical versus contemporaneous exposures. Int J Environ Res Public Health. 2010;7(4):1508–19. doi: 10.3390/ijerph7041508. PMID: 20617043.20617043
11 Sowers M, Jannausch M, Scholl T, . Blood lead concentrations and pregnancy outcomes. Arch Environ Health. 2002;57(5):489–95. doi: 10.1080/00039890209601442. PMID: 12641194.12641194
12 Muntner P, Menke A, DeSalvo KB, . Continued decline in blood lead levels among adults in the United States: the National Health and Nutrition Examination Surveys. Arch Intern Med. 2005;165(18):2155–61. doi: 10.1001/archinte.165.18.2155. PMID: 16217007.16217007
13 Centers for Disease Control and Prevention. Elevated blood lead levels in refugee children-New Hampshire, 2003-2004. MMWR. 2005;54(2):42–6. PMID: 15660019.15660019
14 Centers for Disease Control and Prevention. Blood lead levels-United States, 1999-2002. MMWR. 2005;54(20):513–6. PMID: 15917736.15917736
15 Tong S, von Schirnding YE, Prapamontol T. Environmental lead exposure: a public health problem of global dimensions. Bull World Health Organ. 2000;78(9):1068–77. PMID: 11019456.11019456
16 United States Environmental Protection Agency. Lead in Outdoor Air. 2016. www.epa.gov/lead/lead-outdoor-air. Accessed November 21, 2017.
17 Rabin R. The lead industry and lead water pipes “A Modest Campaign”. Am J Public Health. 2008;98(9):1584–92. doi: 10.2105/ajph.2007.113555. PMID: 18633098.18633098
18 Raab GM, Laxen DP, Anderson N, . The influence of pH and household plumbing on water lead concentration. Environ Geochem Health. 1993;15(4):191–200. doi: 10.1007/bf00146742. PMID: 24198138.24198138
19 Hanna-Attisha M, LaChance J, Sadler RC, . Elevated blood lead levels in children associated with the Flint drinking water crisis: a spatial analysis of risk and public health response. Am J Public Health. 2016;106(2):283–90. doi: 10.2105/AJPH.2015.303003. PMID: 26691115.26691115
20 Fletcher AM, Gelberg KH, Marshall EG. Reasons for testing and exposure sources among women of childbearing age with moderate blood lead levels. J Community Health. 1999;24(3):215–27. PMID: 10399653.10399653
21 United States Department of Labor. Occupational Safety and Health Standards. 1995. www.osha.gov/pls/oshaweb/owadisp.show_document?p_id=10033&p_table=STANDARDS. Accessed February 9, 2018.
22 Goyer RA. Nutrition and metal toxicity. Am J Clin Nutr. 1995;61:(3 Suppl):646s–50s. PMID: 7879732.7879732
23 Hernandez-Avila M, Gonzalez-Cossio T, Hernandez-Avila JE, . Dietary calcium supplements to lower blood lead levels in lactating women: a randomized placebo-controlled trial. Epidemiology. 2003;14(2):206–12. doi: 10.1097/01.Ede.0000038520.66094.34. PMID: 12606887.12606887
24 Rothenberg SJ, Karchmer S, Schnaas L, . Changes in serial blood lead levels during pregnancy. Environ Health Perspect. 1994;102(10):876–80. PMID: 9644197.9644197
25 Hertz-Picciotto I, Schramm M, Watt-Morse M, . Patterns and determinants of blood lead during pregnancy. Am J Epidemiol. 2000;152(9):829–37. PMID: 11085394.11085394
26 Ettinger AS, Lamadrid-Figueroa H, Tellez-Rojo MM, . Effect of calcium supplementation on blood lead levels in pregnancy: a randomized placebo-controlled trial. Environ Health Perspect. 2009;117(1):26–31. doi: 10.1289/ehp.11868. PMID: 19165383.19165383
27 Bellinger DC. Teratogen update: lead and pregnancy. Birth Defects Res Part A Clin Mol Teratol. 2005;73(6):409–20. doi: 10.1002/bdra.20127. PMID: 15880700.15880700
28 United Nations Environment Programme. The Lead Campaign. web.unep.org/transport/node/151/. Accessed Feburary 9, 2018.
29 Graber N, Gabinskaya T, Forman J, . Prenatal lead exposure in New York City immigrant communities [poster]. Pediatric Academic Societies (PAS) 2006 Annual Meeting. San Francisco; 2006.
30 American College of Obstetricians and Gynecologists. Lead screening during pregnancy and lactation. 2012. www.acog.org/Resources-And-Publications/Committee-Opinions/Committee-on-Obstetric-Practice/Lead-Screening-During-Pregnancy-and-Lactation. Accessed November 15, 2017.
31 Centers for Disease Control and Prevention. Lead poisoning from Mexican folk remedies-California. MMWR. 1983;32(42):554–5. PMID: 6415385.6415385
32 Centers for Disease Control and Prevention. Lead poisoning associated with imported candy and powdered food coloring-California and Michigan. MMWR. 1998;47(48):1041–3. PMID: 9869075.9869075
33 Wengrovitz AM, Brown MJ, Advisory Committee on Childhood Lead Poisoning DoE, . Recommendations for blood lead screening of Medicaid-eligible children aged 1-5 years: an updated approach to targeting a group at high risk. MMWR. 2009;58(RR-9):1–11. PMID: 19661858.19661858
34 American Academy of Pediatrics. Breastfeeding and the use of human milk. Pediatrics. 2012;129(3):e827–e41. doi: 10.1542/peds.2011-3552.22371471
35 Bradman A, Eskenazi B, Sutton P, . Iron deficiency associated with higher blood lead in children living in contaminated environments. Environ Health Perspect. 2001;109(10):1079–84. PMID: 11675273.11675273
36 Wright RO, Shannon MW, Wright RJ, . Association between iron deficiency and low-level lead poisoning in an urban primary care clinic. Am J Public Health. 1999;89(7):1049–53. PMID: 10394314.10394314
37 Kosnett MJ, Wedeen RP, Rothenberg SJ, . Recommendations for medical management of adult lead exposure. Environ Health Perspect. 2007;115(3):463–71. doi: 10.1289/ehp.9784. PMID: 17431500.17431500
38 Shannon M. Severe lead poisoning in pregnancy. Ambulatory Pediatrics. 2003;3(1):37–9. PMID: 12540252.12540252
39 Minnesota Department of Health. Blood Lead Screening Guidelines for Pregnant & Breastfeeding Women in Minnesota. St. Paul, MN: 2015. http://www.health.state.mn.us/divs/eh/lead/reports/pregnancy/pregnancyguidelines.pdf Accessed November 15, 2017.
40 New York City Department of Health and Mental Hygiene. Lead poisoning: Prevention, identification and management. City Health Information. 2010;29(5):41–8.
41 U. S. Preventive Services Task Force. Screening for elevated blood lead levels in children and pregnant women. Pediatrics. 2006;118(6):2514–8. doi: 10.1542/peds.2006-2352. PMID: 17142538.17142538
42 U.S. Preventive Services Task Force. Procedure Manual. 2017. www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed November 15, 2017.
43 Rischitelli G, Nygren P, Bougatsos C, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Screening for Elevated Lead Levels in Childhood and Pregnancy: Update of a 1996 U.S. Preventive Services Task Force Review Agency for Healthcare Research and Quality (US). Rockville (MD): 2006. PMID: 2072214120722141.
44 United Nations Development Programme. International Human Development Indicators. 2017. hdr.undp.org/en/countries. Accessed November 17, 2017.
45 Stefanak MA, Bourguet CC, Benzies-Styka T. Use of the Centers for Disease Control and Prevention childhood lead poisoning risk questionnaire to predict blood lead elevations in pregnant women. Obstet Gynecol. 1996;87(2):209–12. doi: 10.1016/0029-7844(95)00397-5. PMID: 8559525.8559525
46 Lanphear BP, Weitzman M, Eberly S. Racial differences in Urban children’s environmental exposures to lead. Am J Public Health. 1996;86(10):1460–3. PMID: 8876521.8876521