# Chapter 4 Discussion

## Summary of Review Findings

Evidence to determine the clinical benefits and harms of screening pregnant women for elevated BLLs versus not screening is extremely limited. No evidence directly evaluated the health benefits and harms of screening or the health outcomes or harms of interventions to treat elevated BLLs in pregnant women. Important gaps in the indirect chain of evidence include the lack of an accurate questionnaire to identify women at risk of elevated BLLs and the lack of interventions shown to be effective for reducing BLLs or improving clinical outcomes in women with elevated BLLs. Table 2 summarizes the evidence reviewed for this update.

One observational study of a questionnaire designed to evaluate lead exposure in children modified for use in pregnant women found poor diagnostic accuracy, with noninformative likelihood ratios.^45^ No studies of questionnaires specifically designed to assess lead exposure in pregnant women have been published. Accurate risk assessment instruments would facilitate improved targeted screening strategies.

Evidence on the effectiveness of nutritional interventions for pregnant women with elevated BLLs was limited to one fair-quality trial of calcium supplementation that showed a modest (~11%) reduction in BLLs versus placebo.^26^ There were no studies of chelation therapy or residential interventions in pregnant women. There were no available studies to address the remaining Key Questions or the Contextual Questions. At present, no studies address when to screen during pregnancy or effects of interventions for lowering elevated BLLs in pregnancy on clinical outcomes.

## Contextual Issues

Evidence on the intraindividual and interlaboratory reliability of BLL testing would be helpful for interpreting testing results, informing technical standards, and informing testing protocols and strategies. No risk prediction tools were identified that could be used in primary care practices to target screening of pregnant women living in communities at high risk for lead exposure.

## Generalizability

The findings from the two studies included in this report are not generalizable. The study of the CDC questionnaire originally developed to assess risk in children had poor diagnostic accuracy in a pregnant population.^45^ The single study of calcium supplementation to reduce BLLs was conducted in low- to moderate-income women in Mexico, with a high proportion of enrolled women regularly using lead-glazed ceramics for cooking meals (35%), and did not limit enrollment to women with asymptomatic elevated BLLs at baseline.^26^ It is unclear whether this intervention would have similar effectiveness in a U.S. population given potential differences in environments and nutrition. However, identifying culturally linked sources of lead exposure in U.S. pregnant populations could have an effect on risk.

## Limitations

The major limitation of this review was the overall lack of evidence to address all Key Questions. Other limitations of this review include restriction to English-language articles, which could result in language bias. However, we did not identify non–English-language studies in our searches that otherwise met inclusion criteria. Despite searching for updated data, the available studies may represent outdated risk factors and treatments that are not as relevant in U.S. primary care settings. We included nonrandomized studies to evaluate the effectiveness of interventions for elevated BLLs. Such studies are more susceptible to confounding and bias, as reflected in the quality ratings we assigned. We did not attempt meta-analysis, given the lack of studies, and were unable to formally assess for publication bias due to the small number of studies.

## Evidence for Priority Populations, Particularly Racial/Ethnic Minorities

Elevated BLLs primarily affect socioeconomically disadvantaged and minority populations. Different sources of lead exposure than have been previously considered are emerging in these populations, yet research in these groups remains limited.^31,32,46^ Exposures related to community water sources, lead plumbing in schools, and factory emissions affecting neighborhood soil quality are just some of the emerging factors that are not widely incorporated into current screening questionnaires. Additional research is warranted to validate these potential associations in specific geographic locations and among at-risk populations, as the effect of these exposures on blood lead concentration in pregnant women is not well established. Culturally linked sources of lead poisoning such as imported candy, pottery, and cosmetics, specific to subpopulations living in the United States, may also provide information about risk in minority populations. For example, traditional folk remedies and imported digestive remedies that may contain high levels of lead are not monitored by the U.S. Food and Drug Administration, and are more common in Hispanic and Asian populations.^31,32^ Nontraditional sources of lead exposure that come from items manufactured in other countries, such as leaded pots and pans, cosmetics, medicines, ceramics, and leaded crystal may also pose additional risk since little regulation exists to monitor, identify, and control these nonpaint exposures. Pregnant women who are exposed to these lesser recognized sources of lead exposure may also live in housing that has higher risk for lead exposure. The potential for multiple sources of risk associated with minority communities suggests the need for more focused strategies to address population-specific risks.

## Future Research

Elevated BLLs are associated with serious health consequences. Additional research is urgently needed to better inform decisions regarding screening in pregnant women, including evaluations of newer testing methods and techniques. Development of questionnaires that incorporate current risk factors for elevated BLLs with validation in contemporary populations of pregnant women in the United States is necessary. Ideally, randomized trials would recruit pregnant women from a range of racial/ethnic and socioeconomic strata, and evaluate the effects of screening on improving health outcomes as well as short- and long-term harms. These studies should address risk factors in pregnant women including occupational exposures, be tested in contemporary cohorts, and be validated in independent cohorts. An initial step would include conducting RCTs that evaluate effective interventions for lowering BLLs in pregnant women and that report intermediate and health outcomes, outcomes in newborns, and harms in both women and infants. Research on the intraindividual and interlaboratory reliability of BLL testing would be helpful for informing testing strategies.

## Conclusions

Evidence on the benefits and harms of screening pregnant women for elevated BLLs is extremely limited, with no evidence on effects of screening or interventions for lowering elevated BLLs in pregnant women on health outcomes.