# Chapter 3 Results

The search and selection of articles are summarized in the literature flow diagram. Two reviewers independently evaluated 3,147 unique citations and 233 full-text articles based on predefined criteria. Two studies met inclusion criteria for this review (N=984). There were no studies of screening in pregnant women and no studies reported health outcomes of interventions to reduce BLLs in asymptomatic pregnant women. One study reported the diagnostic accuracy of a clinical questionnaire for pregnant women^45^ and one study reported effects of a nutritional intervention during pregnancy.^26^ Appendix A3 shows the results of the literature search and selection process, Appendix A4 lists the included studies, and Appendix A5 lists the excluded full-text papers.

## Key Question 1a Is There Direct Evidence That Screening for Elevated BLLs in Asymptomatic Pregnant Women Improves Health Outcomes?

## Key Question 1b Does the Effectiveness of Screening in Asymptomatic Pregnant Women Vary by Gestational Age?

As in the prior USPSTF review, no studies directly evaluated clinical benefits and harms of screening pregnant women for elevated BLLs versus no screening, or how effectiveness of screening varies according to the gestational age at which screening is performed.

## Key Question 2 What Is the Accuracy of Questionnaires or Clinical Prediction Tools That Identify Pregnant Women Who Have Elevated BLLs?

### Summary

One fair-quality observational study^45^ included in the prior USPSTF review evaluated the accuracy of a questionnaire for identifying pregnant women with elevated BLLs using four questions from the five-question 1991 CDC questionnaire designed for identifying children at risk (N=314) (Appendixes B1 and C1). Women with a positive response to at least one of the four questions were more likely to have elevated BLLs than those who answered negatively to all four questions (RR, 2.39 [95% CI, 1.17 to 4.89]; P=0.01). However, diagnostic accuracy was poor, with a sensitivity of 75.7 percent and specificity of 46.2 percent. The most predictive single item was a “home built before 1960.”

### Evidence

The prior USPSTF review described one fair-quality cross-sectional study (n=314) of pregnant women in Ohio on the accuracy of the CDC lead questionnaire for screening children for risk of elevated BLLs that was carried forward to this update.^7^ No additional studies on the accuracy of instruments for identifying pregnant women with elevated BLLs were identified.

The CDC questionnaire is a five-item survey developed in 1991 that aims to assess residential, household, and personal risk factors for lead exposure in children. Specific items include the age of current housing and the condition of the paint; presence of household members and children with a BLL [underlined: of] 15 µg/dL or greater; exposure through [parental] work or hobbies; and a home in close proximity to lead industry.

The included study of pregnant women used four of the five items in the CDC questionnaire and eliminated an item on point source lead exposure from industries not relevant to this community. This study also included three additional questions.^45^ The questions were answered based on responses to a self-administered questionnaire of 19 items and a logistic model to identify the most predictive factors. The study enrolled low-income women attending public health clinics. The majority of participants were age 35 years or younger, and a third were adolescents. Ninety-four percent were Medicaid eligible, 66 percent were white, and 28 percent were black. Thirteen percent of the study population (39/314) had BLLs of 10 µ/dL or greater, with a mean BLL of 12.6 µg/dL.

Based on the threshold of at least one positive answer to one of four questions, 57 percent of the enrolled women qualified as at high risk for lead exposure and had a significantly increased risk for having an elevated BLL (defined as ≥10 µg/dL). The modified CDC questionnaire had a sensitivity of 75.7 percent and specificity of 46.2 percent. The positive likelihood ratio was 1.4 and the negative likelihood ratio was 0.52.

Using logistic regression, three specific questions were identified as predicting elevated BLLs more accurately: question 1 in the CDC set (home built before 1960 with peeling paint) and two questions added to the CDC questions (being a current smoker and consuming >10 servings of canned food per week). The sensitivity and specificity of these questions were 59.5 and 67.2 percent, respectively, for a house built before 1960; 56.8 and 63.0 percent, respectively, for being a current smoker; and 18.9 and 91.6 percent, respectively, for consuming more than 10 servings of canned food per week. Answering “yes” to any of these three questions resulted in a sensitivity of 75.7 percent and specificity of 41.2 percent. The positive likelihood ratio for this three-question set was 1.4 and the negative likelihood ratio was 0.26. The exact method for selecting these three questions was not clearly reported.

Limitations of this study include lack of clarity on how patients were selected, no comparison group, and answers to the evaluated questions (four CDC questions and an additional three questions) being derived from a separate 19-question set. It was not clear if the interpretation of the questionnaire results was done without knowledge of the BLLs. In addition, the derived three-item instrument was not tested in an independent cohort.

## Key Question 3 What Are the Harms of Screening for Elevated BLLs (With or Without Screening Questionnaires) in Asymptomatic Pregnant Women?

As in the prior report, no studies directly compared the harms of screening pregnant women for elevated BLLs in a screened population versus an unscreened population.

## Key Question 4 Do Counseling and Nutritional Interventions, Residential Lead Hazard Control Techniques, or Chelation Therapy Reduce BLLs and Rates of Gestational Hypertension in Asymptomatic Pregnant Women With Elevated BLLs?

### Summary

One new fair-quality RCT of healthy pregnant women in Mexico (N=670) with mean baseline BLLs of approximately 4 µg/dL found that calcium supplementation was associated with reduced BLLs versus placebo (difference, 11%; p=0.004; levels in each group not reported). Effects were more pronounced in women with baseline [underlined: BLLs of] 5 µg/dL or greater (Appendixes B2 and C2).

### Evidence

The prior USPSTF report did not include any studies on effects of interventions to lower BLLs in asymptomatic pregnant women.

One new fair-quality RCT (n=670) of healthy pregnant women at less than 14 weeks’ gestation attending Mexican Social Security Institute prenatal clinics compared a nightly dose of 1,200 mg of calcium until delivery versus placebo.^26^ Women were not required to have an elevated BLL at baseline (mean BLL, 3.8 vs. 4.1 µg/dL).

Calcium supplementation was associated with an 11-percent greater reduction in BLL than placebo (p=0.004; BLLs in each group not reported).^26^ The difference was largest during the second trimester (14% difference; p<0.01; third trimester difference, 8%; p=0.11). Stratifying the analysis according to baseline BLL showed greater effects of calcium supplementation in patients with elevated BLL at baseline. In women with a BLL [underlined: of] 5 µg/dL or greater at baseline, calcium supplementation was associated with a 17-percent greater reduction in BLL versus placebo, compared with a 7-percent greater reduction in women with BLLs less than 5 µg/dL at baseline.

Limitations of this study include unclear methods of allocation (e.g., enrollment of any healthy pregnant woman, and not identifying an asymptomatic group with elevated BLLs at baseline), lack of blinding of patients or outcome assessors, and small population differences at baseline, including dietary calcium intake.

Secondary analyses found a dose-response association between adherence with calcium supplementation and greater effects on blood lead concentration. Adherence of 50 percent or greater with calcium doses was associated with BLLs 15 percent lower than in the placebo group (p<0.001), taking more than 67 percent of calcium doses resulted in 19 percent lower levels (p<0.001), and taking more than 75 percent of calcium doses resulted in 24 percent lower levels (p<0.001). In women with an elevated BLL at baseline, the difference between calcium and placebo in BLL reduction among more adherent women was smaller (3%) and not statistically significant.

There were no studies of the effects of other interventions to reduce elevated BLLs in pregnant women.

## Key Question 5 Do Counseling and Nutritional Interventions, Residential Lead Hazard Control Techniques, or Chelation Therapy Improve Health Outcomes in Asymptomatic Pregnant Women With Elevated BLLs?

As in the prior USPSTF report, no studies reported health outcomes following interventions to reduce BLLs in asymptomatic pregnant women.

## Key Question 6 What Are the Harms of Interventions in Asymptomatic Pregnant Women With Elevated BLLs?

The prior USPSTF report found no studies on harms of interventions for lowering elevated BLLs in pregnant women. A subsequent RCT on effects of calcium supplementation on BLLs in pregnant women did not report harms (see Key Question 4).^26^

## Contextual Questions

No studies were identified on the reliability of venous blood lead testing at various lead levels in pregnant women, the association between reduced BLLs and improved health outcomes in asymptomatic pregnant women with elevated blood lead concentrations, or accuracy of risk prediction tools in identifying communities at highest risk for lead exposure during pregnancy.