# Chapter 2 Methods

## Key Questions and Analytic Framework

This systematic review followed a standard protocol consistent with USPSTF procedures.^42^ The scope and Key Questions for this report were developed by Evidence-based Practice Center investigators in collaboration with the USPSTF and the Agency for Healthcare Research and Quality, and informed by evidence gaps identified from the prior review.^43^ In addition, three Contextual Questions were requested by the USPSTF. Contextual Questions address topics important to the USPSTF recommendations, but are reviewed by summarizing evidence from key informative studies rather than by using systematic review methodology. Key Questions and Contextual Questions are listed below. Investigators created an analytic framework incorporating the Key Questions and outlining the patient populations, interventions, outcomes, and potential adverse effects (Figure 1). A research plan was externally reviewed and modified prior to finalization.

Figure 1 Analytic Framework and Key Questions

Abbreviation: KQ=key question.

^a^ Interventions include counseling families to reduce lead exposure, nutritional interventions, residential hazard control techniques, and chelation therapy.

^b^ Included outcomes measured in family members (e.g., siblings, pregnant women in the same household) subsequently identified as having elevated blood lead levels after the index family member was found to have an elevated blood lead level during screening.

Figure 1 is an analytic framework that depicts the populations, interventions, outcomes, and harms of interest for screening for elevated blood lead levels in pregnant women. The far left of the framework describes the target population for screening: asymptomatic pregnant women. To the right is screening. Below the screening is an oval for harms of screening. An arrow leads from screening to a box containing health outcomes of reduced cognitive problems in offspring, reduced adverse perinatal outcomes, and reduced adverse maternal outcomes. To the right of screening is a box for elevated blood lead level. An arrow leads from asymptomatic pregnant women to elevated blood lead level. To the right of elevated blood lead is intervention, which has an oval below it for harms of intervention. An arrow leads directly from intervention to the final health outcomes of reduced cognitive problems in offspring, reduced adverse perinatal outcomes, and reduced adverse maternal outcomes. To the right of intervention is a box for the intermediate outcomes of reduced blood lead level and reduced gestational hypertension. The intermediate outcomes have a dotted line leading to the health outcomes of reduced cognitive problems in offspring, reduced adverse perinatal outcomes, and reduced adverse maternal outcomes.

### Key Questions

1a Is there direct evidence that screening for elevated BLLs in asymptomatic pregnant women improves health outcomes (e.g., reduced cognitive problems in offspring, adverse perinatal outcomes, and adverse maternal outcomes)?
1b Does the effectiveness of screening in asymptomatic pregnant women vary by gestational age?
2 What is the accuracy of questionnaires or clinical prediction tools that identify pregnant women who have elevated BLLs?
3 What are the harms of screening for elevated BLLs (with or without screening questionnaires) in asymptomatic pregnant women?
4 Do counseling and nutritional interventions, residential lead hazard control techniques, or chelation therapy reduce BLLs and rates of gestational hypertension in asymptomatic pregnant women with elevated BLLs?
5 Do counseling and nutritional interventions, residential lead hazard control techniques, or chelation therapy improve health outcomes in asymptomatic pregnant women with elevated BLLs?
6 What are the harms of interventions in asymptomatic pregnant women with elevated BLLs?

### Contextual Questions

1. What is the reliability of venous blood lead testing at various lead levels in pregnant women?
2. What is the association between reduced BLLs and improved health outcomes in asymptomatic pregnant women with elevated BLLs?
3. Are there valid risk prediction tools available that identify communities at highest risk for lead exposure that could be used in primary care practices to target screening efforts in pregnant women?

Key Question 1a focused on direct evidence of the effectiveness of screening for elevated BLLs for improving future health outcomes (e.g., reduced cognitive problems in offspring, reduced adverse perinatal outcomes, and reduced adverse maternal outcomes) compared with not screening. Key Question 1b evaluated the effectiveness of screening by gestational age. Because such direct evidence may be limited, the remainder of the analytic framework (Key Questions 2 through 6) evaluates the chain of indirect evidence needed to link screening with improved health outcomes. Links in the chain of indirect evidence include the accuracy of screening for identifying pregnant women with elevated BLLs, the effectiveness of interventions for treating identified elevated BLLs and reducing the incidence of complications, the association between improvements in intermediate outcomes and clinical health outcomes, and harms (including infant harms) associated with screening and treatments. Implicit in the indirect chain of evidence is that, to understand benefits and harms of screening, it is necessary but not sufficient to show that pregnant women with elevated BLLs can be identified. It is also necessary to show that there are effective treatments for women identified with elevated BLLs.

A separate report covers screening for elevated BLLs in children.

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials (through March 2017), Cochrane Database of Systematic Reviews (through April 2017), and Ovid MEDLINE (1946 through March 2017) for relevant studies. Search strategies are available in Appendix A1. Searches were supplemented by review of studies included in the prior USPSTF review and by review of reference lists of other relevant studies. Searches were updated through June 2018. Ongoing surveillance was conducted through article alerts and targeted searches of high-impact journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence. The last surveillance was conducted on December 5, 2018.

## Study Selection

Two reviewers independently evaluated each study to determine eligibility for inclusion based on predetermined inclusion and exclusion criteria developed for each Key Question (Appendix A2).

Populations of asymptomatic pregnant women were included, regardless of risk for elevated BLLs. Studies of screening questionnaires were included for Key Question 2. Comparisons were screening versus no screening (Key Questions 1 and 3); a questionnaire versus a reference standard for elevated BLL (i.e., venous BLL) (Key Question 2); and treatment versus placebo, no treatment, or usual care (Key Questions 4 through 6). Key Question 4 evaluated effects of interventions for elevated BLLs on intermediate outcomes (i.e., BLLs). Clinical outcomes were gestational hypertension, cognitive outcomes in offspring, and perinatal and maternal outcomes. Other outcomes were statistical markers of diagnostic accuracy, harms of testing (e.g., anxiety, distress, pain, or discomfort related to testing), and morbidity attributed to treatment (e.g., renal toxicity, sensitivity reactions). Inclusion was restricted to English-language articles, and studies only published as abstracts were excluded. Studies of nonhuman subjects were also excluded, and studies had to report original data. Studies conducted in countries with a “very high” Human Development Index^39^ (i.e., considered applicable to U.S. populations and practice) were included; studies from countries with a “high” Human Development Index were included if no other studies were available. For Key Questions 4 through 6 (treatments for elevated BLLs), studies of asymptomatic pregnant women conducted in any country that evaluated interventions that focused on the individual or family (e.g., counseling, nutritional interventions, residential hazard control techniques, and chelation therapy) were included; studies of policies, laws, or community-based interventions focused on the primary prevention of lead exposure were excluded. Study designs were randomized, controlled trials (RCTs) of screening and treatments; controlled clinical trials on effects of therapies on health outcomes; controlled clinical trials and prospective cohort studies on harms of therapies; and studies on diagnostic accuracy of screening questionnaires or capillary sampling. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists included studies and Appendix A5 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

One investigator abstracted details about the study design, patient population, setting, screening method, interventions, analysis, followup, and results. A second investigator reviewed data abstraction for accuracy. For studies that did not report measures of diagnostic accuracy but provided the necessary data, we calculated RRs, likelihood ratios, positive and negative predictive values, and 95 percent CI or p-values. Two investigators independently applied criteria developed by the USPSTF^42^ to rate the quality of each study as good, fair, or poor (Appendix A6) and resolved discrepancies by consensus.

## Data Synthesis

Two independent reviewers assessed the internal validity (quality) of the body of evidence for each Key Question (“good,” “fair,” or “poor”) using methods developed by the USPSTF, based on the number, quality and size of studies, consistency of results between studies, and directness of evidence (Table 2).^42^ Due to the limited nature of the evidence, meta-analyses were not possible and we discuss the evidence qualitatively.

Table 2 Summary of Evidence

Key Question^*^ | Main Findings From Prior USPSTF Reviews | Number and Type of Studies Identified for Update | Limitations | Consistency | Applicability | Summary of Findings | Overall Quality^†^
1a, 1b | No studies | 0 | No studies | No studies | No studies | No studies | No studies
2 | No studies | 1 observational study | Questionnaire not designed specifically for pregnant women; used a higher BLL threshold than the CDC threshold of <5 µg/dL. No intention-to-treat analysis. Larger set of investigator-designed questions not reported. | Not applicable | One study conducted in a single setting in Ohio from 1990 to 1992. | One study used 4/5 questions from the CDC questionnaire for children and showed that women with a positive response to at least 1 of the 4 questions were more likely to have elevated BLLs than those who answered negatively to all 4 questions (RR, 2.39 [95% CI, 1.17 to 4.89]; p=0.01). The CDC questionnaire had a sensitivity of 75.7% and a sensitivity of 46.2%. The most predictive single item was “home built before 1960.” | Fair
3 | No studies | 0 | No studies | No studies | No studies | No studies | No studies
4 | No studies | 1 RCT | Enrolled any healthy pregnant woman; did not identify an asymptomatic group with elevated BLL at baseline. Limited subgroup analyses of women with elevated BLLs were available; some findings conflict with overall study results. | Not applicable | One study conducted in Mexico city; high proportion of participants regularly using lead-glazed ceramics for cooking meals (35%). | One RCT of healthy pregnant women (mean baseline BLL, ~4 µg/dL) in Mexico found that calcium supplementation was associated with reduced BLLs vs. placebo (difference, 11%; p=0.004; levels in each group not reported). In women with baseline BLL ≥5 µg/dL, calcium supplementation was associated with a 17% greater reduction in BLL vs. placebo, compared with a 7% greater reduction in those with lead levels <5 µg/dL at baseline. | Fair
5 | No studies | 0 | No studies | No studies | No studies | No studies | No studies
6 | No studies | 0 | No studies | No studies | No studies | No studies | No studies

* Key Question 1a. Is there direct evidence that screening for elevated BLLs in asymptomatic pregnant women improves health outcomes?

Key Question 1b. Does the effectiveness of screening in asymptomatic pregnant women vary by gestational age?

Key Question 2. What is the accuracy of questionnaires or clinical prediction tools that identify pregnant women who have elevated BLLs?

Key Question 3. What are the harms of screening for elevated BLLs in asymptomatic pregnant women?

Key Question 4. Do counseling and nutritional interventions, residential lead hazard control techniques, or chelation therapy reduce BLLs and rates of gestational hypertension in asymptomatic pregnant women with elevated BLLs?

Key Question 5. Do counseling and nutritional interventions, residential lead hazard control techniques, or chelation therapy improve health outcomes in asymptomatic pregnant women with elevated BLLs?

Key Question 6. What are the harms of interventions in asymptomatic pregnant women with elevated BLLs?

† “Overall quality” is based on new evidence identified for this update.

Abbreviations: BLL=blood lead level; CDC=Centers for Disease Control; RCT=randomized, controlled trial; RR=relative risk; U.S.=United States; USPSTF=U.S. Preventive Services Task Force.

## External Review

The draft report was reviewed by content experts (Appendix A7), USPSTF members, Agency for Healthcare Research and Quality Project Officers, and collaborative partners, and has been posted for public comment; it has been revised accordingly.

## Response to Public Comment

A draft version of the evidence report was posted for public comment on the USPSTF Web site from October 30, 2018 to December 3, 2018. No changes to the report were made in response to public comments.