# Chapter 1 Introduction and Background

## Purpose

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2006 recommendation on screening for elevated blood lead levels (BLLs) in pregnancy. This update focuses on studies published since the prior USPSTF systematic review^1^ of this topic and may include studies also included in the prior review.

In 2006, the USPSTF recommended against routine screening for elevated BLLs in asymptomatic pregnant women (D recommendation). The USPSTF found no studies that examined the effectiveness or harms of screening or interventions among pregnant women but did discuss a variety of potential harms similar to those among children. Given the low prevalence of elevated BLLs in asymptomatic pregnant women, the small amount of potential benefit was not thought to outweigh the potential harms of screening and intervention in this group.

## Condition Background

### Condition Definition

Elevated BLL is defined as greater than 5 µg/dL, according to the Centers for Disease Control and Prevention (CDC).^2^ Although no safe level of lead exposure exists, this is the level at which further clinical monitoring or treatment is recommended for pregnant women.^2^ This reference range value was based on the 98th percentile of the National Health and Nutrition Examination Survey (NHANES) blood lead distribution in women of childbearing age.^3^

### Prevalence and Burden of Disease/Illness

Lead causes a number of adverse health effects, primarily affecting the central nervous, hematopoietic, hepatic, and renal systems.^4^ Manifestations are variable, but there is a general correlation between higher BLLs and the presence of symptoms. Acute toxicity resulting from intense lead exposure over a short duration is very uncommon and primarily associated with occupational exposure.^4^ Clinical symptoms of acute lead exposure include muscle pain, fatigue, abdominal pain, headache, vomiting, seizures, and coma.^4^ Adults with lower level, chronic, or recurrent exposures may be asymptomatic or present with vague nonspecific symptoms (e.g., myalgia, fatigue, difficulty concentrating, and insomnia).^4^

Many potential health effects of lead exposure are irreversible. Compared with other organ systems, the nervous system is the most sensitive and chief target for lead-induced toxicity.^4^ More severe manifestations occur at very high exposures and include delirium, lack of coordination, convulsions, paralysis, coma, and ataxia. Lead exposure can lead to anemia by directly affecting the synthesis of hemoglobin (by inhibiting various key enzymes involved in the heme synthesis pathway) and by reducing the life span of circulating erythrocytes by increasing the fragility of cell membranes.^5^

Pregnant women exposed to lead are at an increased risk of adverse perinatal outcomes as well as nonpregnancy-related morbidity. Among adults in general, analyses of NHANES data (1988 to 1994) indicate that BLLs greater than 10 µg/dL are associated with an increased risk of death from all causes (relative risk [RR], 1.59 [95% confidence interval (CI), 1.28 to 1.98]), cardiovascular disease (RR, 1.55 [95% CI, 1.16 to 2.07]), and cancer (RR, 1.69 [95% CI, 1.14 to 2.52]).^6^ Exposure in adults can additionally lead to increased blood pressure and the incidence of hypertension, reproductive problems, and decreased kidney function.^7^ The International Agency for Research on Cancer lists lead as a probable carcinogen, and the U.S. Report on Carcinogens also lists lead and lead compounds as “reasonably anticipated to be a human carcinogen.”^8,9^ Lead exposure during pregnancy can result in spontaneous abortion,^3^ reduced fetal growth, premature birth, and cognitive deficiencies in the child.^3^ As with young children, lead exposure during the critical initial neurological development of a fetus may be particularly harmful.^10^ Pregnant women and nursing mothers with high BLLs may experience elevations in both systolic and diastolic blood pressure.^11^

Public health efforts to reduce exposure to lead in the United States (e.g., removal of lead from household paints and gasoline) are considered major successes. Although it is difficult to measure changes in morbidity attributable to lead exposure, the prevalence of elevated BLLs in adults has declined significantly over the past few decades.

Based on NHANES data, the percentage of adults with BLLs of 10 μg/dL or greater declined from 3.3 percent in 1988 to 1994 to 0.7 percent in 1999 to 2002 (p<0.001).^12^ In 1999 to 2002, the multivariable-adjusted odds ratio of having a BLL of 10 μg/dL or greater was 2.91 (95% CI, 1.74 to 4.84) and 3.26 (95% CI, 1.83 to 5.81) for non-Hispanic black and Mexican American adults, respectively, compared with non-Hispanic white adults.^13^ Among women of childbearing age, an estimated 1 percent have BLLs greater than 5 μg/dL.^3^ In one analysis of pregnant women, the age-adjusted prevalence of elevated BLLs was less than 0.5 percent.^14^

### Etiology and Natural History

Lead is a heavy metal that occurs naturally in the environment. Unique properties of lead (e.g., high malleability, low melting point, and resistance to corrosion) resulted in its widespread use in various industries. Lead has become widely distributed and mobilized in the environment, resulting in increasing human exposure and uptake over time.^15^

Common sources of lead exposure include lead-based paint, contaminated soil (e.g., by exterior lead-based paint or gasoline), lead-contaminated water (e.g., by lead plumbing), and dust contaminated by chipping or chalking of lead-based paint and tracked-in soil.^15^ In the United States, leaded gasoline began to be phased out in 1973 and was banned by 1996. From 1980 to 2014, exposure to lead fumes from leaded gasoline decreased by 98 percent.^16^ Lead-based paints were banned for use in housing in 1978. All houses built before 1978 are likely to contain some lead-based paint that ultimately deteriorates and causes a problem.^15^ Although lead was restricted in plumbing material in 1986, older homes and neighborhoods may still contain lead service lines, lead connections, or other lead-based plumbing materials.^17^ The release of lead from lead-based plumbing materials into drinking water is variable and influenced by factors such as water softness, temperature, and acidity.^18^ Flint, Michigan provides an example of increased lead contamination of drinking water related to changes in water sources and treatment, including the use of disinfectants.^19^

Like young children, adults may be exposed to lead-based paints and other household exposures. Adults may also be at risk of occupational lead exposure, exposure via hobbies (e.g., lead-glazed pottery), and ingestion of some lead-containing complementary and alternative treatments (e.g., Ayurvedic herbal medicine products). One survey of reproductive-age women in New York with elevated BLLs (10 to 25 µg/dL) found that 46 percent of exposures were occupational, 24 percent were due to home renovations, and 30 percent were unknown.^20^ Among women with occupational exposures to lead fumes or dust, the most common occupational exposures were precision production (e.g., work involving soldering or the production of lead-containing materials); craft and repair operations; and among operators, fabricators, and laborers. Specific recommendations exist for medical surveillance of pregnant women with occupational exposure to lead.^21^

Once exposed to lead, nutritional factors in both children and adults are known to affect lead absorption and toxicity. Iron- or calcium-deficient diets may lead to more efficient absorption of lead in children and adults.^22^ Interactions between micronutrients and exposure to lead are also important in pregnancy. Studies suggest that maternal calcium consumption may affect bone resorption based on the toxicokinetics of lead during different stages of pregnancy.^23^ During pregnancy, increased mobilization of lead may occur from bone stores that provide for fetal developmental needs.^24^ Once absorbed, lead is then distributed to the blood, soft tissues, and bone. In blood, 99 percent of lead is bound to the erythrocyte, and the remaining 1 percent is free in the plasma to exchange with soft tissues (kidney, brain, liver, and bone marrow). More than 90 percent of lead in the body is stored in bone, and this might be mobilized in periods of high turnover such as pregnancy and lactation.^3^

During pregnancy, BLLs have been found to follow a U-shaped curve with a nadir between 12 and 20 weeks. The rate at which BLLs rise in late pregnancy varies by age (higher among older women) and is associated with calcium intake (lower in women taking calcium supplements).^24–26^ After delivery, breastfeeding women experience a rise in lead levels that is attributed to increased lead absorption and increased lead mobilization from deeper storage (i.e., bone).^27^

### Risk Factors

Risk factors for lead exposure include socioeconomic disadvantage; living in an area with lead industry; renovation or deterioration of older lead-painted houses; and previously living in a developing country where leaded gasoline is still used.^15,28^ Socioeconomic factors associated with lead exposure include lower family income, older age of housing, and poorer nutritional status.

In a New York study of low-income pregnant women, foreign-born women were 8 times more likely to have elevated BLLs compared with women born in the United States.^29^ The American College of Obstetricians and Gynecologists (ACOG) and the CDC also list the following as risk factors for lead exposure in pregnant women: living near a point source of lead; working with lead or living with someone who does; using lead-glazed ceramic pottery; eating nonfood substances (e.g., pica); using complementary and alternative therapies; using imported cosmetics; engaging in high-risk hobbies; renovating old homes without lead hazards in place; consuming lead-contaminated drinking water; having a previous history of lead exposure; and living with someone diagnosed with an elevated BLL.^3,30^

Specific risk factors may vary in different communities. For example, exposures that occur through local water sources, lead pipes, and culturally-linked sources such as folk remedies, imported food and candy, and traditional pottery used for cooking^31,32^ may influence lead exposure on the local level. The CDC recommends that state or local health departments provide information to clinicians on community-specific risk factors that can be used to determine the need for screening in pregnant women.^3^ The CDC also recommends developing validated questionnaires at the community level since risk factors may vary significantly between communities.

### Rationale for Screening/Screening Strategies

Current clinical guidelines and policies emphasize primary prevention of lead exposure. The rationale for screening pregnant women is to identify and reduce sources of lead exposure to reduce the risk of pregnancy complications and decrease the risk of lead exposure to the developing fetus and infant. Potential benefits for the pregnant women includes reduction of perinatal complications and prevention of general complications associated with adult lead exposure. As the prevalence of elevated BLLs has declined, there has been a shift from universal to targeted screening that incorporates primary prevention education.^33^ Although several questionnaires have been developed to identify children at higher risk of lead exposure, none have been developed specifically for pregnant women. Venous blood sampling is the recommended screening strategy for pregnant women when lead exposure is suspected.^3,30^

### Interventions/Treatment

The management of elevated BLLs in pregnant women varies depending on the confirmed BLL and other factors. Types of interventions include education and environmental strategies, nutritional interventions, and chelation therapy. Identifying the source of lead exposure is key to preventing ongoing or repeated exposure and remains the mainstay of treatment for lead exposure.

#### Educational and Environmental Interventions

Educational interventions address awareness of lead exposure pathways, hygiene, and household dust control measures to prevent ingestion of dust and soil. Environmental and household interventions include specialized cleaning, repairs, maintenance, soil abatement (e.g., removal and replacement), painting, and temporary containment of lead hazards. For pregnant women, additional education includes advice on strategies to decrease exposure to children who are breastfeeding. The CDC suggests that breastfeeding be discouraged in women with BLLs of 40 µg/dL or greater; however, a 2012 policy statement from the American Academy of Pediatrics on breastfeeding does not include a recommendation to discourage breastfeeding for women with BLLs of 40 µg/dL or greater.^30,34^ Current guidelines state that women with levels of 5 to 39 µg/dL may breastfeed, but infant BLLs should be measured, and breastfeeding should be discontinued if infant BLLs rise above 5 µg/dL.

#### Nutritional Interventions

The role of nutritional supplementation in reducing BLLs among pregnant women with elevated BLLs is unclear. Calcium, dietary iron, and other supplements are thought to decrease the intestinal absorption of lead. For lead, this theory is supported by epidemiologic studies that demonstrate an increased prevalence of iron deficiency among children with lead poisoning.^35,36^ However, the association is inconsistent and evidence in iron-replete children is lacking. Nonetheless, calcium and vitamin C supplementation is often recommended for women with elevated BLLs.^30^

#### Chelation Therapy

In adults, chelation therapy may more rapidly decrease BLLs and relieve acute lead symptoms. Initiation of chelation is recommended for individuals with BLLs greater than 100 µg/dL and should also be considered for levels between 80 and 100 µg/dL in asymptomatic individuals and for symptomatic patients with BLLs between 50 and 80 µg/dL.^37^ 2,3-dimercaptosuccinic acid (DMSA), succimer, and calcium disodium ethylenediaminetetraacetate (CaEDTA) are commonly used chelating agents. Because treatment with CaEDTA is associated with significant adverse effects, it must be administered in a hospital setting. The risks and benefits of chelation therapy have not been fully characterized among pregnant women. There are eight case reports of successful use of chelation therapy in pregnant women, all of whom had a BLL greater than 45 µg/dL.^38^ The CDC recommends considering the use of chelation therapy when BLLs are greater than 45 µg/dL.^3^ CaEDTA is considered pregnancy category B and DMSA is considered category C. Pregnant women undergoing chelation therapy should be managed by a clinician who is experienced with lead intoxication during pregnancy.

### Current Clinical Practice/Recommendations of Other Groups

#### Current Clinical Practice

There are no available data regarding the prevalence of health care providers who screen pregnant women for elevated BLLs. The states of Minnesota^39^ and New York^40^ recommend routine risk factor assessment for lead exposure, as do ACOG and the CDC.^3,30^ The CDC recommends targeted screening for elevated BLLs through venous blood sampling based on risk factors for lead exposure in individual communities.

The accuracy of screening questionnaires for predicting elevated BLLs in pregnant women is uncertain. No validated questionnaire exists for identifying pregnant women at high risk of lead exposure. The state of Minnesota^39^ provides a 10-question risk assessment tool, and the state of New York provides a five-question risk assessment tool.^3^ In both screening programs, BLL testing is recommended if a woman answers yes to one or more questions. However, neither of these tools has been validated in pregnant populations. Venous blood sampling is the recommended screening method for maternal blood lead testing.^3,30^

#### Recommendations of Other Groups

Table 1 summarizes current screening recommendations from other groups. At the time of the previous USPSTF recommendation,^41^ no other organizations had issued guidance about screening pregnant women for elevated BLLs. Since 2006, both the CDC and ACOG published recommendations stating that all pregnant women with risk factors for lead exposure should be screened for elevated BLLs using venous blood sampling and managed appropriately.^3,30^

Table 1 Current Recommendations From Other Organizations Screening

Organization, Year | Screening Recommendation for Pregnant Women
American Academy of Family Physicians (AAFP), 2006 | The AAFP recommends against routine screening for elevated blood lead levels in asymptomatic pregnant women.
Centers for Disease Control and Prevention (CDC), 2010 | Universal screening is not recommended. Blood lead testing is recommended for pregnant and lactating women with one or more important risk factors for lead exposure and increased blood lead levels:; - Recent immigration (from an area where ambient lead contamination is high); - Living near point source of lead (e.g., lead mines, smelters, battery recycling plants, home remodeling); - Pica (i.e., compulsive eating of nonfood items); - Occupational exposures (e.g., painters, women exposed to batteries or radiators, women living with someone who works in lead industry); - Environmental exposures (e.g., lead-contaminated soil, water, or food); - Use of lead-containing cosmetics; - Cooking/storing in lead-glazed pottery; - Use of herbal/alternative medicines (e.g., some Chinese herbs, Ayurvedic medicines)
American College of Obstetricians and Gynecologists (ACOG), 2012 | Blood lead testing of all pregnant women in the United States is not recommended. Obstetric health care providers should consider the possibility of lead exposure in individual pregnant women by evaluating risk factors for exposure as part of a comprehensive health risk assessment and perform blood lead testing if a single risk factor is identified. Assessment of lead exposure should take place at the earliest contact with the pregnant patient. The ACOG guidelines refer to CDC recommendations regarding risk factors for exposure.

Abbreviations: AAFP=American Academy of Family Physicians; ACOG=American College of Obstetrics and Gynecologists; CDC=Centers for Disease Control and Prevention.