# Appendix C Quality Assessment

## Appendix C1 Quality Assessment of Pregnancy Diagnostic Accuracy Study

Author, year | Was a consecutive or random sample of patients enrolled? | Was a case-control design avoided? | Did the study avoid inappropriate exclusions? | Were the index test results interpreted without knowledge of the results of the reference standard? | If a threshold was used, was it prespecified? | Is the reference standard likely to correctly classify the target condition? | Were the reference standard results interpreted without knowledge of the results of the index text? | Was there an appropriate interval between index test(s) and reference standard? | Did all patients receive a reference standard? | Did patients receive the same reference standard? | Were all patients included in the analysis? | Quality rating
Stefanak, 1996^45^ | Unclear | Yes | Yes | Unclear | Yes | Yes, but not the current | Unclear | Yes | Yes | Yes | No (299/314) | Fair

## Appendix C2 Quality Assessment of Pregnancy Trial

Author, year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Attrition and with-drawals reported? | Loss to followup differential/high? | Analyze people in the groups in which they were randomized? | Quality rating
Ettinger, 2009^26^ | Unclear | Unclear | Yes; except age | Yes | Unclear | Unclear; but described as double blind | Yes | Yes | No | Yes | Fair