# Appendix B Evidence Tables

Appendix B1 Data Abstraction of Pregnancy Diagnostic Accuracy Study

Appendix B2 Data Abstraction of Pregnancy Trials