# References

1 Rischitelli G, Nygren P, Bougatsos C, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Screening for Elevated Lead Levels in Childhood and Pregnancy: Update of a 1996 U.S. Preventive Services Task Force Review Agency for Healthcare Research and Quality (US). Rockville (MD): 2006. PMID: 2072214120722141.
2 Centers for Disease Control and Prevention. Standard surveillance definitions and classifications. 2013. http://www.cdc.gov/nceh/lead/data/definitions.htm.
3 Centers for Disease Control and Prevention, Roper WL, Houk VN, . Preventing lead poisoning in young children: A statement by the Centers for Disease Control, October 1991 Centers for Disease Control and Prevention. Atlanta, GA (United States): 1991.
4 Advisory Committee on Childhood Lead Poisoning Prevention. Low level lead exposure harms children: A renewed call for primary prevention. 2012. www.cdc.gov/nceh/lead/acclpp/final_document_030712.pdf. Accessed November 15, 2017.
5 Flora G, Gupta D, Tiwari A. Toxicity of lead: a review with recent updates. Interdiscip Toxicol. 2012;5(2):47–58. doi: 10.2478/v10102-012-0009-2. PMID: 23118587.23118587
6 Guidotti TL, Ragain L. Protecting children from toxic exposure: three strategies. Pediatr Clin North Am. 2007;54(2):227–35, vii. doi: 10.1016/j.pcl.2007.02.002. PMID: 17448358.17448358
7 Tchounwou PB, Yedjou CG, Patlolla AK, . Heavy metal toxicity and the environment. EXS. 2012;101:133–64. doi: 10.1007/978-3-7643-8340-4_6. PMID: 22945569.22945569
8 Agency for Toxic Substances and Disease Registry. ToxGuide^TM^ for lead Pb U.S. Department of Health and Human Services Public Health Service Agency for Toxic Substances and Disease Registry. Atlanta, GA: 2007.
9 Needleman H. Lead poisoning. Annu Rev Med. 2004;55:209–22. doi: 10.1146/annurev.med.55.091902.103653. PMID: 14746518.14746518
10 White RF, Diamond R, Proctor S, . Residual cognitive deficits 50 years after lead poisoning during childhood. Br J Ind Med. 1993;50(7):613–22. PMID: 8343422.8343422
11 Hu H. A 50-year follow-up of childhood plumbism. Hypertension, renal function, and hemoglobin levels among survivors. Am J Dis Child. 1991;145(6):681–7. PMID: 2035497.2035497
12 Hu H. Knowledge of diagnosis and reproductive history among survivors of childhood plumbism. Am J Public Health. 1991;81(8):1070–2. PMID: 1854006.1854006
13 Raymond J, Wheeler W, Brown MJ, . Lead screening and prevalence of blood lead levels in children aged 1-2 years-Child Blood Lead Surveillance System, United States, 2002-2010 and National Health and Nutrition Examination Survey, United States, 1999-2010. MMWR Suppl. 2014;63(2):36–42. PMID: 25208256.25208256
14 Tong S, von Schirnding YE, Prapamontol T. Environmental lead exposure: a public health problem of global dimensions. Bull World Health Organ. 2000;78(9):1068–77. PMID: 11019456.11019456
15 United States Environmental Protection Agency. Lead in Outdoor Air. 2016. www.epa.gov/lead/lead-outdoor-air. Accessed November 21, 2017.
16 Rabin R. The lead industry and lead water pipes “A Modest Campaign”. Am J Public Health. 2008;98(9):1584–92. doi: 10.2105/ajph.2007.113555. PMID: 18633098.18633098
17 Raab GM, Laxen DP, Anderson N, . The influence of pH and household plumbing on water lead concentration. Environ Geochem Health. 1993;15(4):191–200. doi: 10.1007/bf00146742. PMID: 24198138.24198138
18 Hanna-Attisha M, LaChance J, Sadler RC, . Elevated blood lead levels in children associated with the Flint drinking water crisis: a spatial analysis of risk and public health response. Am J Public Health. 2016;106(2):283–90. doi: 10.2105/AJPH.2015.303003. PMID: 26691115.26691115
19 Lanphear BP, Matte TD, Rogers J, . The contribution of lead-contaminated house dust and residential soil to children’s blood lead levels. A pooled analysis of 12 epidemiologic studies. Environ Res. 1998;79(1):51–68. doi: 10.1006/enrs.1998.3859. PMID: 9756680.9756680
20 Triantafyllidou S, Gallagher D, Edwards M. Assessing risk with increasingly stringent public health goals: the case of water lead and blood lead in children. J Water Health. 2014;12(1):57–68. doi: 10.2166/wh.2013.067. PMID: 24642433.24642433
21 American College of Obstetricians and Gynecologists. Lead screening during pregnancy and lactation. 2012. www.acog.org/Resources-And-Publications/Committee-Opinions/Committee-on-Obstetric-Practice/Lead-Screening-During-Pregnancy-and-Lactation. Accessed November 15, 2017.
22 Goyer RA. Nutrition and metal toxicity. Am J Clin Nutr. 1995;61:(3 Suppl):646s–50s. PMID: 7879732.7879732
23 Centers for Disease Control and Prevention. Guidelines for the identification and management of lead exposure in pregnant and lactating women. U.S. Department of Health and Human Services. Atlanta, GA; 2010. www.cdc.gov/nceh/lead/publications/leadandpregnancy2010.pdf. Accessed November 15, 2017.
24 Wengrovitz AM, Brown MJ, Advisory Committee on Childhood Lead Poisoning DoE, . Recommendations for blood lead screening of Medicaid-eligible children aged 1-5 years: an updated approach to targeting a group at high risk. MMWR Recomm Rep. 2009;58(RR-9):1–11. PMID: 19661858.19661858
25 Centers for Disease Control and Prevention. Screening young children for lead poisoning: guidance for state and local public health officials. Screening young children for lead poisoning: guidance for state and local public health officials. 1997:400.
26 Graber N, Gabinskaya T, Forman J, . Prenatal lead exposure in New York City immigrant communities [poster]. Pediatric Academic Societies (PAS) 2006 Annual Meeting. San Francisco; 2006.
27 Parsons PJ, Raciti K, Esernio-Jenssen D. Evaluation and improvement of sample collection procedures for the determination of blood lead Center for Disease Control and Prevention. Atlanta: Centers for Disease Control and Prevention: 1993.
28 Centers for Disease control and Prevention. Managing elevated blood lead levels among young children: Recommendations from the Advisory Committee on Childhood Lead Poisoning Prevention. 2002. www.cdc.gov/nceh/lead/CaseManagement/caseManage_main.htm. Accessed December 11, 2017.
29 Bradman A, Eskenazi B, Sutton P, . Iron deficiency associated with higher blood lead in children living in contaminated environments. Environ Health Perspect. 2001;109(10):1079–84. PMID: 11675273.11675273
30 Wright RO, Shannon MW, Wright RJ, . Association between iron deficiency and low-level lead poisoning in an urban primary care clinic. Am J Public Health. 1999;89(7):1049–53. PMID: 10394314.10394314
31 Nightingale SL. From the Food and Drug Administration. JAMA. 1991;265(14):1802. PMID: 1848642.1848642
32 Mann KV, Travers JD. Succimer, an oral lead chelator. Clin Pharm. 1991;10(12):914–22. PMID: 1663439.1663439
33 Campbell JR, Schaffer SJ, Szilagyi PG, . Blood lead screening practices among US pediatricians. Pediatrics. 1996;98(3 Pt 1):372–7. PMID: 8784359.8784359
34 Lane WG, Kemper AR, American College of Preventive M. American College of Preventive Medicine Practice Policy Statement. Screening for elevated blood lead levels in children. Am J Prev Med. 2001;20(1):78–82. PMID: 11137780.11137780
35 Bright Futures/American Academy of Pediatrics. Recommendations for Preventive Pediatric Health Care. 2016. www.aap.org/en-us/professional-resources/practice-support/Periodicity/Periodicity%20Schedule_FINAL.pdf. Accessed November 21, 2017.
36 American Academy of Family Physicians. Summary of Recommendations for Clinical Preventive Services. Lakewood, KS; 2016. www.aafp.org/dam/AAFP/documents/patient_care/clinical_recommendations/cps-recommendations.pdf. Accessed November 21, 2017.
37 Council on Environmental Health. Prevention of childhood lead toxicity. Pediatrics. 2016;138(1). doi: 10.1542/peds.2016-1493.
38 U.S. Preventive Services Task Force. Procedure Manual. 2017. www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed November 15, 2017.
39 United Nations Development Programme. International Human Development Indicators. 2017. hdr.undp.org/en/countries. Accessed November 17, 2017.
40 Moses LE, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. 1993;12(14):1293–316. PMID: 8210827.8210827
41 Liu Z, Yao Z, Li C, . A step-by-step guide to the systematic review and meta-analysis of diagnostic and prognostic test accuracy evaluations. Br J Cancer. 2013;108(11):2299–303. doi: 10.1038/bjc.2013.185. PMID: 23695015.23695015
42 Toft N, Nielsen SS. Summary receiver operating characteristics (SROC) and hierarchical SROC models for analysis of diagnostic test evaluations of antibody ELISAs for paratuberculosis. Prev Vet Med. 2009;92(3):249–55. doi: 10.1016/j.prevetmed.2009.08.019. PMID: 19747743.19747743
43 Casey R, Wiley C, Rutstein R, . Prevalence of lead poisoning in an urban cohort of infants with high socioeconomic status. Clin Pediatr. 1994;33(8):480–4. PMID: 7955789.7955789
44 Dalton MA, Sargent JD, Stukel TA. Utility of a risk assessment questionnaire in identifying children with lead exposure. Arch Pediatr Adolesc Med. 1996;150(2):197–202. PMID: 8556126.8556126
45 Robin LF, Beller M, Middaugh JP. Statewide assessment of lead poisoning and exposure risk among children receiving Medicaid services in Alaska. Pediatrics. 1997;99(4):E9. PMID: 9099784.9099784
46 Snyder DC, Mohle-Boetani JC, Palla B, . Development of a population-specific risk assessment to predict elevated blood lead levels in Santa Clara County, California. Pediatrics. 1995;96(4 Pt 1):643–8. PMID: 7567324.7567324
47 Kazal LA, Jr. The failure of CDC screening questionnaire to efficiently detect elevated lead levels in a rural population of children. J Fam Pract. 1997;45(6):515–8. PMID: 9420588.9420588
48 France EK, Gitterman BA, Melinkovich P, . The accuracy of a lead questionnaire in predicting elevated pediatric blood lead levels. Arch Pediatr Adolesc Med. 1996;150(9):958–63. PMID: 8790128.8790128
49 Holmes SE, Drutz JE, Buffone GJ, . Blood lead levels in a continuity clinic population. J Toxicol Clin Toxicol. 1997;35(2):181–6. PMID: 9120888.9120888
50 Muniz MA, Dundas R, Mahoney MC. Evaluation of a childhood lead questionnaire in predicting elevated blood lead levels in a rural community. J Rural Health. 2003;19(1):15–9. PMID: 12585770.12585770
51 Schaffer SJ, Kincaid MS, Endres N, . Lead poisoning risk determination in a rural setting. Pediatrics. 1996;97(1):84–90. PMID: 8545231.8545231
52 Binns HJ, LeBailly SA, Poncher J, . Is there lead in the suburbs? Risk assessment in Chicago suburban pediatric practices. Pediatric Practice Research Group. Pediatrics. 1994;93(2):164–71. PMID: 8121725.8121725
53 Lanphear BP, Succop P, Roda S, . The effect of soil abatement on blood lead levels in children living near a former smelting and milling operation. Public Health Rep. 2003;118(2):83–91. doi: 10.1093/phr/118.2.83. PMID: 12690062.12690062
54 McCusker J. Longitudinal changes in blood lead level in children and their relationship to season, age, and exposure to paint or plaster. Am J Public Health. 1979;69(4):348–52. PMID: 426160.426160
55 Nordin JD, Rolnick SJ, Griffin JM. Prevalence of excess lead absorption and associated risk factors in children enrolled in a midwestern health maintenance organization. Pediatrics. 1994;93(2):172–7. PMID: 8121726.8121726
56 Rooney BL, Hayes EB, Allen BK, . Development of a screening tool for prediction of children at risk for lead exposure in a midwestern clinical setting. Pediatrics. 1994;93(2):183–7. PMID: 8121728.8121728
57 Sargent JD, Dalton M, Klein RZ. Diagnostic testing unwarranted for children with blood lead 10 to 14 microg/dL. Pediatrics. 1999;103(4):e51. PMID: 10103343.10103343
58 Schaffer SJ, Szilagyi PG, Weitzman M. Lead poisoning risk determination in an urban population through the use of a standardized questionnaire. Pediatrics. 1994;93(2):159–63. PMID: 8121724.8121724
59 Striph KB. Prevalence of lead poisoning in a suburban practice. J Fam Pract. 1995;41(1):65–71. PMID: 7798067.7798067
60 Tejeda DM, Wyatt DD, Rostek BR, . Do questions about lead exposure predict elevated lead levels? Pediatrics. 1994;93(2):192–4. PMID: 8121730.8121730
61 Holtrop TG, Yee HY, Simpson PM, . A community outreach lead screening program using capillary blood collected on filter paper. Arch Pediatr Adolesc Med. 1998;152(5):455–8. PMID: 9605028.9605028
62 Sargent JD, Dalton MA. Rethinking the threshold for an abnormal capillary blood lead screening test. Arch Pediatr Adolesc Med. 1996;150(10):1084–8. PMID: 8859143.8859143
63 Schlenker TL, Fritz CJ, Mark D, . Screening for pediatric lead poisoning. Comparability of simultaneously drawn capillary and venous blood samples. JAMA. 1994;271(17):1346–8. PMID: 8158820.8158820
64 Anonymous. Safety and efficacy of succimer in toddlers with blood lead levels of 20-44 microg/dL. Treatment of Lead-Exposed Children (TLC) Trial Group. Pediatr Res. 2000;48(5):593–9. doi: 10.1203/00006450-200011000-00007. PMID: 11044477.11044477
65 Dietrich KN, Ware JH, Salganik M, . Effect of chelation therapy on the neuropsychological and behavioral development of lead-exposed children after school entry. Pediatrics. 2004;114(1):19–26. PMID: 15231903.15231903
66 Liu X, Dietrich KN, Radcliffe J, . Do children with falling blood lead levels have improved cognition? Pediatrics. 2002;110(4):787–91. PMID: 12359796.12359796
67 Rogan WJ, Dietrich KN, Ware JH, . The effect of chelation therapy with succimer on neuropsychological development in children exposed to lead. N Engl J Med. 2001;344(19):1421–6. doi: 10.1056/NEJM200105103441902. PMID: 11346806.11346806
68 O’Connor ME, Rich D. Children with moderately elevated lead levels: is chelation with DMSA helpful? Clin Pediatr (Phila). 1999;38(6):325–31. doi: 10.1177/000992289903800602. PMID: 10378089.10378089
69 Boreland F, Lesjak M, Lyle D. Evaluation of home lead remediation in an Australian mining community. Sci Total Environ. 2009;408(2):202–8. doi: 10.1016/j.scitotenv.2009.10.013. PMID: 19853886.19853886
70 Brown MJ, McLaine P, Dixon S, . A randomized, community-based trial of home visiting to reduce blood lead levels in children. Pediatrics. 2006;117(1):147–53. doi: 10.1542/peds.2004-2880. PMID: 16396872.16396872
71 Markowitz ME, Sinnett M, Rosen JF. A randomized trial of calcium supplementation for childhood lead poisoning. Pediatrics. 2004;113(1 Pt 1):e34–9. PMID: 14702492.14702492
72 Wolf AW, Jimenez E, Lozoff B. Effects of iron therapy on infant blood lead levels. J Pediatr. 2003;143(6):789–95. doi: 10.1067/S0022-3476(03)00540-7. PMID: 14657829.14657829
73 Nicholson JS. A community-based intervention for low-income families to reduce children’s blood lead levels between 3–9.9 μg/Dl. Children’s Health Care. 2017:1–18. doi: 10.1080/02739615.2017.1370673.
74 Shannon M, Graef J, Lovejoy FH, Jr. Efficacy and toxicity of D-penicillamine in low-level lead poisoning. J Pediatr. 1988;112(5):799–804. PMID: 3361395.3361395
75 Ettinger AS, Brown MJ. Re: Errata for prevention of childhood lead toxicity. Pediatrics. 2018;141(4)doi: 10.1542/peds.2018-0064. PMID: 29602899.29602899
76 Ossiander EM. A systematic review of screening questionnaires for childhood lead poisoning. J Public Health Manag Pract. 2013;19(1):E21–9. doi: 10.1097/PHH.0b013e3182249523. PMID: 22668673.22668673
77 Caldwell KL, Cheng PY, Jarrett JM, . Measurement challenges at low blood lead levels. Pediatrics. 2017;140(2)doi: 10.1542/peds.2017-0272. PMID: 28771411.28771411
78 World Health Organization. Brief guide to analytical methods for measuring lead in blood. 2011. www.who.int/ipcs/assessment/public_health/lead_blood.pdf. Accessed December 13, 2017.
79 Lanphear BP, Weitzman M, Eberly S. Racial differences in Urban children’s environmental exposures to lead. Am J Public Health. 1996;86(10):1460–3. PMID: 8876521.8876521
80 Centers for Disease Control and Prevention. Lead poisoning from Mexican folk remedies-California. MMWR. 1983;32(42):554–5. PMID: 6415385.6415385
81 Centers for Disease Control and Prevention. Lead poisoning associated with imported candy and powdered food coloring-California and Michigan. MMWR. 1998;47(48):1041–3. PMID: 9869075.9869075
82 US Department of Health and Human Services, Agency for Toxic Substances and Disease Registry. Lead toxicity. Case Studies in Environmental Medicine. 2000.
83 Sargent JD, Brown MJ, Freeman JL, . Childhood lead poisoning in Massachusetts communities: its association with sociodemographic and housing characteristics. Am J Public Health. 1995;85(4):528–34. PMID: 7702117.7702117