# Acknowledgements

The authors thank AHRQ Medical Officer Iris Mabry-Hernandez, MD, MPH, as well as current and former members of the U.S. Preventive Services Task Force who contributed to topic discussions.