# Chapter 4 Discussion

## Summary of Review Findings

Consistent with the prior USPSTF review,^1^ no study directly evaluated benefits or harms of screening children for elevated BLLs compared with no screening. As in the prior USPSTF review, we found four additional studies of instruments to identify children at higher risk of elevated BLLs to guide targeted screening, all of which had poor diagnostic accuracy. This update also confirms there are no clear effects of interventions for lowering elevated BLLs in affected children or for improving neurodevelopmental outcomes. Evidence reviewed for this update is summarized in Table 2.

Given the decreased prevalence of elevated BLLs in the U.S. pediatric population (from 88% between 1976 and 1980 to 0.8% from 2007 to 2010), targeted screening strategies have been suggested.^4^ The most commonly used risk assessment instrument is the CDC questionnaire. However, studies found poor diagnostic accuracy of the 1991 CDC questionnaire for identifying children with elevated BLLs, with noninformative likelihood ratios.^3^ In addition, the CDC questionnaire was created in 1991 and no study on its accuracy has been published since 1997, potentially limiting the applicability of currently available evidence to contemporary clinical practice. Accordingly, screening recommendations from the CDC, AAP, and other organizations note the limitations of this questionnaire. The CDC recommends that public and clinical health professionals collaborate to develop screening plans that are responsive to local conditions by using local data, with universal screening in the absence of such plans.^25,75^ Accurate risk assessment instruments would facilitate improved targeted screening strategies, and some states have adapted the CDC questionnaire with items addressing local risk factors. However, studies on modified versions of the CDC questionnaire for specific settings and populations also showed poor accuracy for identifying children at risk for elevated BLLs.^48–51^ In lieu of accurate screening instruments for identifying children to screen, alternative strategies such as universal screening^43,47^ or screening targeted at communities with high prevalence of elevated BLLs could be effective.^44^

A recent systematic review^76^ of screening questionnaires for elevated BLLs reported sensitivities ranging from 0.25 to 0.87 and specificities ranging from 0.31 to 0.80, but it included other questionnaires, did not report results for the CDC questionnaire separately, included studies that evaluated different cutoffs for a positive questionnaire, or did not use venous samples as the reference standard. Our findings regarding the poor accuracy of the CDC questionnaire are generally consistent with this review.

Four studies evaluated the diagnostic accuracy of capillary blood lead testing compared with venous measurement.^27,61–63^ Capillary sampling is slightly less sensitive than venous sampling, with comparable specificity, provided that contamination is avoided using standard techniques. Factors that may inform the decision to perform capillary versus venous sampling for screening include the tradeoffs between slightly worse accuracy and greater convenience or patient preferences. Both methods require confirmation of elevated BLLs. The prior review provided descriptive information of some diagnostic tests but did not evaluate the diagnostic accuracy of sampling techniques using venous blood as a reference standard.

There is limited evidence on the effectiveness of interventions for elevated BLLs on neurodevelopmental outcomes and BLLs. One trial showed short-term (through 1 year) effects of DMSA chelation therapy on lowering BLLs versus placebo in children with moderately elevated BLLs (20 to 44 µg/dL) at baseline, but no clear effects on longer-term BLLs or neurodevelopmental outcomes, and some data indicating potential harms (hematological and other laboratory parameters and growth).^64–67^ A small, fair-quality trial found no effects of DMSA chelation therapy on BLLs.^68^ No trial evaluated effects of chelation therapy in children with BLLs less than 20 µg/dL, but chelation therapy in children with blood lead concentrations in this range is not recommended in the absence of severe symptoms. Evidence on residential interventions was limited and showed no clear effects on blood lead concentrations, while evidence on nutritional interventions (calcium or iron supplementation) was of poor quality and insufficient to determine effects on clinical outcomes. The prior review found limited and contradictory effects of nutritional interventions, no studies on outcomes related to residential lead hazard control, and short term reductions in BLL from chelation therapy, with no sustained effect over longer periods.

## Contextual Issues

Evidence on the intraindividual and interlaboratory reliability of BLL testing would be helpful for interpreting testing results, informing technical standards, and informing testing protocols and strategies. Newer recommendations suggest the use of a population-based reference value as the “level of concern” to identify children and environments associated with lead hazards.^77^ Lowering the reference value may affect the accuracy and precision of blood collection and analysis, suggesting that further evidence on test reliability would be advantageous. The World Health Organization has noted the potential benefits of portable point-of-care testing and recommends a highly accurate method with a low limit of detection for the general population in which relatively low levels of exposure exist.^78^ The association between reduced BLLs and improved health outcomes was addressed in one treatment trial, which found that short-term decreases in blood lead concentrations induced by treatment with DMSA did not correlate with long-term cognitive test scores.^66^

## Limitations

This review has several limitations. First, there was an overall lack of evidence to address all Key Questions. Second, despite searching for updated data, the available studies evaluating the effectiveness of risk-based questionnaires were published between 1994 and 2003 and may not assess contemporary risk factors. Current clinical practice uses a reference BLL of greater than 5 µg/dL, based on updated CDC guidance, but several of the studies included in this review used the older reference value of 10 µg/dL. Despite changing reference values, included studies of diagnostic accuracy may also not reflect the amount of potential error in measures of continuous BLLs, as these are prone to miscategorization due to the dichotomization of results, regardless of which threshold is used. Third, nonrandomized studies were included to evaluate the effectiveness of interventions for elevated BLLs, but these are more susceptible to confounding and bias than well conducted RCTs, leading to downgrading of study quality. Fourth, direct correlation of environmental lead exposures with longer-term health outcomes is difficult to study and characterize, since these exposures often have subtle clinical effects. Fifth, the review focused on screening and treatment of individuals in primary care settings, excluding community and public health approaches that could inform screening practices at the population level. The review restricted inclusion to English-language articles, which could result in language bias. However, we did not identify non–English-language studies in our searches that otherwise met inclusion criteria. Finally, we did not attempt meta-analysis for outcomes other than diagnostic accuracy, given the small number of studies and clinical and methodological diversity within the studies, and we were unable to formally assess for publication bias due to the small number of studies.

## Evidence for Priority Populations, Particularly Racial/Ethnic Minorities

Elevated BLLs predominantly affect socioeconomically disadvantaged and minority children. Different sources of lead exposure than previously considered are emerging in these populations, yet research on screening and prevention in these populations remains limited.^79–81^ Exposures related to community water sources, lead pipes in schools, and factory emissions affecting neighborhood soil quality are some of the emerging factors that are not well incorporated into current screening questionnaires. Additional research is warranted to validate these potential associations in specific geographic locations and among at-risk populations. Culturally-linked sources of lead poisoning such as imported candy, pottery, and cosmetics, specific to subpopulations living in the United States, may also provide information about risk in minority populations. For example, traditional folk remedies and imported digestive remedies that may contain high levels of lead are not monitored by the U.S. Food and Drug Administration and are more common in Hispanic and Asian populations.^80,81^ Nontraditional sources of lead exposure that come from items manufactured in other countries, such as leaded pots and pans, cosmetics, medicines, ceramics, candy, and leaded crystal may also pose additional risk since little regulation exists to monitor, identify, and control these nonpaint exposures. Children who are exposed to less commonly recognized sources of lead exposure also often live in areas with a higher risk for housing-related source exposures.^79^ The dual risk associated with minority communities calls for a more focused strategy to deal with population-specific risks.

## Future Research

Elevated BLLs are associated with serious health consequences. Additional research is needed to better inform decisions regarding screening for elevated BLLs in children. Effective screening could identify lead-contaminated residential environments and abate them, not only to improve the health of the child but also for siblings and others in the household. While remediation of lead exposures in a specific residence may be too late for a child who already is exposed, interventions could prevent exposures in subsequent generations of children who may reside in that residence. Development of questionnaires that incorporate current risk factors for elevated BLLs with validation in contemporary populations of children in the United States is necessary. Research is needed to evaluate the effectiveness of treatments for elevated BLLs such as counseling, nutritional interventions (such as calcium), and residential lead hazard control techniques in trials with adequate sample sizes to inform treatment strategies. While there is limited evidence for a clinical benefit of nutritional supplementation in reducing BLLs in children, epidemiological evidence is supported by studies of the toxicokinetics of lead in childhood^82^ and could be further validated by well-designed research studies. Ideally, randomized trials would recruit children from a range of racial/ethnic and socioeconomic strata, and evaluate the effects of screening on improving health outcomes as well as harms in the short and long term. However, randomized trials may not be feasible or appropriate for lead screening or some interventions of environmental health exposures due to ethical issues. Research on newer methods for testing for elevated BLLs, such as point-of-care testing, and on the intraindividual and interlaboratory reliability of BLL testing would be helpful for informing testing strategies.

## Conclusions

Evidence on the benefits and harms of screening children for lead poisoning is lacking. Screening questionnaires are not accurate for identifying children with elevated BLLs. Capillary blood testing is slightly less accurate than venous blood testing for identification of elevated BLLs. Treatment studies of chelating agents, often combined with environmental or household interventions, were not associated with sustained effects on BLLs but were associated with harms.