# Chapter 2 Methods

## Key Questions and Analytic Framework

This systematic review followed a standard protocol in accordance with USPSTF procedures.^38^ The scope and Key Questions for this report were developed by Evidence-based Practice Center investigators in collaboration with the USPSTF and the Agency for Healthcare Research and Quality, and informed by evidence gaps identified from the prior review.^1^ In addition, three Contextual Questions were requested by the USPSTF. Contextual Questions address topics important to the USPSTF recommendations, but are reviewed by summarizing evidence from key informative studies rather than by using systematic review methodology. Key Questions and Contextual Questions are listed below. Investigators created an analytic framework incorporating the Key Questions and outlining the patient populations, interventions, outcomes, and potential adverse effects, as well as the direct and indirect pathways from screening to health outcomes (Figure 1). A research plan was externally reviewed and modified prior to finalization.

Figure 1 Analytic Framework and Key Questions

Abbreviation: KQ=key question.

^a^ Interventions include counseling families to reduce lead exposure, nutritional interventions, residential hazard control techniques, and chelation therapy.

^b^ We included outcomes measured in family members (e.g., siblings, pregnant women in the same household) subsequently identified as having elevated blood lead levels after the index family member was found to have an elevated blood lead level during screening.

Figure 1 is an analytic framework that depicts the populations, interventions, outcomes, and harms of interest for screening for elevated blood lead levels in children. The far left of the framework describes the target population for screening: asymptomatic children age 5 years and younger. To the right is screening. Below the screening is an oval for harms of screening. An arrow leads from screening to a box containing health outcomes of reduced cognitive problems, reduced behavioral problems, and reduced learning disorders. To the right of screening is a box for elevated blood lead level. An arrow leads from asymptomatic children age 5 years and younger to the box for elevated lead levels. To the right of elevated blood lead levels is the intervention for elevated blood lead levels, which has an oval below it for harms of intervention. An arrow leads from intervention directly to the health outcomes of reduced cognitive problems, reduced behavioral problems, and reduced learning disorders. To the right of the intervention is a box for the intermediate outcome of reduced blood lead level. The intermediate outcome of reduced blood lead level has a dotted line leading to the final health outcomes of reduced cognitive problems, reduced behavioral problems, and reduced learning disorders.

### Key Questions

1 Is there direct evidence that screening for elevated BLLs in asymptomatic children age 5 years and younger improves health outcomes (i.e., reduced cognitive or behavioral problems or learning disorders)?
2a What is the accuracy of questionnaires or clinical prediction tools that identify children who have elevated BLLs?
2b What is the accuracy of capillary blood lead testing in children?
3 What are the harms of screening for elevated BLLs (with or without screening questionnaires) in children?
4 Do counseling and nutritional interventions, residential lead hazard control techniques, or chelation therapy reduce BLLs in asymptomatic children with elevated BLLs?
5 Do counseling and nutritional interventions, residential lead hazard control techniques, or chelation therapy improve health outcomes in asymptomatic children with elevated BLLs?
6 What are the harms of interventions in asymptomatic children with elevated BLLs?

### Contextual Questions

1. What is the reliability of capillary and venous BLL testing at various lead levels in children?
2. What is the association between reduced BLLs and improved health outcomes in asymptomatic children with elevated BLLs?
3. Are there valid risk prediction tools available that identify communities at highest risk for lead exposure that could be used in primary care practices to target screening efforts in children?

Key Question 1 focused on direct evidence of the effectiveness of screening asymptomatic children age 5 years and younger for elevated BLLs for improving future health outcomes (e.g., reduced cognitive problems, reduced behavioral problems, and reduced learning disorders) compared with not screening. Screening refers to diagnostic testing of BLLs to identify children with unrecognized elevation of lead levels. Because such direct evidence may be limited, the remainder of the analytic framework (Key Questions 2 through 6) evaluates the chain of indirect evidence needed to link screening with improvement in important health outcomes. Links in the chain of indirect evidence include the accuracy of screening for identifying children with elevated BLLs, the effectiveness of interventions for treating children identified with elevated BLLs and reducing the incidence of complications, the association between improvements in intermediate outcomes and clinical health outcomes, and harms associated with screening and treatments. Implicit in the indirect chain of evidence is that, to understand benefits and harms of screening, it is necessary but not sufficient to show that children with elevated BLLs can be identified. It is also necessary to show that there are effective treatments for children identified with elevated BLLs.

A separate report addresses screening for elevated BLLs in pregnant women.

## Search Strategies

Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews (through March 2017), Ovid MEDLINE (1946 through March 2017), all studies from prior reviews, and reference lists of included studies were searched for relevant studies. Search strategies are available in Appendix A1. An additional Ovid MEDLINE search (through October 2017) was conducted for the Contextual Questions after the initial search did not identify any studies meeting inclusion criteria. Searches were updated through June 2018. Ongoing surveillance was conducted through article alerts and targeted searches of high-impact journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and therefore the related USPSTF recommendation. The last surveillance was conducted on December 5, 2018.

## Study Selection

Two reviewers independently evaluated each study to determine its inclusion eligibility based on predetermined inclusion and exclusion criteria developed for each Key Question (Appendix A2).

Populations of asymptomatic children age 5 years and younger were included, regardless of risk for elevated BLLs, but we accepted studies that included children older than age 5 years when the majority of the study population was age 5 years and younger. Studies of high- or low-risk populations were included for all Key Questions. Testing approaches included screening questionnaires and venous or capillary blood lead testing. Comparisons were screening versus no screening (Key Question 1); a questionnaire versus a reference standard (i.e., venous lead level) (Key Question 2a); capillary versus venous BLL testing (Key Question 2b); and treatment versus no treatment, placebo, or inactive control (Key Questions 3 through 5). Intermediate outcomes (e.g., BLLs) were included, as well as clinical outcomes using validated measures of cognitive or neurobehavioral outcomes in children. Other outcomes were measures of diagnostic accuracy (Key Question 2) and harms of testing (e.g., anxiety, distress, pain, or discomfort related to testing) and treatment. Inclusion was restricted to English-language articles and studies only published as abstracts were excluded. Studies of nonhuman subjects were also excluded, and studies had to report original data. Studies conducted in countries with a “very high” Human Development Index^39^ (i.e., considered applicable to U.S. populations and practice) were included; studies from countries with a “high” Human Development Index were included if no other studies were available. Included studies for Key Questions 4 through 6 (treatment of elevated BLLs) were studies of asymptomatic children conducted in any country that evaluated interventions that focused on the individual or family (i.e., counseling, nutritional interventions, residential hazard control techniques, and chelation therapy). Studies on effects of policies, laws, or community-based interventions focused on the primary prevention of lead exposure were excluded. For harms, randomized, controlled trials (RCTs) of screening and treatments, controlled clinical trials on effects of therapies on health outcomes, controlled clinical trials and prospective cohort studies on harms of therapies, and studies on diagnostic accuracy of screening questionnaires or capillary sampling were included. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists included studies and Appendix A5 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

One investigator abstracted details about the study design, patient population, setting, screening method, interventions, analysis, followup, and results. A second investigator reviewed data abstraction for accuracy. For studies that did not report measures of diagnostic accuracy but provided the necessary data, we calculated relative risks (RRs), likelihood ratios, positive and negative predictive values, and 95 percent CIs or p-values. Two investigators independently applied criteria developed by the USPSTF^38^ to rate the quality of each study as good, fair, or poor (Appendix A6) and resolved discrepancies by consensus.

## Data Synthesis

Two independent reviewers assessed the internal validity (quality) of the body of evidence for each Key Question (“good,” “fair,” or “poor”) using methods developed by the USPSTF, based on the number, quality, and size of studies, consistency of results between studies, and directness of evidence (Table 2).^38^ For diagnostic accuracy of clinical questionnaires, comparable studies were pooled using a random-effects model with the ‘metandi’ command in Stata version 14.2 and created hierarchical summary receiver operating characteristic (ROC) plots using the ‘metandiplot’ function.^40,41^ The “metandi” command is a meta-analysis function for diagnostic test accuracy studies in which both the index test under study and the reference test (gold standard) are dichotomous. It assumes a bivariate normal distribution for random effects as a two-level mixed logistic regression model, with independent binomial distributions for the true positives and true negatives within each study, and a bivariate normal model for the logit transforms of sensitivity and specificity between studies. Forest plots (without a summary measure) and summary ROC plots were also created using Review Manager version 5.3.^42^

Table 2 Summary of Evidence

Key Question^*^ | Main Findings From Prior USPSTF Reviews | Number and Type of Studies Identified for Update | Limitations | Consistency | Applicability | Summary of Findings | Strength of Evidence^†^
1 | No studies | 0 | No studies | No studies | Not applicable | No studies | Insufficient
2a | Not previously reviewed^‡^ | 10 cross-sectional studies | All studies conducted from 1994 to 2003; studies used the 1991 CDC questionnaire or a modified version of this survey. | Consistent | Moderate | Five studies that used the threshold of ≥1 positive answers on the 5-item 1991 CDC screening questionnaire reported a pooled sensitivity of 48% (95% CI, 31.4% to 65.6%) and specificity of 58% (95% CI, 39.9% to 74.0%) for identifying children with a venous BLL ≥10 µg/dL. Four studies that used versions of the CDC questionnaire modified for specific populations or settings did not demonstrate improved accuracy (sensitivity range, 25% to 68%; specificity range, 49% to 58%). | Moderate
2b | Not previously reviewed^‡^ | 4 observational studies | None | Consistent | Moderate | Four studies conducted in urban areas of the U.S. found capillary BLL testing associated with sensitivity of 87% to 91% and specificity >90% (92% to 99%) for identification of elevated BLL compared with venous sampling. | Moderate
3 | No studies | 0 | No studies | No studies | Not applicable | No studies | Insufficient
4 | Not previously reviewed^‡^ | 7 RCTs or observational studies (in 10 publications) | Poor-quality studies of nutritional interventions do not provide adequate data to assess treatment effects. | Consistent | Low to moderate | One large RCT found that chelation therapy with DMSA in children with a mean BLL of 20 to 45 μg/dL was associated with decreased BLL vs. placebo at 1 week, 6 months, and 1 year, but there were no effects at longer-term followup at 4.5 to 6 years. One RCT found no differences between chelation and placebo in BLL at 1 or 6 months. There was insufficient evidence from 2 studies to determine effects of nutritional supplementation. Three studies of residential lead hazard control techniques found no difference in BLL between intervention or control groups. | Moderate
5 | No clear evidence to support a clinical benefit from chelation therapy in children with elevated BLL at baseline, based on 1 trial; no studies on effects of environmental or nutritional interventions on health outcomes. | 1 RCT (in 3 publications) | Based on 1 RCT of 780 U.S. children, the adjusted treatment effect on one cognitive testing subscore showed a statistically significant but small improvement in the placebo group (p=0.045). No other significant outcomes for all other effects of treatment on cognitive, neuropsychiatric, and behavioral testing scores. | Consistent | Moderate | One randomized study found no differences between chelation therapy and placebo in neuropsychological outcomes, despite a decrease in BLL following chelation. There was no evidence on effects of counseling and nutritional interventions or residential lead hazard control techniques on health outcomes in asymptomatic children with elevated BLL at baseline. | Moderate
6 | Adverse effects of environmental interventions included transient BLL, inconvenience associated with abatement work or relocation, and cost-benefit considerations. Adverse effects after chelation treatment included mild GI and systemic symptoms, rashes, transient hyperphosphatas-emia, neutropenia, eosinophilia, and elevations in serum aminotransferases | 1 RCT (in 3 publications) and 1 observational study | One poor-quality study reported intermediate outcomes associated with adverse effects of treatment. | Consistent | Moderate to high for harms | One good-quality and 1 poor-quality study reported adverse effects of chelation therapy. The good-quality study found that children treated with DMSA had a small but statistically significant decrease in height growth over 34 months and slightly poorer scores on attention and executive function tests at age 7 years. One poor-quality study reported adverse events associated with the less commonly used chelator d-penicillamine, including leukopenia, thrombocytopenia, urticarial and maculopapular rashes, urinary incontinence, abdominal pain, and diarrhea. No study identified harms of counseling, nutritional interventions, or residential lead hazard control techniques. | Moderate

* Key Question 1. Is there direct evidence that screening for elevated BLLs in asymptomatic children age 5 years and younger improves health outcomes (i.e., reduced cognitive or behavioral problems or learning disorders)?

Key Question 2a. What is the accuracy of questionnaires or clinical prediction tools that identify children who have elevated BLLs?

Key Question 2b. What is the accuracy of capillary blood lead testing in children?

Key Question 3. What are the harms of screening for elevated BLLs (with or without screening questionnaires) in children?

Key Question 4. Do counseling and nutritional interventions, residential lead hazard control techniques, or chelation therapy reduce BLLs in asymptomatic children with elevated BLLs?

Key Question 5. Do counseling and nutritional interventions, residential lead hazard control techniques, or chelation therapy improve health outcomes in asymptomatic children with elevated BLLs?

Key Question 6. What are the harms of interventions in asymptomatic children with elevated BLLs?

† “EPC Assessment of Strength of Evidence” is based on new evidence identified for this update and relevant evidence from the prior report.

‡ Key Questions in this review differ from the previous review and Key Question numbers in this review do not correspond to Key Question numbers in the prior review. For some questions, the number of studies included in the prior review was not precisely reported.

Abbreviations: BLL=blood lead level; CDC=Centers for Disease Control and Prevention; CI=confidence interval; DMSA=dimercaptosuccinic acid; GI=gastrointestinal; RCT=randomized, controlled trial; U.S.=United States; USPSTF=U.S. Preventive Services Task Force.

## External Review

The draft report was reviewed by content experts (Appendix A7), USPSTF members, Agency for Healthcare Research and Quality Project Officers, and collaborative partners, and has been posted for public comment; it has been revised accordingly.

## Response to Public Comment

The draft report was posted for public comment on the USPSTF Web site from October 30, 2018 to December 3, 2018. Comments encompassed requests to include results from studies of primary prevention and challenges in assessing clinical effects of lead exposure, which can take several years to manifest. However, primary prevention of lead exposure is out of scope for this review, which focused on screening and interventions to identify and reduce already elevated BLLs. As noted in the Results, studies on the long-term effects of screening or treatment of elevated BLLs are lacking.