# Chapter 1 Introduction and Background

## Purpose and Previous U.S. Preventive Services Task Force Recommendation

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2006 recommendation on screening for elevated blood lead levels in children. This update focuses on studies published since the prior USPSTF systematic review^1^ of this topic as well as studies included in the prior review.

In 2006, the USPSTF found insufficient evidence for screening asymptomatic children ages 1 to 5 years at increased risk for elevated blood lead levels (BLLs) (I recommendation). The USPSTF recommended against routine screening for elevated BLLs in asymptomatic children ages 1 to 5 years who are at average risk (D recommendation) based on evidence that did not support any benefits conferred with detection or early intervention among children with asymptomatic or mild/moderate lead levels. In addition, good-quality evidence from the 2006 review showed that interventions did not result in sustained decreases in BLLs, and chelation treatment specifically was associated with a slight diminution in cognitive performance.

## Condition Background

### Condition Definition

Elevated BLL is defined as greater than 5 µg/dL, according to the Centers for Disease Control and Prevention (CDC).^2^ Although no safe level of lead exposure exists, this is the level at which further clinical monitoring or treatment is recommended for children.^2^ Previously, children with a BLL of 10 µg/dL or greater were identified as having a blood lead “level of concern,” and the CDC recommended that identification of children with a BLL of 10 µg/dL or greater should prompt public health action and followup testing by state or local health departments.^3^ However, in 2012, the CDC’s Advisory Committee for Childhood Lead Poisoning Prevention (ACCLPP) lowered the level, because no safe level of lead exposure has been established, and it determined that a threshold of 10 µg/dL or greater likely misses children at risk of adverse health effects.^4^ The ACCLPP recommended using a reference range value based on the estimated 97.5 percentile of the BLL distribution among children ages 1 to 5 years calculated from two 2-year cycles of National Health and Nutritional Examination Survey (NHANES) data.^4^ In 2010, the upper value of the reference range was 5 µg/dL.^2^ The ACCLPP also recommended that clinicians monitor children with BLLs between 5 and 10 µg/dL based on evidence that higher BLLs are associated with IQ deficits, attention-related behaviors, and poor academic achievement.^4^ Current reference ranges are based on population levels from NHANES BLL distribution; these do not define safe lead levels but are the level at which further clinical monitoring and treatment is recommended. The reference range may continue to change with population prevalence.

### Prevalence and Burden of Disease/Illness

Lead causes a number of adverse health effects primarily affecting the central nervous, hematopoietic, hepatic, and renal systems.^5^ Manifestations are variable, but there is a general correlation between higher BLLs and the presence of symptoms. Acute toxicity resulting from intense lead exposure over a short duration is very uncommon and primarily associated with occupational exposure or ingestion of lead-containing products in children.^5^ Clinical symptoms of acute lead exposure include muscle pain, fatigue, abdominal pain, headache, vomiting, seizures, and coma.^5^

Many health effects associated with chronic exposure to elevated BLLs are irreversible. Compared with other organ systems, the nervous system is the most sensitive and chief target for lead-induced toxicity.^5^ The severity of lead toxicity is correlated with higher BLLs and may include delirium, lack of coordination, convulsions, paralysis, coma, ataxia, and death. Lead exposure can lead to anemia by directly affecting the synthesis of hemoglobin (by inhibiting various key enzymes involved in the heme synthesis pathway) and by reducing the life span of circulating erythrocytes by increasing the fragility of cell membranes.^6^

Adverse effects in children include behavioral and learning problems, lower IQ and hyperactivity, impaired growth, hearing problems, and anemia.^7^ Young children absorb lead at a higher rate (40% to 50% of ingested lead) compared to adults (3% to 10%) and are especially vulnerable to the neurological effects of lead.^8^ The developing nervous system is thought to absorb a higher fraction of blood lead compared with adults.^9^ New findings also suggest lead exposure in children can result in a range of cardiovascular, immunological, and endocrine adverse health effects.^4^ Few studies of the long-term consequences of childhood lead poisoning exist. However, in a 50-year followup of 35 adult survivors of childhood lead poisoning, all of whom had been symptomatic, cognitive dysfunction,^10^ hypertension,^11^ and offspring with learning disabilities^12^ were more prevalent than in matched adult controls.

Public health efforts to reduce exposure to lead in the United States (e.g., removal of lead from household paints and gasoline) are considered major successes. Although it is difficult to measure changes in morbidity attributable to lead exposure, the percentages of children and adults with elevated BLLs have declined significantly over the past few decades.

Data from the 1976 to 1980 cycle of NHANES estimated that 88 percent of children ages 1 to 5 years had BLLs of 10 µg/dL or greater. This percentage fell sharply in the following decades to 4.4 percent from 1991 to 1994, then 1.6 percent during the 1999 to 2002 cycle, and was estimated to be 0.8 percent in the most recent 2007 to 2010 survey cycle.^2^ NHANES data from 2007 to 2010 estimated that 3.1 percent of children ages 1 to 2 years had BLLs of 5 µg/dL or greater.^4^ Estimates varied by race/ethnicity, socioeconomic status, and age of housing. Among children ages 1 to 2 years, 7.7 percent of non-Hispanic black children had BLLs of 5 µg/dL or greater, compared with 3.2 percent of non-Hispanic white children and 1.6 percent of Mexican American children; 3.1 percent of males and 3.2 percent of females had BLLs of 5 µg/dL or greater in the same survey.^13^ Differences were also observed based on socioeconomic status; 6.0 percent of children living in a household with a poverty-to-income ratio of less than 1.3 had BLLs of 5 µg/dL or greater, compared with 0.5 percent of children living in a household with a poverty-to-income ratio of 1.3 or greater (ratio <1.00 indicates an income below the official definition of poverty). During the NHANES 1999 to 2002 cycle, children living in pre-1950 housing were 10 times more likely to have BLLs of 5 µg/dL or greater than children living in homes built after 1978. By the 2007 to 2010 cycle, children living in pre-1950 housing were 4 times more likely to have BLLs of 5 µg/dL or greater than children living in homes built after 1978.^13^

### Etiology and Natural History

Lead is a heavy metal that occurs naturally in the environment. Unique properties of lead (e.g., high malleability, low melting point, and resistance to corrosion) resulted in its widespread use in various industries. Lead has become widely distributed and mobilized in the environment resulting in increasing human exposure and uptake over time.^14^

Common sources of lead exposure include the following: lead-based paint, contaminated soil (e.g., by exterior lead-based paint, historical lead emitting industrial sites, or gasoline), lead-contaminated water (e.g., by lead plumbing), and dust contamination by chipping or chalking of lead-based paint and tracked-in soil.^14^ In the United States, leaded gasoline began to be phased out in 1973 and was banned by 1996. From 1980 to 2010, exposure to lead fumes from leaded gasoline decreased by 89 percent.^15^ Lead-based paints were banned for use in housing in 1978. All houses built before 1978 are likely to contain some lead-based paint and the deterioration of this paint is an important source of lead in older homes.^14^ Although lead was restricted in plumbing material in 1986, older homes and neighborhoods may still contain lead service lines, lead connections, or other lead-based plumbing materials.^16^ The release of lead from lead-based plumbing materials into drinking water is variable and influenced by factors such as water softness, temperature, acidity, and corrosion control techniques.^17^ Flint, Michigan provides an example of increased lead contamination of drinking water related to changes in water sources and treatment, including the use of disinfectants.^18^

Children are exposed to lead in a variety of ways. Since the removal of lead from gasoline, lead-based paint has become the major source of lead exposure for children in the United States.^19^ Other important pediatric sources of lead exposure include elevated maternal blood lead concentration during pregnancy and breastfeeding; exposure to lead-contaminated soil, food, or water; and lead in toys.^3^ Young children frequently place objects in their mouths resulting in ingestion of lead-contaminated dust and soil. Children and infants may be exposed to lead via drinking water or reconstituted formula,^20^ placental transfer of lead during pregnancy to the fetus, or maternal transfer of lead to infants through breast milk.^21^ Children can be exposed to lead via take-home exposures by adults who work with lead.^19^ Parental take-home exposures from work or hobbies can be easily transferred to children through lead dust found on hair, clothes, or tools. Compared with adults, children have a higher rate of physiological uptake of lead.

Once exposed, nutritional factors are known to affect lead absorption and toxicity. Iron-deficient or calcium-deficient diets may lead to more efficient lead absorption.^22^ Following absorption, lead is distributed to the blood, soft tissues, and bone. In blood, 99 percent of lead is bound to erythrocytes and the remaining 1 percent is free in the plasma to exchange with soft tissues (kidney, brain, liver, and bone marrow). More than 90 percent of lead in the body is stored in bone.^23^

### Risk Factors

Risk factors for lead exposure include: socioeconomic disadvantage; living in an area with lead industry; renovation or deterioration of older lead-painted houses; and previously living in developing countries where leaded gasoline is still used.^14^ Among children, socioeconomic factors such as lower family income, older age of housing, and poorer nutritional status predict exposure to lead.^4,13^

### Rationale for Screening/Screening Strategies

Current clinical guidelines and policies emphasize primary prevention of lead exposure. The rationale for screening in primary care settings is to identify children for whom primary prevention was unsuccessful, so that interventions can be initiated to reduce lead levels and minimize or prevent the neurodevelopmental adverse effects of lead poisoning.

As the prevalence of elevated BLLs has declined, clinical practice has shifted from universal to targeted screening that incorporates education about primary prevention.^24^ Several questionnaires have been developed to identify children at higher risk of elevated BLLs. The mostly widely used is the CDC questionnaire, developed in 1991, which consists of five questions about living in or visiting a house built before 1960 with chipping paint or undergoing renovation; having a sibling or close contact being followed or treated for lead poisoning (BLL ≥15 µg/dL); living with an adult who is exposed to lead through work or hobbies; and living near lead-based industry. The CDC has recommended the use of the questionnaire, with a positive or “don’t know” answer to any of the five questions indicating the need for a blood lead test.^25^ However, given more recent recognition of the limitations of this questionnaire, the CDC recommends that public and clinical health professionals collaborate to develop screening plans that are responsive to local conditions by using local data.^25^

Screening options to detect an elevated BLL include 1) directly measuring the BLL through venous or capillary blood sampling or 2) measuring the effect of lead exposure on hemoglobin synthesis using either a free erythrocyte or zinc protoporphyrin (EP) assay (via venous blood sampling).^24^ Measuring BLLs using capillary blood sampling is simpler than venous sampling and is the recommended initial method for lead screening.^26^ However, if performed incorrectly, capillary samples may be contaminated with exogenous lead and can yield false-positive results.^27^ Potential sources of contamination include inadequate use of gloves by phlebotomists, use of alcohol wipes contaminated with lead-based ink, inadequate cleansing of the child’s finger, and failure to wipe off the first drop of blood.^24^ Patients who have elevated BLLs on capillary samples must have confirmatory venous blood testing.^28^ EP levels usually are not elevated until BLLs are greater than 30 µg/dL. Therefore, EP levels are not an accurate assessment of lower levels of lead toxicity and are not recommended for screening.^24^ In addition, EP levels are elevated in other conditions, including iron deficiency and inherited porphyrias.^24^

### Interventions/Treatment

The management of elevated BLLs in children varies depending on the confirmed BLL and other factors. Identifying the source of lead exposure is a key to preventing ongoing or repeated exposure and remains the mainstay of treatment for lead exposure.

#### Educational and Environmental Interventions

Educational interventions address parental awareness of lead exposure pathways, hygiene, and household dust control measures to prevent ingestion of dust and soil. Environmental (household) interventions include specialized cleaning, repairs, maintenance, soil abatement (e.g., removal and replacement), painting, and temporary containment of lead hazards.

#### Nutritional Interventions

The role of nutritional supplementation in reducing blood lead concentration among children with elevated BLLs is unclear. Calcium, dietary iron, and other supplements are thought to decrease the intestinal absorption of lead. This is supported by epidemiologic studies that have demonstrated an increased prevalence of iron deficiency among children with lead poisoning.^29,30^ However, the association is inconsistent, and evidence of an association between iron intake and lead levels in iron-replete children is lacking.

#### Chelation Therapy

In children, chelation therapy is recommended for severe lead toxicity (defined by a venous BLL of ≥70 µg/dL or having symptoms of encephalopathy) and moderate toxicity (symptomatic or BLL between 45 and 69 µg/dL) and is generally reserved for symptomatic individuals. Chelating agents work as binding agents that remove metals (i.e., lead) from the blood and soft tissues, including the brain, to reverse acute encephalopathy and alleviate vomiting, abdominal pain, anemia, and renal insufficiency caused by lead toxicity. Dimercaprol (dimercaptosuccinic acid [DMSA] or succimer) is a commonly used agent for the oral chelation of lead in children with levels at or above 45 µg/dL,^31^ and d-penicillamine is rarely used in patients who do not tolerate DMSA. In regions where cost is an issue, d-penicillamine may be used, but it is not recommended as a first-line agent. However, multiple potential harms of chelation therapy have been described, including side effects such as rash, neutropenia, elevation of serum liver transaminases, and gastrointestinal upset, in addition to acute side effects such as injection site pain, nausea, vomiting, headache, paresthesias, and tremor.^32^ Serious adverse reactions may include hypertension, tachycardia, infection site abscess, and fever.^28^

### Current Clinical Practice/Recommendations of Other Groups

#### Current Clinical Practice

Data are lacking on the current proportion of primary providers who screen asymptomatic children for elevated BLLs. A 1996 survey (N=734) of pediatricians, members of the American Academy of Pediatrics (AAP), found that 53 percent reported screening all patients ages 9 to 36 months, 39 percent reported screening some patients, and 8 percent reported screening none of their patients. Among physicians who reported screening for elevated BLLs, 96 percent used a BLL assay and 3 percent used a porphyrin assay. Of those who used a BLL assay, 39 percent collected blood for screening using a finger stick method and 52 percent collected blood using venipuncture (9% did not report the method used). The primary risk factors that selective screeners identified were history of pica (94%), living in an older home with recent renovations (92%), living in an older home with peeling paint (93%), and having a sibling who had an elevated BLL (88%).^33^

When a child with an elevated BLL is identified, confirmatory and repeat testing is recommended, followed by management based on lead levels and symptoms. Important management strategies for asymptomatic children with BLLs of 45 µg/dL or less include removing the source of lead exposure, testing close contacts and other children in the household at risk, and lead abatement and education. For children who are symptomatic or with higher blood lead concentration (≥45 µg/dL), in addition to the management strategies mentioned above, emergent consultation with an expert is recommended for consideration of hospitalization, stabilization, and chelation therapy based on the degree of symptoms. Specific guidelines exist for followup depending on the degree of elevation of BLL.^25^

#### Recommendations of Other Groups

Table 1 summarizes current screening recommendations from other organizations. Contrary to the 2006 USPSTF recommendation, existing recommendations from the AAP, CDC, and American College of Preventive Medicine all state that children at high risk for lead exposure should receive screening.^4,23,34–36^ The American College of Preventive Medicine defines high-risk groups as those receiving Medicaid or WIC, living in a community with 12 percent or greater prevalence of BLLs at 10 µg/dL or greater, living in a community with 27 percent or greater of homes built before 1950, or meeting one or more high-risk criteria of a lead screening questionnaire. Questionnaires tailored to specific communities may include questions about the use of home remedies and cosmetics, country of origin, and behavioral risk factors.^34^ Bright Futures recommends screening in accordance with state law, and universal screening at ages 12 and 24 months in states with no screening program in place.^35^ In 2016, AAP recommended screening according to federal, state, and local requirements, with targeted screening of populations including immigrant, refugee, and internationally adopted children when they arrive in the United States; children ages 12 to 24 months living in communities with 25 percent or greater of housing built before 1960 or a 5 percent or greater prevalence of BLLs of 5 µg/dL or greater; and children with identified lead hazards or a home built before 1960 that is in poor repair or renovated in the past 6 months.^37^

Table 1 Current Recommendations From Other Organizations

Organization, Year | Screening Recommendation
American Academy of Family Physicians (AAFP) 2006^36^ | The AAFP adopted the 2006 USPSTF recommendations for children. Recommendations state that evidence is insufficient to recommend for or against routine screening for elevated BLLs in asymptomatic children ages 1 to 5 years who are at increased risk. The AAFP recommends against routine screening for elevated BLLs in asymptomatic children ages 1 to 5 years who are at average risk.
American Academy of Pediatrics (AAP) 2016^37^ | Providers should test asymptomatic children for elevated blood lead concentrations according to federal, local, and state requirements. Immigrant, refugee, and internationally adopted children also should be tested for blood lead concentrations when they arrive in the United States due to increased risk. Recommends targeted screening of children ages 12 to 24 months living in communities with ≥25% of housing built before 1960 or a prevalence of BLLs ≥5 μg/dL of ≥5%; children who live in or visit a home or child care facility with an identified lead hazard; and children living in a home built before 1960 in poor repair or renovated in the past 6 months.
American Academy of Pediatrics (AAP)/ Bright Futures^35^ 2012 | Screening for lead poisoning should be done in accordance with state law as applicable. For children who live in states that do not have a state screening program in place, the AAP recommends universal screening for children at ages 12 and 24 months.
American College of Preventive Medicine (ACPM) 2001^33^ | Screening for elevated BLLs via venous or capillary blood lead testing should be conducted for children at age 1 year, only if they are identified as being at high risk for elevated BLLs. Criteria for being at high risk include receipt of Medicaid or WIC, living in a community with ≥12% prevalence of BLLs at ≥10 µg/dL, living in a community with ≥27% of homes built before 1950, or meeting one or more high-risk criteria of a lead screening questionnaire. This questionnaire should include both questions suggested by the CDC in its 1997 guidelines and questions developed for and tailored to specific communities. These questions may pertain to use of home remedies and cosmetics, country of origin, and behavioral risk factors. Risk assessment for lead exposure should be performed beginning during prenatal visits and continuing until age 6 years.
Centers for Disease Control and Prevention (CDC) 2010^23^ | Guidelines emphasize primary prevention of lead poisoning and recommend that clinicians educate families about prevention of lead exposure and provide environmental assessments to identify sources of lead exposure before testing children for lead poisoning.
Advisory Committee on Childhood Lead Poisoning Prevention (ACCLPP) 2012^4^ | Blood lead screening remains necessary to identify children for whom primary prevention is unsuccessful. Screening for lead poisoning should be done in accordance with state law as applicable. For children who live in states that do not have a state screening program in place, the ACCLPP recommends universal screening for children at ages 12 and 24 months.

Abbreviations: AAFP=American Academy of Family Physicians; AAP=American Academy of Pediatrics; ACCLPP=Advisory Committee on Childhood Lead Poisoning Prevention; ACPM=American College of Preventive Medicine; BLL=blood lead level; CDC=Centers for Disease Control and Prevention; USPSTF=U.S. Preventive Services Task Force.