# Appendix C Quality Assessment

## Appendix C1 Quality Assessment of Childhood Diagnostic Accuracy Studies

Author, year | Was a consecutive or random sample of patients enrolled? | Was a case-control design avoided? | Did the study avoid inappropriate exclusions? | Were the index test results interpreted without knowledge of the results of the reference standard? | If a threshold was used, was it prespecified? | Is the reference standard likely to correctly classify the target condition? | Were the reference standard results interpreted without knowledge of the results of the index text? | Was there an appropriate interval between index test and reference standard? | Did all patients receive a reference standard? | Did patients receive the same reference standard? | Were all patients included in the analysis? | Quality rating
Casey, 1994^43^ | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | No | No | Yes | Yes | Fair
Dalton, 1996^44^ | No | Yes | Yes | Unclear | Yes | Yes | Yes | Unclear | No | Yes | No | Fair
France, 1996^48^ | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Holmes, 1997^49^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | No | Fair
Holtrop, 1998^61^ | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Fair
Kazal, 1997^47^ | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | No | Yes | No | Fair
Muniz, 2003^50^ | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear | No | Yes | Yes | Yes | Fair
Parsons, 1997^27^ | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Fair
Robin, 1997^45^ | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Sargent, 1996^62^ | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Schaffer, 1996^51^ | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear | Yes | No | No | No | Fair
Schlenker, 1994^63^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Fair
Snyder, 1995^46^ | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Unclear | Fair
Tejeda, 1994^60^ | No | Yes | Yes | Unclear | Yes | Yes | Unclear | No | Yes | Yes | No | Poor

## Appendix C2 Quality Assessment of Childhood Trials

Author, year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Attrition and withdrawals reported? | Loss to followup differential/ high? | Analyze people in the groups in which they were randomized? | Quality rating
Boreland, 2009^69^ | Unclear | Unclear | Yes; matched | Yes | Unclear | No | No | Yes | No/No | Yes | Fair
Brown, 2006^70^ | Yes | Yes | Yes | Yes | Yes | No; not for the intervention group | No | Yes | No/No | Yes | Fair
Markowitz, 2004^71^ | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes | No/Yes (34% overall) | Yes | Poor
Nicholson, 2017^73^ | No (shuffled envelopes) | Yes | Yes | Yes | Unclear | No | No | Yes | No/No | Yes | Fair
O’Connor, 1999^68^ | Unclear | Unclear | No; not sex | Yes | Yes | Yes | Yes | Yes | No/No | Yes | Fair
Treatment of Lead-Exposed Children (TLC) Trial Group, 2000^64^; See also: Rogan, 2001^67^; Liu, 2002^66^; Dietrich, 2004^65^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No/No | Yes | Good
Wolf, 2003^72^ | Unclear | Unclear | Unclear; only BLL reported | Yes | Unclear | Yes | Yes | Yes | No/No | Yes | Poor

Abbreviation: BLL=blood lead level.

## Appendix C3 Quality Assessment of Childhood Cohort Studies

Author, year | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria, or a random sample (inception cohort)? | Were the groups comparable at baseline on key prognostic factors? | Did the study use accurate methods for ascertaining exposures and potential confounders? | Were outcome assessors and/or data analysts blinded to the exposure being studied? | Did the article maintain comparable groups (report attrition, contamination, adherence, and cross-over)? | Did the study perform appropriate statistical analyses on potential confounders? | Is there important differential or overall high loss to followup? | Were outcomes prespecified and defined, and ascertained using accurate methods? | Quality rating
Shannon, 1988^74^ | Yes; all | Unclear | Unclear | Unclear | Unclear | No | No/No | Yes | Poor